# Acknowledgments

We are indebted to an exceptional group of colleagues who made this report possible. Each step of a systematic review draws on the skills and attention of an entire team. The authors gratefully acknowledge the following individuals for their contributions to this project:

Ms. Sanura Latham and Ms. Hollie Black assisted with formatting, data entry, and article retrieval. Ms. Nila Sathe provided guidance on logistics of the review process and organization of the report.