# Discussion

## Key Findings

### State of the Literature

We included 72 publications from 59 unique studies in this review, including 56 RCTs and three prospective controlled cohort studies. Most studies (42) were conducted in the United States with six from the United Kingdom, four from Australia, two from Canada, two from Denmark, and one study each in Scotland, Sweden, and Spain. The majority of the studies recruited pregnant women (55) and only four studies recruited women in the postpartum period. Studies enrolled women who were current smokers (42 studies), recent quitters (8 studies), or both (9 studies). There were 13 studies of good quality, 15 of fair quality, and 28 of poor quality.

### Key Question 1 (KQ1)

Fifty-six RCTs examined the effectiveness of interventions intended to achieve or maintain smoking cessation in women who are pregnant or postpartum. We categorized these studies broadly by primary intervention as counseling (14 studies), educational materials (10 studies), NRT (5 studies), peer support (4 studies), other interventions, consisting of various unique studies (9 studies); and multicomponent (14 studies) interventions. Studies within each category were heterogeneous. We only included studies that provided biochemical validation methods because discrepancies between self-reported smoking status and biochemically validated smoking status are common and sometimes considerable. The duration of followup in the studies included in this review was generally short with most studies that delivered an intervention during pregnancy limiting followup to the prenatal period. No study reported validated cessation outcomes beyond 12 months postpartum.

Eight of 24 studies of good or fair quality demonstrated effectiveness for cessation with a difference in cessation between intervention and control groups ranging from 5.8 percent to 31.0 percent, as shown in Table 26. Four of these studies used multicomponent interventions.39, 93, 110, 130 Counseling,86 educational materials,97 peer support,85 and voucher incentives84 were each the primary intervention in one positive study. This qualitative synthesis suggests that, generally speaking, multicomponent approaches were most effective, but does not provide evidence to drive selection of specific components to form those interventions. The most common interventions in successful multicomponent studies were also common in studies that failed to demonstrate effectiveness. For each study with a primary intervention that demonstrated effectiveness, there were other studies of this intervention that did not demonstrate effectiveness.

Table 26 Studies demonstrating a significant difference in smoking cessation/relapse prevention

Author, Year Country (Number Randomized) | Quality | Intervention (number analyzed) | Cessation, % | Cessation, %Δ | Significance (association)
Smoking Cessation
Heil et al., 2008^84^ U.S. (82) | Fair | Contingent vouchers (37) Control (40) | 41.0 10.0 | 31.0 | (p=0.003)
Ondersma et al., 2012^97^ U.S. (110) | Good | Educational materials (CD-5A's) (23) Usual care (23) | 43.5 17.4 | 26.1 | (p<0.05) (OR=10.1,^a^ 95% CI: 1.4 to 75.0)
Donatelle et al., 2000^110^ U.S. (220) | Fair | Multicomponent (105) Usual care (102) | 32.0 9.0 | 23.0 | (p<0.0001)
Dornelas et al., 2006^86^ U.S. (105) | Fair | Counseling (53) Usual care (52) | 28.3 9.6 | 18.7 | (p=0.02)
Windsor et al., 1985^93^ U.S. (309) | Fair | Multicomponent (102) Usual care (104) | 14.0 2.0 | 12.0 | (RR=0.12, 95% CI: 0.05 to 0.19)
Walsh et al., 1997^130^ U.S. (293) | Good | Multicomponent (127) Control (125) | 13.0 6.0 | 7.0 | (p=0.0353)
Windsor et al., 1993^39^ U.S. (994) | Fair | Multicomponent (400) Usual care (414) | 14.3 8.5 | 5.8 | (p=0.01)
Albrecht et al., 2006^85^ U.S. (142) | Good | Peer Support (TFS-B) (45) Usual care (50) | NR | NR | (p=0.01) (OR=3.73, 99% CI: 1.00 to 13.89)
Relapse Prevention
Phillips et al., 2012^80^ U.S. (54) | Good | Mother-infant bonding (21) Usual care (28) | 81.0^b^ 46.0 | 35.0 | (p<0.001)

Abbreviations: CBT = cognitive behavioral therapy; CI = confidence interval; CD-5A's = computer delivered 5A's; NRT = nicotine replacement therapy; OR = odds ratio; RR = relative risk; TFS-B = Teen FreshStart plus buddy; U.S. = United States.

Notes: Includes good and fair quality studies that demonstrated a statistically significant difference in biochemically confirmed smoking cessation or relapse prevention outcomes; rows ordered by studies in current smokers followed by studies in recent quitters and then by difference in cessation.

a Odds ratio adjusted for minority status and baseline smoking status; unadjusted OR=3.7 (95% CI: 0.94 to 14.2) p=NS

b 8 weeks postpartum

One of five studies of good or fair quality demonstrated effectiveness for relapse prevention with a 35 percent higher cessation in the intervention group than the control group, as shown in Table 26. This study evaluated a unique intervention to promote mother- infant bonding. Additional studies are needed to confirm the effectiveness of this intervention, as this study included only 54 participants and cessation outcomes were not reported beyond 8 weeks postpartum.

### Key Question 2 (KQ2)

Infant and child outcomes associated with smoking cessation and relapse prevention interventions targeted at pregnant and postpartum women have not been well-explored. Only 13 of 56 RCTs identified in this review assessed infant outcomes, and these were limited to data collected at the time of birth. No studies addressed longer-term or child outcomes. In addition, given the prevalence of adverse birth outcomes, all studies were likely underpowered to detect meaningful differences in infant outcomes in terms of both benefit and harms.

Findings regarding mean birth weight were inconsistent, and no clinically meaningful differences were identified. Only one of the seven studies that reported gestational age had statistically significant results with women who received NRT in addition to CBT giving birth an average of one week later than women who received CBT only. No studies found statistically significant differences in the incidence of preterm birth, neonatal deaths, or NICU admissions between the intervention and control groups.

### Key Question 3 (KQ3)

Only 4 out of the 56 RCTs in our review reported harms associated with smoking cessation interventions; three of these were studies in which NRT was the primary intervention. None of the studies reported a higher incidence of adverse events in women receiving interventions compared to the control groups. As noted in recent systematic reviews and reflected in the regulatory guidance from the FDA, the safety of NRT and other pharmacologic smoking cessation aids in pregnancy is uncertain. Data from the studies included in this review add little to the current understanding of NRT risks in pregnancy. The NRT trials that assessed harms had low numbers of participants and low adherence rates. A review including a much larger sample would be required to comprehensively assess the effect of this therapy on infrequent adverse birth outcomes. Caution is warranted in interpreting the lack of harms identified with NRT, particularly given risks to the fetus articulated in the FDA guidance about use of the nicotine transdermal patch in pregnancy. None of the studies that evaluated relapse prevention interventions reported harms data.

### Key Question 4 (KQ4)

Twenty-nine good or fair quality studies were available to separate out the effect of components of the smoking cessation intervention itself on cessation of smoking or durability of cessation. The most common components of the interventions were counseling, information, quit guides, personal followup, and clinic reinforcement. In a Bayesian random effects meta-analysis of the 23 studies that could be combined, the use of incentives was most clearly associated with substantially increased smoking cessation. The odds of quitting with the use of incentives were three times the odds of quitting in the absence of incentives holding all other interventions constant (OR 3.23; 95% BCI, 1.98 to 4.59). Additional intervention components that may have some positive effect, as demonstrated by 80 percent or greater probability that the odds are higher than the null for the intervention increasing smoking cessation, include feedback about biologic measures, information, personal followup, NRT, and quit guides. Clinic reinforcement, peer support, and prescriptions to quit were ineffective in these studies. Because counseling was ubiquitous and heterogeneous, it could not be appropriately measured in the meta-analysis. Therefore, we need to look at those studies that purport to be primarily focused on counseling interventions. None of those studies demonstrated effectiveness of counseling or relatively better results for any type of counseling.

The most common components of relapse prevention interventions were counseling, quit guides, information, and personal followup. These studies were too heterogeneous to conduct an analysis to assess the effect of the components. Data were not available to specifically address the impact of who delivered the intervention or where the intervention was delivered.

### Key Question 5 (KQ5)

In this literature with biochemical validation of non-smoking status, few studies explicitly examined the influence of participant characteristics on probability of response to intervention or probability of successful cessation. No randomized clinical trials that demonstrated that the intervention being studied was superior to the comparison group outcomes provided analyses of effect modification by participant characteristics. Across good and fair quality trials, consistent and inter-related baseline predictors of achieving and maintaining cessation included lower levels of tobacco dependence as measured by biomarkers, questions gauging dependence, and cigarettes per day. Data were sparse to document the influence of maternal age, parity, other smokers in the home, a non-smoking partner, and smoke free policies in the home. Data were less consistent for the effects of education, prior experience with cessation, readiness to change, and self-reported motivation to quit.

### Findings in Relationship to What Is Already Known

To put this review into context of what is currently known, we sought available systematic reviews. Fifteen systematic reviews published since 2008 were considered to be relevant. Most of the reviews looked at smoking cessation interventions overall, rather than at specific interventions.

A 2012 Cochrane review51 of pharmacologic agents for cessation included six trials of NRT agents and reported insufficient evidence to permit conclusions about benefits and harms. A 2012 meta-analysis by Myung and colleagues included six trials of NRT and one of bupropion.52 In contrast to the Cochrane review,51 Myung et al.52 found a higher rate of abstinence in pregnant smokers receiving pharmacotherapy than in women serving as controls, with no significant differences between groups in mean birth weight, rate of low birth weight, mean gestational age, and preterm birth rate. The Myung et al. analysis,52 however, included a large study that was excluded from the Cochrane review because it was judged to have high risk of bias and it is likely that this poor quality study had a significant effect on the conclusions.51

A 2011 review conducted by the British Columbia Centre for Excellence in Women's Health,54 reviewed 97 studies including observational studies and clinical trials, and reported positive effects from 14 interventions including counseling, self-help materials, and incentives; the report described weak evidence for 56 interventions and noted that 27 “showed promise.”54 A 2009 Cochrane review of randomized and quasi-randomized trials conducted between 1975 and 2008 concluded that smoking cessation interventions in pregnancy reduce the proportion of women who continue to smoke in late pregnancy.53 The treatment group in this review had a reduction in low birth weight and preterm birth as well as an increase in mean birth weight. A 2007 review of randomized controlled trials (RCTs) found no evidence that providing advice, materials, and counseling affected postpartum smoking cessation.50 Incentive-based interventions were found to be the most likely to be effective. However, the 2007 review did not attempt to identify the content of the intervention or if there were subgroups of women that were better suited to benefit from it. The review was also focused on interventions delivered during pregnancy but not in the postpartum period.50

Overall, the findings from existing systematic reviews suggest that NRT, behavioral and educational cessation strategies, and multicomponent interventions may be beneficial to women who smoke in pregnancy or the postpartum period. Despite these previous systematic review efforts, however, the efficacy of specific components and the impact of these various strategies on smoking and infant outcomes in pregnant and postpartum women remain unclear. Findings regarding birth outcomes, including birth weight and preterm birth, are inconsistent across reviews. These differences may reflect the fact that reviews differed in inclusion and exclusion criteria and thus the studies that were included.

Thus our analysis is consistent with and extends prior reviews in demonstrating mixed effects overall for pregnancy focused smoking interventions. Our review adds two important elements to the literature. First, we focus on biochemically validated outcomes, so the outcomes in our review are likely to be most accurate. Second, the use of the meta-analysis enables us to quantify the relative benefit of specific components of what are almost always multicomponent interventions in practice. This addition to the literature provides data that end users can apply in selecting interventions for their practice settings.

### Applicability

Applicability for this literature is largely dependent on the target population and the feasibility of the interventions in the clinical setting. The target populations are defined by whether women were pregnant or postpartum, whether they were current smokers or recent quitters, and whether they were selected from sociodemographically at-risk populations. Interventions could be resource intensive across axes of time, money and personnel. Thus, to ascertain the applicability of any given intervention, the potential end user must consider whether research on the intervention has been conducted in their target population, and whether the intervention is appropriate and feasible in terms of resource allocation.

The majority of studies (55 studies) included in this review recruited pregnant women; four studies were conducted in the postpartum period. Most studies (42) were conducted in the United States and thus should be applicable to the U.S. health system. Studies enrolled women who were current smokers (42 studies), recent quitters (8 studies) or both (9 studies). The duration of followup in the studies included in this review was generally short, and thus little is known about durability of effects. Most studies that delivered an intervention during pregnancy limited followup to the prenatal period. Only 15 studies reported biochemically validated cessation after birth. For studies evaluating an intervention delivered in the postpartum period, one study reported cessation at 6 weeks postpartum,79 one at 8 weeks postpartum,80 one at 3 months postpartum,81 and one at 6 months postpartum.82

It would be particularly helpful to end users to know whether certain interventions were effective in high-risk populations. One study enrolled adolescents only,85 six studies targeted income-specific groups,11, 101, 103, 106, 107, 110 and one study specifically selected participants from the Medicaid population.98 Of these, only one demonstrated a positive effect110; this study evaluated a multicomponent intervention in WIC clinics in Oregon. One study120 included only African American pregnant smokers and one study127 targeted indigenous Australian women.

Interventions were generally more effective among participants with lower levels of tobacco dependence, so even the more effective approaches may be less applicable in populations with extremely high levels of nicotine dependence. Younger maternal age, which is correlated with fewer years of smoking, was reported to be associated with improved chance of cessation.

In terms of interventions, smoking cessation and relapse prevention interventions, both prenatal and postpartum, were overwhelmingly multifaceted. Studies deployed multiple components in the intervention being compared with usual care or an alternative level of standard cessation services. As described earlier, incentives had the highest independent effect, but given that statistical model underlying the meta-analysis was additive and that the likelihood of positive effects was high for a number of intervention components, it would be reasonable for providers to select a set of components that might have greatest applicability in their setting and develop those into a multicomponent intervention. To that end, we have made relative assessments of the resources and considerations that end users might have around implementation of the components assessed in this report (Table 27).

Table 27 Resource considerations for applicability

Component | Definition | Resource Considerations
Clinic Reinforcement | Identifying participants at followup visits (usually by flagging patient charts) to remind staff to address smoking (e.g., assessment of smoking status, encouragement to achieve or maintain cessation). | Clinic reinforcement can be easily integrated into standard clinical care and conducted during usual processes such as weight and blood pressure measurements. It is low intensity in terms of human and cost resources.
Counseling | Any form of individual counseling, however brief, delivered by a range of practitioners (e.g., obstetrician, peers). | Counseling ranges in intensity. At its most intense, it can be costly in terms of provider time and can require provider training in approaches. On average, we consider it to be medium intensity in human and financial resources.
Feedback about Biologic Measures | Ultrasound images, stress tests, biochemical tests for smoking (e.g., carbon monoxide, cotinine), or other biologic data delivered to the pregnant woman. | Feedback is low in intensity by the clinical provider, but may require substantial resources to obtain biologic data, particularly if materials must be sent to an external laboratory.
Groups | Support groups or group counseling to promote and/or sustain smoking cessation. | Support groups require a trained facilitator, which may entail upfront costs, but are able to reach multiple patients simultaneously. We therefore consider them to be of moderate intensity. This would depend substantially, however, on the personnel and space availability at a given clinical site.
Incentives | Both financial and symbolic rewards (baby gifts, t-shirts, mugs, awards) contingent upon smoking reduction or cessation. This does not include gifts given at study enrollment or incentives for study visits. | Incentives are of variable resource intensity in terms of financial costs, depending on the size and type of incentives, but are easy to distribute and require little sustained effort by staff. As the intervention component found to be most effective, their relative human resource low intensity could make them an attractive option.
Information | Education about pregnancy and smoking in the form of pamphlet, video, or other educational material. This includes factual or educational material only as distinguished from a Quit Guide, which contains practical information and/or directions that the patient can use. | Providing information in the form of existing pamphlets or other educational material is a very low-intensity intervention, provided that the materials exist and are available. Producing, printing, and purchasing materials could be challenging from a resource perspective.
NRT | Pharmacological nicotine replacement therapy (e.g., patches, gum). | For the provider, this is a low-cost, low-intensity intervention. For the pregnant woman or her third-party payer, this may be viewed as costly. For the pregnant woman, the cost of NRT may be offset by savings of tobacco not purchased.
Partner/household/social context | Identification of the smoking patterns of the partner, friends, and family as key aspects of the assessment process. This may include household members. | Identification of smoking patterns in the household can be done in the context of regular history-taking in clinic visits and thus requires little additional effort on the part of the provider or the patient.
Peer support | Encouraging the identification and involvement of a peer or “buddy” for the pregnant woman as ongoing social support during the cessation process. This includes buddy contracts and lay health advisors. | Peer support requires that an individual outside of the patient-clinical dyad commit resources and potentially training time to be prepared to support the patient in quitting. It may also require clinical care sites to implement training programs and develop contracts for peers.
Personal Followup | Followup with the purpose of sustaining the impact of the other components and offering encouragement (e.g., calls, postcards, congratulations letters). | The ability to personally follow up with patients outside of the typical clinical encounter likely varies by clinical care site and should be a consideration for implementation. This effort requires both a tracking system of some sort and the personnel effort to make contacts, and is thus resource intense.
Prescription to quit | A written “prescription” from care provider typically including a target quit date. | Prescriptions to quit require little additional effort beyond the standard clinical encounter and are thus a very low-resource-intensive intervention.
Quit contract | Contract or formalized commitment to a specific quit date. | Once a contract template is developed, there is additional effort required in the clinical environment to discuss and have a fully informed commitment to the quit contract.
Quit guide | A take-home, patient-focused guide to quitting, usually incorporating some skill building, tips on reduction and cessation, and practical advice. This includes practical information and/or directions that the patient can use or do as distinguished from Information which provides factual or educational material only. | Quit guides are currently available and thus could be made available to patients fairly easily. Deciding to develop or modify existing quit guides would add to the resources needed for implementation, but this may be a consideration for clinical sites wishing to target a particular population. The resources expended for quit guides are primarily on the side of the patient in terms of time and effort.

## Summary of Strength of Evidence and Findings

Overall the evidence to answer KQs about smoking cessation and relapse prevention interventions for pregnant and postpartum women did not reach standards for high strength of evidence. The strength of evidence tables (Tables 28-30) summarize the total number of studies and within those studies the number of participants randomized. The tables also provide the assessment of the risk of bias, consistency of findings across trials, directness of the evidence, and precision of the estimate provided by the literature. For effectiveness, we assessed strength of evidence based on the good and fair quality included studies because there were enough of these studies to form a “best evidence” set that would not be obscured by biased and poorly conducted studies. To support this decision, we assessed the likelihood that inclusion of the poor quality studies would change the strength of evidence and determined that inclusion of those studies would not have modified our assessment. For infant outcomes (KQ2) and harms of interventions (KQ3), we included poor-quality studies in the strength-of-evidence assessment. These Key Questions warrant a more expansive assessment of the literature because they focus on outcomes that are rarely reported.

Table 28 Strength of evidence for effectiveness of intervention components for smoking cessation among current smokers in pregnancy

Number of Studies (participants randomized) Intervention Component | Risk of Bias | Consistency | Directness | Precision | OR (BCI) Posterior Probability^a^ Strength of Evidence^b^
Incentives | Medium | Consistent | Direct | Precise | 3.23 (1.98 to 4.59) 100% Moderate for effect
Feedback | Medium | Inconsistent | Direct | Precise | 1.43 (0.88 to 2.03) 95% Low for effect
Information | Medium | Inconsistent | Direct | Precise | 1.32 (0.88 to 1.79) 93% Low for effect
Personal followup | Medium | Inconsistent | Direct | Precise | 1.25 (0.94 to 1.57) 95% Low for effect
NRT | Medium | Inconsistent | Direct | Precise | 1.24 (0.84 to 1.68) 87% Low for effect
Quit guide | Medium | Inconsistent | Direct | Precise | 1.18 (0.82 to 1.56) 83% Low for effect
Prescription to quit | Medium | Inconsistent | Direct | Precise | 1.13 (0.46 to 1.95) 57% Low for no effect
Peer support | Medium | Inconsistent | Direct | Precise | 1.07 (0.7 to 1.46) 60% Low for no effect
Clinic reinforcement | Medium | Inconsistent | Direct | Precise | 1.05 (0.65 to 1.49) 55% Low for no effect

Note: Table data from 8, 086 participants randomized in 23 RCTs39, 83-93, 97, 100-102, 107, 110, 117, 119, 122, 123, 130 BCI = Bayesian credible interval; OR = odds ratio.

a Probability that the OR is greater than the null

b The effect is positive if the posterior probability is 80% or greater

Table 29 Strength of evidence for infant outcomes associated with smoking cessation interventions in pregnancy and the postpartum period compared with usual care or other interventions

Outcome | Number of Studies (participants randomized) | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect Strength of Evidence
Birth weight | 13 RCTs84, 102, 104, 105, 117, 120-122, 124, 129, 132-134 (5759) | Medium | Inconsistent | Direct | Imprecise | Insufficient to determine effect
Gestational age | 7 RCTs84, 102, 104, 120-122, 132 (2423) | Medium | Inconsistent | Direct | Imprecise | Insufficient to determine effect
Neonatal death | 2 RCTs122, 132 (1812) | Medium | Consistent | Direct | Imprecise | Insufficient to determine effect
Preterm birth | 7 RCTs84, 117, 120, 122, 129, 132, 134 (4005) | Medium | Consistent | Direct | Imprecise | No significant difference Low for lack of effect
NICU admission | 6 RCTs84, 105, 117, 121, 122, 132 (2621) | Medium | Consistent | Direct | Imprecise | No significant difference Low for lack of effect

Table 30 Strength of evidence for harms of interventions for smoking cessation in pregnancy and the postpartum period

Outcome Intervention | Number of Studies (participants randomized) | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect Strength of Evidence
Maternal and fetal-neonatal adverse effects NRT plus counseling vs. counseling | 3 RCTs102, 104, 122(1425) | Medium | Inconsistent | Indirect | Imprecise | Insufficient to determine effect
Stress levels Quit guides vs. quit guides and interaction computer program vs. standard advice | 1 RCT125 (918) | High | NA | Indirect | Imprecise | Insufficient to determine effect

We assessed the strength of evidence for the effectiveness of intervention components using the meta-analysis for all components other than counseling, which was ubiquitous across studies. Strength of evidence was moderate for the effectiveness of incentives and low for all other intervention components (Table 28).

There is insufficient strength of evidence to determine the effect of smoking cessation interventions on birth weight, gestational age, and neonatal deaths (Table 29). There is low strength of evidence for no significant effect on preterm birth and NICU admission (Table 29). There is also insufficient strength of evidence to determine the harms of smoking cessation interventions (Table 30).

## Implications for Clinical and Policy Decisionmaking

As clinicians and policymakers consider implementing smoking cessation interventions, their primary consideration is choosing those approaches that are most likely to be effective and feasible. Qualitatively, this review suggests approaches that combine multiple components will have the best likelihood of success. Selecting which components to include is more complex and should be based on the particular considerations of the interventions and clinical setting.

Efficacy is foremost in choosing the combination of interventions in a multicomponent strategy. The meta-analysis presented in this review allowed us to calculate the posterior probability that specific intervention components contributed to success of smoking cessation. Multiple components had a greater than 80 percent probability of having a positive effect with incentives demonstrating the strongest effect. While incentives require a financial investment, they are not time intensive. In addition, prior research in other fields, such as weight loss,148, 149, vaccination,150, and medication adherence151 suggests that modest incentives can be adequate to change behavior. However, use of financial incentives remains controversial. The other components with high probability of success were feedback about biologic measures, information, personal followup, NRT, and quit guides. Our meta-analysis results suggested that clinic reinforcement, peer support, and prescriptions to quit contributed little in multicomponent interventions.

Resource allocation is another important consideration in selecting which smoking cessation interventions to implement. Financial and human resources needed for development and implementation vary by intervention (Table 27). In addition to resources, the logistics of the clinical setting and how a specific intervention can be integrated into current processes or added needs to be assessed.

Harms must also be evaluated in selecting which interventions to implement. With the exception of medications, for which limited harms data are available, smoking cessation interventions lack adverse effects. The safety of these interventions makes it reasonable to include a number of interventions in a multicomponent approach.

Understanding whether specific populations of patients are more amenable to behavior change could be useful in intervention development and implementation. Although few data are available to guide targeting of services, the research reviewed in this report suggests that women who are less tobacco dependent, younger, and of lower parity may have a greater chance of successfully quitting. More intensive interventions are worth considering for other populations of women (e.g., heavier smokers, older, higher parity) who are less likely to successfully quit smoking.

## Limitations of This Review

Studies of effectiveness in this review were limited to RCTs which are known at times to have limited applicability and to be suboptimal for assessing harms and long-term outcomes. Nonetheless, they provide the greatest evidence for effectiveness, and we had adequate numbers of RCTs to evaluate these interventions. Limiting trials to those with biochemical validation improves the accuracy of outcomes but decreases the number of studies that are available to provide information. We required cessation, rather than reduction, as the outcome because this is the optimal outcome for maternal and infant health.

## Limitations of the Evidence Base

Nearly half of the studies (n=28) were of poor quality, and the most common reason for high risk of bias was incomplete outcome data. Losses to followup varied by intervention, but the reasons for this variation and its impact on the results are unclear. Studies were most commonly rated fair quality (n=15) due to unclear risk of bias associated with allocation concealment and random sequence generation.

The interventions are almost always multicomponent as is the care to which they are being compared. Because the interventions are often poorly characterized, it can be difficult to clearly identify the components of the intervention and what is having the effect. In addition, poor characterization of interventions reduces the potential that they can be replicated both in practice and in research. None of the studies adequately assessed intervention fidelity, which is likely to be particularly challenging with behavioral interventions and has implications for biasing the estimate of effect and the applicability of the results. The field is not consistent in selecting a specific gestational age as the optimal time point to measure cessation, which makes comparing studies very difficult. For example, outcomes reported as the end of pregnancy spanned the entire third trimester. More precision around ideal end points would help future research. Ideally these should be linked to fetal development and likelihood of being able to maintain cessation. Few studies assess cessation beyond birth, which is important in light of the high rate of relapse and need to know which interventions are most durable.

## Future Research Needs

Future research needs around smoking cessation in pregnancy are both substantive and methodologic. There are several interventions that warrant additional research and replication, including better assessments. Priorities for future research about interventions include—

- Conducting additional studies of incentives, including the amount needed and under what circumstances they are effective.
- Replicating the evaluation of the mother-infant bonding intervention that was found to be effective in the relapse prevention study.
- Developing much more rigorous studies that isolate counseling and its components. Counseling was ubiquitous, and studies were heterogeneous in their approach.
- Studying intervention components, either in isolation or in multicomponent studies with very high rigor, identified in the meta-analysis as having a high probability of being effective so that the effect of individual components, or specific combinations of components, can be measured.

Methodologic and study design considerations for future research include—

- Clear characterization of the components of both the intervention and comparator.
- A plan for assessment and reporting of fidelity of intervention implementation and the potential for crossover of the intervention into the comparator group.
- Use of biochemically validated outcomes. Self-report is known to underestimate smoking prevalence. A sustained measure of smoking abstinence, as opposed to a point prevalence measure, would be ideal.
- Assessment of the degree to which timing matters in successfully achieving cessation Intervention timing varies substantially across studies, including early and late in pregnancy, and some studies suggest interventions may have potential for getting women to stop earlier even when overall differences are not significant.
- Adequate sample sizes with long-term followup. Current studies are short term and have no ability to assess effectiveness over time including long-term health implications. This is in part due to need for large numbers at study inception in order to maintain adequate power over time. Larger sample sizes are needed to assess comprehensively infant and longer term child outcomes as well as events and harms.
- Identification of the underlying study purpose. There is a lack of clarity overall in this body of research about whether encouraging women to stop smoking in pregnancy is for the purpose of optimizing fetal growth or creating a smoke free home by the end of pregnancy. While both goals are important, identifying the specific underlying rationale for a study can help in intervention development in a way that is targeted and potentially more effective.

## Conclusions

Across interventions, data are sparse to evaluate sustained cessation among pregnant and postpartum women. This review suggests approaches that combine multiple components will have the best likelihood of success. Selecting which components to include is more complex and should be based on the particular considerations of the clinical setting including patient characteristics and resource allocation, but incentives demonstrated the greatest effect among components studied. Infant outcomes are limited to data collected at time of birth; no studies assessed longer-term or child outcomes. Harms data were rarely reported.