# Risk of Bias and Quality Score for Individual Studies

Table I1 Risk of bias and quality score for RCTs

Author, year | Random Sequence Generation | Allocation Conceal | Selective Reporting | Other Bias | Blinding (patients/personnel) | Blinding (outcome assessment) | Incomplete Outcome Data | High | Low | Unclear | Quality Score
Eades, et al., 2012^1^ | H | H | L | L | H | L | H | 4 | 3 | 0 | Poor
Coleman, et al., 2012^2^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Naughton, et al., 2012^3^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Ondersma, et al., 2012^4^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Tuten, et al., 2012^5^ | U | U | L | L | L | L | H | 1 | 4 | 2 | Poor
Phillips, et al., 2012^6^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Windsor, et al., 2011^7^ | L | L | L | U | H | L | L | 1 | 5 | 1 | Poor
Reitzel, et al., 2010^8^ | L | L | L | L | H | L | L | 1 | 6 | 0 | Poor
Cinciripini, et al., 2010^9^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Hennrikus, et al., 2010^10^ | L | U | L | L | U | L | L | 0 | 5 | 2 | Fair
Stotts, et al., 2009^11^ | L | U | L | L | L | L | L | 0 | 6 | 1 | Fair
Oncken, et al., 2008^12^ | L | L | L | L | L | L | U | 0 | 6 | 1 | Fair
Bullock, et al., 2009^13^ | L | L | L | L | L | L | H | 1 | 6 | 0 | Poor
Heil, et al., 2008^14^ | L | U | L | L | L | L | L | 0 | 6 | 1 | Fair
Pollak, et al., 2007^15^ | L | L | L | L | H | L | L | 1 | 6 | 0 | Poor
Ruger, et al., 2008^16^ | U | U | L | L | U | L | H | 1 | 3 | 3 | Poor
Albrecht, et al., 2006^17^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Dornelas, et al., 2006^18^ | U | U | L | L | L | L | L | 0 | 5 | 2 | Fair
Rigotti, et al., 2006^19^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Suplee, 2005^20^ | U | L | L | L | L | L | L | 0 | 6 | 1 | Fair
Tappin, et al., 2005^21^ | L | L | L | L | H | L | L | 1 | 6 | 0 | Poor
Hotham, et al., 2006^22^ | L | L | L | L | H | L | H | 2 | 5 | 0 | Poor
Pbert, et al., 2004^23^ | L | L | L | L | L | L | H | 1 | 6 | 0 | Poor
Cope, et al., 2003^24^ | H | H | L | L | L | L | H | 3 | 4 | 0 | Poor
Hegaard, et al., 2003^25^ | H | H | L | L | L | L | L | 2 | 5 | 0 | Poor
Lawrence, et al., 2003^26^ | U | H | L | L | L | L | L | 1 | 5 | 1 | Poor
Malchodi, et al., 2003^27^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Moore, et al., 2002^28^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Stotts, et al., 2002^29^ | L | L | L | H | L | L | H | 2 | 5 | 0 | Poor
Hajek, et al., 2001^30^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Ershoff, et al., 1999^31^ | U | U | L | L | L | L | L | 0 | 5 | 2 | Fair
Solomon, et al., 2000^32^ | U | U | L | H | L | L | L | 1 | 4 | 2 | Poor
Donatelle, et al., 2000^33^ | U | U | L | L | L | L | L | 0 | 5 | 2 | Fair
Johnson, et al., 2000^34^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Panjari, et al., 1999^35^ | U | U | L | L | L | L | H | 1 | 4 | 2 | Poor
Secker-Walker, et al., 1998^36^ | U | U | L | L | L | L | H | 1 | 4 | 2 | Poor
Secker-Walker, et al., 1998^37^ | U | U | L | U | L | L | L | 0 | 4 | 3 | Fair
Walsh, et al., 1997^38^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Gielen, et al., 1997^39^ | U | U | L | L | L | L | L | 0 | 5 | 2 | Fair
Lowe, et al., 1997^40^ | U | U | L | H | L | L | L | 1 | 4 | 2 | Poor
Secker-Walker, et al., 1997^41^ | U | U | L | H | L | L | L | 1 | 4 | 2 | Poor
Hartmann, et al., 1996^42^ | L | L | L | L | L | L | L | 0 | 7 | 0 | Good
Ershoff, et al., 1995^43^ | U | U | L | L | L | L | L | 0 | 5 | 2 | Fair
Secker-Walker, et al., 1995^44^ | U | U | L | L | L | L | H | 1 | 4 | 2 | Poor
Kendrick, et al., 1995^45^ | U | U | L | L | L | L | H | 1 | 4 | 2 | Poor
Secker-Walker, et al., 1994^46^ | U | L | L | H | L | L | H | 2 | 4 | 1 | Poor
Windsor, et al., 1993^47^ | L | U | L | L | L | L | L | 0 | 6 | 1 | Fair
O'Connor, et al., 1992^48^ | H | H | L | U | L | U | H | 3 | 2 | 2 | Poor
Price, et al., 1991^49^ | U | L | L | U | L | L | H | 1 | 4 | 2 | Poor
Hjalmarson, et al., 1991^50^ | H | H | L | U | L | L | L | 2 | 4 | 1 | Poor
Ershoff, et al., 1989^51^ | U | U | L | L | L | L | L | 0 | 5 | 2 | Fair
Windsor, et al., 1985^52^ | L | U | L | L | L | L | L | 0 | 6 | 1 | Fair
Bauman, et al., 1983^53^ | L | U | L | L | L | L | H | 1 | 5 | 1 | Poor
Burling, et al., 1991^54^ | U | U | L | L | L | L | U | 0 | 4 | 3 | Fair
El-Mohandes, et al., 2012^55^ | L | L | L | L | H | L | L | 1 | 6 | 0 | Poor
Jimenez-Muro, et al., 2012^56^ | H | H | L | L | L | L | H | 3 | 4 | 0 | Poor
High | 6 | 7 | 0 | 5 | 7 | 0 | 17 | 42
Low | 29 | 26 | 56 | 46 | 47 | 55 | 37 | | 296
Unclear | 21 | 23 | 0 | 5 | 2 | 1 | 2 | | | 54

Table I2 Quality score for cohort studies

Author, year | Selection | Comparability | Outcome | Total Points | Quality Score
Gadomski, et al., 2011^57^ | 4/4 | 1/2 | 3/3 | 8 | Fair
Windsor, et al., 2000^58^ | 4/4 | 1/2 | 3/3 | 8 | Fair
Wisborg, et al., 1998^59^ | 2/4 | 2/2 | 1/3 | 5 | Poor

## References

1 Eades SJ, Sanson-Fisher RW, Wenitong M, et al. An intensive smoking intervention for pregnant Aboriginal and Torres Strait Islander women: a randomised controlled trial. Med J Aust. Jul. 2. 2012;197(1):42-6. [pmid: 22762231].
2 Coleman T, Cooper S, Thornton JG, et al. A randomized trial of nicotine-replacement therapy patches in pregnancy. N Engl J Med. Mar. 1. 2012;366(9):808-18. [pmid: 22375972].
3 Naughton F, Prevost AT, Gilbert H, et al. Randomized controlled trial evaluation of a tailored leaflet and SMS text message self-help intervention for pregnant smokers (MiQuit). Nicotine Tob Res. May. 2012;14(5):569-77. [pmid: 22311960].
4 Ondersma SJ, Svikis DS, Lam PK, et al. A randomized trial of computer-delivered brief intervention and low-intensity contingency management for smoking during pregnancy. Nicotine Tob Res. Mar. 2012;14(3):351-60. [pmid: 22157229].
5 Tuten M, Fitzsimons H, Chisolm MS, et al. Contingent incentives reduce cigarette smoking among pregnant, methadone-maintained women: Results of an initial feasibility and efficacy randomized clinical trial. Addiction. 2012;107(10):1868-77. [pmid: 22716774].
6 Phillips RM, Merritt TA, Goldstein MR, et al. Prevention of postpartum smoking relapse in mothers of infants in the neonatal intensive care unit. J Perinatol. May. 2012;32(5):374-80. [pmid: 21836549].
7 Windsor R, Woodby L, Miller T, et al. Effectiveness of Smoking Cessation and Reduction in Pregnancy Treatment (SCRIPT) methods in Medicaid-supported prenatal care: Trial III. Health Educ Behav. Aug. 2011;38(4):412-22. [pmid: 21551424].
8 Reitzel LR, Vidrine JI, Businelle MS, et al. Preventing postpartum smoking relapse among diverse low-income women: a randomized clinical trial. Nicotine Tob Res. Apr. 2010;12(4):326-35. [pmid: 20154055].
9 Cinciripini PM, Blalock JA, Minnix JA, et al. Effects of an intensive depression-focused intervention for smoking cessation in pregnancy. J Consult Clin Psychol. Feb. 2010;78(1):44-54. [pmid: 20099949].
10 Hennrikus D, Pirie P, Hellerstedt W, et al. Increasing support for smoking cessation during pregnancy and postpartum: results of a randomized controlled pilot study. Prev Med. Mar. 2010;50(3):134-7. [pmid: 20079760].
11 Stotts AL, Groff JY, Velasquez MM, et al. Ultrasound feedback and motivational interviewing targeting smoking cessation in the second and third trimesters of pregnancy. Nicotine Tob Res. Aug. 2009;11(8):961-8. [pmid: 19553282].
12 Oncken C, Dornelas E, Greene J, et al. Nicotine gum for pregnant smokers: a randomized controlled trial. Obstet Gynecol. Oct. 2008;112(4):859-67. [pmid: 18827129].
13 Bullock L, Everett KD, Mullen PD, et al. Baby BEEP: A randomized controlled trial of nurses' individualized social support for poor rural pregnant smokers. Matern Child Health J. May. 2009;13(3):395-406. [pmid: 18496746].
14 Heil SH, Higgins ST, Bernstein IM, et al. Effects of voucher-based incentives on abstinence from cigarette smoking and fetal growth among pregnant women. Addiction. Jun. 2008;103(6):1009-18. [pmid: 18482424].
15 Pollak KI, Oncken CA, Lipkus IM, et al. Nicotine replacement and behavioral therapy for smoking cessation in pregnancy. Am J Prev Med. Oct. 2007;33(4):297-305. [pmid: 17888856].
16 Ruger JP, Weinstein MC, Hammond SK, et al. Cost-effectiveness of motivational interviewing for smoking cessation and relapse prevention among low-income pregnant women: a randomized controlled trial. Value Health. Mar-Apr. 2008;11(2):191-8. [pmid: 17854434].
17 Albrecht SA, Caruthers D, Patrick T, et al. A randomized controlled trial of a smoking cessation intervention for pregnant adolescents. Nurs Res. Nov-Dec. 2006;55(6):402-10. [pmid: 17133147].
18 Dornelas EA, Magnavita J, Beazoglou T, et al. Efficacy and cost-effectiveness of a clinic-based counseling intervention tested in an ethnically diverse sample of pregnant smokers. Patient Educ Couns. Dec. 2006;64(1-3):342-9. [pmid: 16859864].
19 Rigotti NA, Park ER, Regan S, et al. Efficacy of telephone counseling for pregnant smokers: a randomized controlled trial. Obstet Gynecol. Jul. 2006;108(1):83-92. [pmid: 16816060].
20 Suplee PD. The importance of providing smoking relapse counseling during the postpartum hospitalization. J Obstet Gynecol Neonatal Nurs. Nov-Dec. 2005;34(6):703-12. [pmid: 16282228].
21 Tappin DM, Lumsden MA, Gilmour WH, et al. Randomised controlled trial of home based motivational interviewing by midwives to help pregnant smokers quit or cut down. BMJ. Aug. 13. 2005;331(7513):373-7. [pmid: 16096304].
22 Hotham ED, Gilbert AL, Atkinson ER. A randomised-controlled pilot study using nicotine patches with pregnant women. Addict Behav. Apr. 2006;31(4):641-8. [pmid: 15985339].
23 Pbert L, Ockene JK, Zapka J, et al. A community health center smoking-cessation intervention for pregnant and postpartum women. Am J Prev Med. Jun. 2004;26(5):377-85. [pmid: 15165653].
24 Cope GF, Nayyar P, Holder R. Feedback from a point-of-care test for nicotine intake to reduce smoking during pregnancy. Ann Clin Biochem. Nov. 2003;40(Pt 6):674-9. [pmid: 14629807].
25 Hegaard HK, Kjaergaard H, Moller LF, et al. Multimodal intervention raises smoking cessation rate during pregnancy. Acta Obstet Gynecol Scand. Sep. 2003;82(9):813-9. [pmid: 12911442].
26 Lawrence T, Aveyard P, Evans O, et al. A cluster randomised controlled trial of smoking cessation in pregnant women comparing interventions based on the transtheoretical (stages of change) model to standard care. Tob Control. Jun. 2003;12(2):168-77. [pmid: 12773727].
27 Malchodi CS, Oncken C, Dornelas EA, et al. The effects of peer counseling on smoking cessation and reduction. Obstet Gynecol. Mar. 2003;101(3):504-10. [pmid: 12636954].
28 Moore L, Campbell R, Whelan A, et al. Self help smoking cessation in pregnancy: cluster randomised controlled trial. BMJ. Dec. 14. 2002;325(7377):1383. [pmid: 12480850].
29 Stotts AL, Diclemente CC, Dolan-Mullen P. One-to-one: a motivational intervention for resistant pregnant smokers. Addict Behav. Mar-Apr. 2002;27(2):275-92. [pmid: 11817768].
30 Hajek P, West R, Lee A, et al. Randomized controlled trial of a midwife-delivered brief smoking cessation intervention in pregnancy. Addiction. Mar. 2001;96(3):485-94. [pmid: 11255587].
31 Ershoff DH, Quinn VP, Boyd NR, et al. The Kaiser Permanente prenatal smoking-cessation trial: when more isn't better, what is enough?. Am J Prev Med. Oct. 1999;17(3):161-8. [pmid: 10987630].
32 Solomon LJ, Secker-Walker RH, Flynn BS, et al. Proactive telephone peer support to help pregnant women stop smoking. Tob Control. Suppl 3. 2000;9:III72-4. [pmid: 10982914].
33 Donatelle RJ, Prows SL, Champeau D, et al. Randomised controlled trial using social support and financial incentives for high risk pregnant smokers: significant other supporter (SOS) program. Tob Control. Suppl 3. 2000;9:III67-9. [pmid: 10982912].
34 Johnson JL, Ratner PA, Bottorff JL, et al. Preventing smoking relapse in postpartum women. Nurs Res. Jan-Feb. 2000;49(1):44-52. [pmid: 10667628].
35 Panjari M, Bell R, Bishop S, et al. A randomized controlled trial of a smoking cessation intervention during pregnancy. Aust N Z J Obstet Gynaecol. Aug. 1999;39(3):312-7. [pmid: 10554941].
36 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Smoking relapse prevention during pregnancy. A trial of coordinated advice from physicians and individual counseling. Am J Prev Med. Jul. 1998;15(1):25-31. [pmid: 9651635].
37 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Reducing smoking during pregnancy and postpartum: physician's advice supported by individual counseling. Prev Med. May-Jun. 1998;27(3):422-30. [pmid: 9612832].
38 Walsh RA, Redman S, Brinsmead MW, et al. A smoking cessation program at a public antenatal clinic. Am J Public Health. Jul. 1997;87(7):1201-4. [pmid: 9240113].
39 Gielen AC, Windsor R, Faden RR, et al. Evaluation of a smoking cessation intervention for pregnant women in an urban prenatal clinic. Health Educ Res. Jun. 1997;12(2):247-54. [pmid: 10168576].
40 Lowe JB, Windsor R, Balanda KP, et al. Smoking relapse prevention methods for pregnant women: a formative evaluation. Am J Health Promot. Mar-Apr. 1997;11(4):244-6. [pmid: 10165516].
41 Secker-Walker RH, Solomon LJ, Geller BM, et al. Modeling smoking cessation: exploring the use of a videotape to help pregnant women quit smoking. Women Health. 1997;25(1):23-35. [pmid: 9253136].
42 Hartmann KE, Thorp JM Jr., Pahel-Short L, et al. A randomized controlled trial of smoking cessation intervention in pregnancy in an academic clinic. Obstet Gynecol. Apr. 1996;87(4):621-6. [pmid: 8602320].
43 Ershoff DH, Quinn VP, Mullen PD. Relapse prevention among women who stop smoking early in pregnancy: a randomized clinical trial of a self-help intervention. Am J Prev Med. May-Jun. 1995;11(3):178-84. [pmid: 7662397].
44 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Smoking relapse prevention counseling during prenatal and early postnatal care. Am J Prev Med. Mar-Apr. 1995;11(2):86-93. [pmid: 7632455].
45 Kendrick JS, Zahniser SC, Miller N, et al. Integrating smoking cessation into routine public prenatal care: the Smoking Cessation in Pregnancy project. Am J Public Health. Feb. 1995;85(2):217-22. [pmid: 7856781].
46 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Individualized smoking cessation counseling during prenatal and early postnatal care. Am J Obstet Gynecol. Nov. 1994;171(5):1347-55. [pmid: 7977545].
47 Windsor RA, Lowe JB, Perkins LL, et al. Health education for pregnant smokers: its behavioral impact and cost benefit. Am J Public Health. Feb. 1993;83(2):201-6. [pmid: 8427323].
48 O'Connor AM, Davies BL, Dulberg CS, et al. Effectiveness of a pregnancy smoking cessation program. J Obstet Gynecol Neonatal Nurs. Sep-Oct. 1992;21(5):385-92. [pmid: 1403224].
49 Price JH, Krol RA, Desmond SM, et al. Comparison of three antismoking interventions among pregnant women in an urban setting: a randomized trial. Psychol Rep. Apr. 1991;68(2):595-604. [pmid: 1862191].
50 Hjalmarson AI, Hahn L, Svanberg B. Stopping smoking in pregnancy: effect of a self-help manual in controlled trial. Br J Obstet Gynaecol. Mar. 1991;98(3):260-4. [pmid: 2021564].
51 Ershoff DH, Mullen PD, Quinn VP. A randomized trial of a serialized self-help smoking cessation program for pregnant women in an HMO. Am J Public Health. Feb. 1989;79(2):182-7. [pmid: 2913837].
52 Windsor RA, Cutter G, Morris J, et al. The effectiveness of smoking cessation methods for smokers in public health maternity clinics: a randomized trial. Am J Public Health. Dec. 1985;75(12):1389-92. [pmid: 4061709].
53 Bauman KE, Bryan ES, Dent CW, et al. The influence of observing carbon monoxide level on cigarette smoking by public prenatal patients. Am J Public Health. Sep. 1983;73(9):1089-91. [pmid: 6881407].
54 Burling TA, Bigelow GE, Robinson JC, et al. Smoking during pregnancy: Reduction via objective assessment and directive advice. Behavior Therapy. 1991;22(1):31-40.
55 El-Mohandes AA, Windsor R, Tan S, et al. A Randomized Clinical Trial of Trans-Dermal Nicotine Replacement in Pregnant African-American Smokers. Matern Child Health J. 2012. Jul. 4. [pmid: 22761006].
56 Jimenez-Muro A, Nerin I, Samper P, et al. A proactive smoking cessation intervention in postpartum women. Midwifery. 2012. Feb. 21. [pmid: 22361008].
57 Gadomski A, Adams L, Tallman N, et al. Effectiveness of a combined prenatal and postpartum smoking cessation program. Matern Child Health J. Feb. 2011;15(2):188-97. [pmid: 20091107].
58 Windsor RA, Woodby LL, Miller TM, et al. Effectiveness of Agency for Health Care Policy and Research clinical practice guideline and patient education methods for pregnant smokers in medicaid maternity care. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):68-75. [pmid: 10649158].
59 Wisborg K, Henriksen TB, Secher NJ. A prospective intervention study of stopping smoking in pregnancy in a routine antenatal care setting. Br J Obstet Gynaecol. Nov. 1998;105(11):1171-6. [pmid: 9853765].