# Evidence Tables

Table H1 Evidence table (Reference ID# 2)

Table H2 Evidence table (Reference ID# 11

Table H3 Evidence table (Reference ID# 18)

Table H4 Evidence table (Reference ID# 31)

Table H5 Evidence table (Reference ID# 58)

Table H6 Evidence table (Reference ID# 72)

Table H7 Evidence table (Reference ID# 171)

Table H8 Evidence table (Reference ID# 176)

Table H9 Evidence table (Reference ID# 178)

Table H10 Evidence table (Reference ID# 181)

Table H11 Evidence table (Reference ID# 231)

Table H12 Evidence table (Reference ID# 291)

Table H13 Evidence table (Reference ID #336)

Table H14 Evidence table (Reference ID# 337)

Table H15 Evidence table (Reference ID# 395)

Table H16 Evidence table (Reference ID# 396)

Table H17 Evidence table (Reference ID #463)

Table H18 Evidence table (Reference ID #495)

Table H19 Evidence table (Reference ID #497)

Table H20 Evidence table (Reference ID# 547)

Table H21 Evidence table (Reference ID# 564)

Table H22 Evidence table (Reference ID# 578)

Table H23 Evidence table (Reference ID# 675)

Table H24 Evidence table (Reference ID# 708)

Table H25 Evidence table (Reference ID# 725)

Table H26 Evidence table (Reference ID# 736)

Table H27 Evidence table (Reference ID# 746)

Table H28 Evidence table (Reference ID# 761)

Table H29 Evidence table (Reference ID# 807)

Table H30 Evidence table (Reference ID# 850)

Table H31 Evidence table (Reference ID# 880)

Table H32 Evidence table (Reference ID# 886)

Table H33 Evidence table (Reference ID# 887)

Table H34 Evidence table (Reference ID# 928)

Table H35 Evidence table (Reference ID# 929)

Table H36 Evidence table (Reference ID# 939)

Table H37 Evidence table (Reference ID #974)

Table H38 Evidence table (Reference ID# 992)

Table H39 Evidence table (Reference ID# 997)

Table H40 Evidence table (Reference ID# 1023)

Table H41 Evidence table (Reference ID# 1028)

Table H42 Evidence table (Reference ID# 1041)

Table H43 Evidence table (Reference ID# 1046)

Table H44 Evidence table (Reference ID# 1077)

Table H45 Evidence table (Reference ID# 1109)

Table H46 Evidence table (Reference ID# 1117)

Table H47 Evidence table (Reference ID# 1118)

Table H48 Evidence table (Reference ID# 1134)

Table H49 Evidence table (Reference ID# 1187)

Table H50 Evidence table (Reference ID# 1203)

Table H51 Evidence table (Reference ID# 1237)

Table H52 Evidence table (Reference ID# 1239)

Table H53 Evidence table (Reference ID# 1285)

Table H54 Evidence table (Reference ID# 1332)

Table H55 Evidence table (Reference ID# 1359)

Table H56 Evidence table (Reference ID# 1640)

Table H57 Evidence table (Reference ID# 2284)

Table H58 Evidence table (Reference ID# 2285)

Table H59 Evidence table (Reference ID# 3597)