# Reasons for Exclusion

Exclusion Code | Exclusion Reason | Count
X-1 | Does not report results from a clinically-oriented smoking cessation intervention/a cessation intervention that intersects with clinical care and is aimed at pregnant women or postpartum women. | 2015
X-2 | Does not report original research. | 90
X-3 | Does not include 20 or more participants in each group. | 159
X-4 | Not an eligible study design. | 245
X-5 | Does not report outcomes/results for smoking cessation intervention(s). | 184
X-6 | Not an eligible study population. | 120
X-7 | Does not report biochemical validation of abstinence outcomes. | 57
X-8 | Unavailable. | 3
X-9 | Duplicate. | 3
N/A | Related to an included study but does not address a Key Question | 8

## References

1 Smoking and pregnancy. Med J Aust. Apr. 7. 1973;1(14):671. X-8. [pmid: 4701856].
2 Cigarette smoking among reproductive-aged women--Behavioral Risk Factor Surveillance System, 1989. Patient Educ Couns. Jun. 1992;19(3):293-6. X-5. [pmid: 1300629].
3 Heavy smokers in pregnancy…. Valbo A, Nylander G. Smoking cessation in pregnancy: intervention among heavy smokers. Acta Obstetrica et Gynaecologica Scandinavica. 1994;73:215-219. Professional Care of Mother & Child 1994;4(7):221. X-2.
4 The Agency for Health Care Policy and Research Smoking Cessation Clinical Practice Guideline. JAMA: Journal of the American Medical Association. 1996;275(16):1270-80. X-2, X-3, X-4, X-5, X-6. [pmid: 8601960].
5 Smoking cessation program focuses on pregnant women. Healthc Demand Dis Manag. Nov. 1997;3(11):169-73. X-2, X-3, X-4, X-6. [pmid: 10181077].
6 Specific targets of cessation efforts. J Indian Med Assoc. Sep. 1999;97(9):384. X-2, X-3, X-4, X-5, X-6. [pmid: 10638092].
7 Smoking cessation during pregnancy. J Okla State Med Assoc. Mar. 2002;95(3):180-2. X-2, X-3, X-4, X-5, X-6. [pmid: 11921869].
8 ACOG committee opinion. Number 316, October 2005. Smoking cessation during pregnancy. Obstet Gynecol. Oct. 2005;106(4):883-8. X-2, X-3, X-4, X-5, X-6. [pmid: 16199654].
9 How to quit smoking. Adv Nurse Pract. Feb. 2008;16(2):39. X-2, X-3, X-4, X-5, X-6. [pmid: 19999445].
10 Smoking and women's health. Nurs Womens Health. Oct. 2010;14(5):427-9. X-2, X-3, X-4, X-5, X-6. [pmid: 20955537].
11 Smoking and women's health. J Obstet Gynecol Neonatal Nurs. Sep-Oct. 2010;39(5):611-3. X-3, X-4, X-5, X-6. [pmid: 20698933].
12 Systematic review of how to stop smoking in pregnancy and following childbirth. Journal of Advanced Nursing. 2010;66(12):2620-6. X-4.
13 Aaronson NK, Ershoff DH, Danaher BG. Smoking cessation in pregnancy: a self-help approach. Addict Behav. 1985;10(1):103-8. X-4. [pmid: 4003132].
14 Agboola S, McNeill A, Coleman T, et al. A systematic review of the effectiveness of smoking relapse prevention interventions for abstinent smokers. Addiction. 2010;105(8):1362-80. X-4. [pmid: 20653619].
15 Albrecht S, Cassidy B, Salamie D, et al. A smoking cessation intervention for pregnant adolescents: implications for nurse practitioners. J Am Acad Nurse Pract. Apr. 1999;11(4):155-9. X-2, X-3, X-4, X-5, X-6. [pmid: 10504929].
16 Albrecht S, Kelly-Thomas K, Osborne JW, et al. The SUCCESS program for smoking cessation for pregnant women. Journal of Obstetric, Gynecologic, & Neonatal Nursing: Clinical Scholarship for the Care of Women, Childbearing Families, & Newborns. 2011;40(5):520-31. X-4, X-5, X-6. [pmid: 22273409].
17 Albrecht S, Payne L, Stone CA, et al. A preliminary study of the use of peer support in smoking cessation programs for pregnant adolescents. J Am Acad Nurse Pract. Mar. 1998;10(3):119-25. X-3. [pmid: 9644411].
18 Albrecht SA. Smoking cessation in pregnancy: Health implications for mothers, infants and families. Nurs Womens Health. Jun. 2010;14(3):177-9. X-2, X-3, X-4, X-5, X-6. [pmid: 20579293].
19 Albrecht SA, Cornelius MD, Braxter B, et al. An assessment of nicotine dependence among pregnant adolescents. J Subst Abuse Treat. Jun. 1999;16(4):337-44. X-4, X-5. [pmid: 10349607].
20 Albrecht SA, Reynolds MD, Cornelius MD, et al. Connectedness of pregnant adolescents who smoke. J Child Adolesc Psychiatr Nurs. Jan-Mar. 2002;15(1):16-23. X-3, X-4, X-5. [pmid: 11939415].
21 Alpert PT, Colosimo R. Attributional styles of pregnant women who quit or reduce smoking. Communicating Nursing Research. 2006;39:209. X-4, X-5.
22 Aquilino ML, Goody CM, Lowe JB. WIC providers' perspectives on offering smoking cessation interventions. MCN Am J Matern Child Nurs. Sep-Oct. 2003;28(5):326-32. X-3, X-4, X-5, X-6. [pmid: 14501635].
23 Ashford K. Successful postpartum smoking abstinence. Southern Online Journal of Nursing Research. 2008;8(2):1. X-3, X-4, X-5.
24 Aveyard P, Lawrence T, Cheng KK, et al. A randomized controlled trial of smoking cessation for pregnant women to test the effect of a transtheoretical model-based intervention on movement in stage and interaction with baseline stage. Br J Health Psychol. May. 2006;11(Pt 2):263-78. X-5. [pmid: 16643698].
25 Aveyard P, Lawrence T, Evans O, et al. The influence of in-pregnancy smoking cessation programmes on partner quitting and women's social support mobilization: a randomized controlled trial [ISRCTN89131885]. BMC Public Health. 2005;5:80. X-5. [pmid: 16053527].
26 Avidano Britton GR, Brinthaupt J, Stehle JM, et al. The effectiveness of a nurse-managed perinatal smoking cessation program implemented in a rural county. Nicotine Tob Res. Feb. 2006;8(1):13-28. X-4. [pmid: 16497596].
27 Bailey BA, McCook JG, Clements AD, et al. Quitting Smoking During Pregnancy and Birth Outcomes: Evidence of Gains Following Cessation by Third Trimester. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2011;40:S98-9. X-4, X-5.
28 Bakker MJ, Mullen PD, de Vries H, et al. Feasibility of implementation of a Dutch smoking cessation and relapse prevention protocol for pregnant women. Patient Educ Couns. Jan. 2003;49(1):35-43. X-3, X-4, X-5, X-6. [pmid: 12527151].
29 Barker DC, McPhillips-Tangum C. Prenatal smoking cessation strategies in managed care. Tob Control. Suppl 1. 2000;9:I64. X-2, X-3, X-4, X-5, X-6. [pmid: 10688946].
30 Barnes GE, Vulcano BA, Greaves L. Characteristics affecting successful outcome in the cessation of smoking. Int J Addict. Sep. 1985;20(9):1429-34. X-4, X-6. [pmid: 4077330].
31 Barron J, Petrilli F, Strath L, et al. Successful interventions for smoking cessation in pregnancy. MCN Am J Matern Child Nurs. Jan-Feb. 2007;32(1):42-7. quiz 8-9. X-2, X-3, X-4, X-5, X-6. [pmid: 17308457].
32 Baxter S, Blank L, Everson-Hock ES, et al. The effectiveness of interventions to establish smoke-free homes in pregnancy and in the neonatal period: A systematic review. Health Education Research. 2011;26(2):265-82. X-4. [pmid: 21273185].
33 Baxter S, Everson-Hock E, Messina J, et al. Factors relating to the uptake of interventions for smoking cessation among pregnant women: A systematic review and qualitative synthesis. Nicotine & Tobacco Research. 2010;12(7):685-94. X-4. [pmid: 20472696].
34 Bedford K, Wallace C, Carroll T, et al. Pregnant smokers are receptive to smoking cessation advice and use of nicotine replacement therapy. Aust N Z J Obstet Gynaecol. Aug. 2008;48(4):424-6. X-3, X-4, X-5. [pmid: 18837850].
35 Belizan JM, Barros F, Langer A, et al. Impact of health education during pregnancy on behavior and utilization of health resources. Latin American Network for Perinatal and Reproductive Research. Am J Obstet Gynecol. Sep. 1995;173(3 Pt 1):894-9. X-6. [pmid: 7573265].
36 Benowitz NL, Dempsey DA, Goldenberg RL, et al. The use of pharmacotherapies for smoking cessation during pregnancy. Tob Control. Suppl 3. 2000;9:III91-4. X-2, X-3, X-4, X-5, X-6. [pmid: 10982920].
37 Bhandari S, Levitch AH, Ellis KK, et al. Comparative analyses of stressors experienced by rural low-income pregnant women experiencing intimate partner violence and those who are not. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2008;37(4):492-501. X-3, X-4, X-5, X-6. [pmid: 18754988].
38 Bishop S, Panjari M, Astbury J, et al. A survey of antenatal clinic staff: some perceived barriers to the promotion of smoking cessation in pregnancy. Aust Coll Midwives Inc J. Sep. 1998;11(3):14-8. X-3, X-4, X-5, X-6. [pmid: 10531816].
39 Blalock JA, Nayak N, Wetter DW, et al. The relationship of childhood trauma to nicotine dependence in pregnant smokers. Psychol Addict Behav. Dec. 2011;25(4):652-63. X-3, X-4, X-5. [pmid: 21928869].
40 Blalock JA, Robinson JD, Wetter DW, et al. Relationship of DSM-IV-based depressive disorders to smoking cessation and smoking reduction in pregnant smokers. Am J Addict. Jul-Aug. 2006;15(4):268-77. X-7. [pmid: 16867921].
41 Bloch M, Tong VT, Novotny TE, et al. Tobacco use and secondhand smoke exposure among pregnant women in low- and middle-income countries: a call to action. Acta Obstet Gynecol Scand. 2010;89(4):418-22. X-2, X-3, X-4, X-5, X-6. [pmid: 20367426].
42 Boehm FH, Glass CA, Reed GW. Prevention of preterm birth. Role of daily telephone contact. J Reprod Med. Aug. 1996;41(8):595-601. X-4, X-5, X-6. [pmid: 8866388].
43 Bonollo DP, Zapka JG, Stoddard AM, et al. Treating nicotine dependence during pregnancy and postpartum: understanding clinician knowledge and performance. Patient Educ Couns. Dec. 2002;48(3):265-74. X-3, X-4, X-5, X-6. [pmid: 12477611].
44 Brandon TH, Simmons VN, Meade CD, et al. Self-help booklets for preventing postpartum smoking relapse: a randomized trial. Am J Public Health. Nov. 2012;102(11):2109-15. X-7. [pmid: 22994170].
45 Brandon TH, Zelman DC, Baker TB. Effects of maintenance sessions on smoking relapse: delaying the inevitable?. J Consult Clin Psychol. Oct. 1987;55(5):780-2. X-6. [pmid: 3454792].
46 Breithaupt K, Plotnikoff RC, Edwards N, et al. Psychometric quality of a Processes of Change (POC) Scale in a maternal smoking sample. Canadian Journal of Behavioural Science/Revue canadienne des sciences du comportement. 2000;32(3):158-62. X-4, X-5.
47 Brodsky J, Viner-Brown S. Smoking among pregnant WIC participants in Rhode Island. Med Health R I. Nov. 2006;89(11):379-80. X-2, X-3, X-4, X-5, X-6. [pmid: 17168089].
48 Brooten D, Youngblut JM, Brown L, et al. A randomized trial of nurse specialist home care for women with high-risk pregnancies: outcomes and costs. Am J Manag Care. Aug. 2001;7(8):793-803. X-4, X-5, X-6. [pmid: 11519238].
49 Browne AJ, Shultis JD, Thio-Watts M. Solution-focused approaches to tobacco reduction with disadvantaged prenatal clients. J Community Health Nurs. 1999;16(3):165-77. X-2, X-3, X-4, X-5, X-6. [pmid: 10478510].
50 Bryce A, Butler C, Gnich W, et al. CATCH: development of a home-based midwifery intervention to support young pregnant smokers to quit. Midwifery. Oct. 2009;25(5):473-82. X-4. [pmid: 18280015].
51 Bryce RL, Stanley FJ, Garner JB. Randomized controlled trial of antenatal social support to prevent preterm birth. Br J Obstet Gynaecol. Oct. 1991;98(10):1001-8. X-4, X-5, X-6. [pmid: 1751431].
52 Buchanan L. Implementing a smoking cessation program for pregnant women based on current clinical practice guidelines. J Am Acad Nurse Pract. Jun. 2002;14(6):243-50. X-3, X-4, X-5. [pmid: 12087783].
53 Buist A, Yu D. Smoking and pregnancy: awareness, attitudes and habit changes. Health Bull (Edinb). Jul. 1987;45(4):179-84. X-4, X-5. [pmid: 3623900].
54 Bull L. What Can Be Done to Prevent Smoking in Pregnancy? A Literature Review. Early Child Development and Care. 2003;173(6):661-7. X-2, X-3, X-4, X-5, X-6.
55 Bullock LF, Wells JE, Duff GB, et al. Telephone support for pregnant women: outcome in late pregnancy. N Z Med J. Nov. 24. 1995;108(1012):476-8. X-5. [pmid: 8538974].
56 Byrd JC, Meade CD. Smoking cessation among pregnant women in an urban setting. Wis Med J. Nov. 1993;92(11):609-12. X-7. [pmid: 8303896].
57 Caine VA, Smith M, Beasley Y, et al. The impact of prenatal education on behavioral changes toward breast feeding and smoking cessation in a healthy start population. J Natl Med Assoc. May-Jun. 2012;104(5-6):258-64. X-4, X-7. [pmid: 22973675].
58 Campbell E, Walsh RA, Sanson-Fisher R, et al. A group randomised trial of two methods for disseminating a smoking cessation programme to public antenatal clinics: effects on patient outcomes. Tob Control. Apr. 2006;15(2):97-102. X-4. [pmid: 16565456].
59 Carlson SJ, Beebe LA, Leuthard JL. Smoke-free beginnings: changing practice behaviors to improve the delivery of smoking cessation to prenatal patients in Oklahoma. J Okla State Med Assoc. Mar. 2005;98(3):102-6. X-4. [pmid: 15822725].
60 Chalmers K, Gupton A, Katz A, et al. The description and evaluation of a longitudinal pilot study of a smoking relapse/reduction intervention for perinatal women. J Adv Nurs. Jan. 2004;45(2):162-71. X-3, X-4, X-5. [pmid: 14706001].
61 Chan B, Einarson A, Koren G. Effectiveness of bupropion for smoking cessation during pregnancy. J Addict Dis. 2005;24(2):19-23. X-7. [pmid: 15784520].
62 Chilmonczyk BA, Palomaki GE, Knight GJ, et al. An unsuccessful cotinine-assisted intervention strategy to reduce environmental tobacco smoke exposure during infancy. Am J Dis Child. Mar. 1992;146(3):357-60. X-5, X-7. [pmid: 1543187].
63 Chun-Fai-Chan B, Koren G, Fayez I, et al. Pregnancy outcome of women exposed to bupropion during pregnancy: a prospective comparative study. Am J Obstet Gynecol. Mar. 2005;192(3):932-6. X-3, X-4, X-5, X-6. [pmid: 15746694].
64 Cinciripini PM, McClure JB, Wetter DW, et al. An evaluation of videotaped vignettes for smoking cessation and relapse prevention during pregnancy: the very important pregnant smokers (VIPS) program. Tob Control. Suppl 3. 2000;9:III61-3. X-7. [pmid: 10982910].
65 Coleman T. Recommendations for the use of pharmacological smoking cessation strategies in pregnant women. CNS Drugs. 2007;21(12):983-93. X-2, X-3, X-4, X-5, X-6. [pmid: 18020479].
66 Coleman T, Chamberlain C, Cooper S, et al. Efficacy and safety of nicotine replacement therapy for smoking cessation in pregnancy: Systematic review and meta-analysis. Addiction. 2011;106(1):52-61. X-4. [pmid: 21054620].
67 Coleman T, Thornton J, Britton J, et al. Protocol for the smoking, nicotine and pregnancy (SNAP) trial: double-blind, placebo-randomised, controlled trial of nicotine replacement therapy in pregnancy. BMC Health Serv Res. 2007;7:2. X-2, X-3, X-5. [pmid: 17201904].
68 Comer L, Grassley JS. A smoking cessation website for childbearing adolescents. J Obstet Gynecol Neonatal Nurs. Nov-Dec. 2010;39(6):695-702. X-2, X-3, X-4, X-5, X-6. [pmid: 20880049].
69 Cooke M, Mattick RP, Campbell E. The dissemination of a smoking cessation program to 23 antenatal clinics: the predictors of initial program adoption by managers. Aust N Z J Public Health. Feb. 1999;23(1):99-103. X-4, X-5. [pmid: 10083699].
70 Cooke M, Mattick RP, Campbell E. A description of the adoption of the ‘Fresh start’ smoking cessation program by antenatal clinic managers. Aust J Adv Nurs. Sep-Nov. 2000;18(1):13-21. X-3, X-5, X-6. [pmid: 11878358].
71 Cooke M, Mattick RP, Walsh RA. Implementation of the “Fresh Start” smoking cessation programme to 23 antenatal clinics: A randomized controlled trial investigating two methods of dissemination. Drug and Alcohol Review. 2001;20(1):19-28. X-4, X-5.
72 Cope GF, Nayyar P, Holder R. Measurement of nicotine intake in pregnant women--associations to changes in blood cell count. Nicotine Tob Res. May. 2001;3(2):119-22. X-3, X-4, X-5, X-6. [pmid: 11403725].
73 Cope I, Lancaster P, Stevens L. Smoking in pregnancy. Med J Aust. Apr. 7. 1973;1(14):673-7. X-8. [pmid: 4701858].
74 Cottrell L, Wu Y, Harris C, et al. Factors related to women's decisions to smoke during their pregnancies. W V Med J. Nov-Dec. 2005;101(6):244-7. X-4, X-5. [pmid: 16625808].
75 Crawford MA, Woodby LL, Russell TV, et al. Using formative evaluation to improve a smoking cessation intervention for pregnant women. Health Commun. 2005;17(3):265-81. X-3, X-4, X-5. [pmid: 15855073].
76 Crittenden KS, Manfredi C, Cho YI, et al. Smoking cessation processes in low-SES women: the impact of time-varying pregnancy status, health care messages, stress, and health concerns. Addict Behav. Jul. 2007;32(7):1347-66. X-3, X-4, X-6. [pmid: 17097815].
77 Cummins SE, Tedeschi GJ, Anderson CM, et al. Telephone counselling for pregnant smokers: Essential elements. Journal of Smoking Cessation. 2007;2(2):36-46. X-2, X-3, X-4, X-5, X-6.
78 Danaher BG, Shisslak CM, Thompson CB, et al. A smoking cessation program for pregnant women: an exploratory study. Am J Public Health. Sep. 1978;68(9):896-8. X-3, X-4. [pmid: 686216].
79 Davis MF, Miller HS, Nolan PE. Bupropion levels in breast milk for 4 mother-infant pairs: More answers to lingering questions. Journal of Clinical Psychiatry. 2009;70(2):297-8. X-4, X-5. [pmid: 19265649].
80 de Vries H, Bakker M, Mullen PD, et al. The effects of smoking cessation counseling by midwives on Dutch pregnant women and their partners. Patient Educ Couns. Oct. 2006;63(1-2):177-87. X-7. [pmid: 16406475].
81 Dennis CL, Kingston D. A systematic review of telephone support for women during pregnancy and the early postpartum period. Journal of Obstetric, Gynecologic, & Neonatal Nursing: Clinical Scholarship for the Care of Women, Childbearing Families, & Newborns. 2008;37(3):301-14. X-4. [pmid: 18507601].
82 Devonport C. Support for pregnant women who wish to stop smoking. Nurs Times. Mar. 6-12. 1996;92(10):36-7. X-2, X-3, X-4, X-5. [pmid: 8710541].
83 Dixon-Gray L. Program: Smoke Free Mothers and Babies. Health Education & Behavior. 2005;32(1):6-8. X-2, X-3, X-4, X-5, X-6.
84 Dolan-Mullen P, DiClemente CC, Velasquez MM, et al. Enhanced prenatal case management for low income smokers. Tob Control. Suppl 3. 2000;9:III75-7. X-4. [pmid: 10982915].
85 Donovan JW. Randomised controlled trial of anti-smoking advice in pregnancy. Br J Prev Soc Med. Mar. 1977;31(1):6-12. X-7. [pmid: 856371].
86 Donovan JW. Randomised controlled trial of anti-smoking advice in pregnancy: 20 years on. Journal of Epidemiology and Community Health. 1996;50(3):237-8. X-2, X-3, X-4, X-5, X-6. [pmid: 8935451].
87 Donovan JW. Randomised controlled trial of anti-smoking advice in pregnancy. Journal of Epidemiology and Community Health. 1996;50(3):232-6. X-4, X-7. [pmid: 8935450].
88 Donovan JW. Randomised controlled trial of anit-smoking advice in pregnancy: 20 years on. Journal of Epidemiology and Community Health. 1996;50(3):237-8. 1996-05318-002. X-2. [pmid: 8935451].
89 Dornelas E, Oncken C, Greene J, et al. Major depression and PTSD in pregnant smokers enrolled in nicotine gum treatment trial. The American Journal on Addictions. 2013;22(1):54-9. 2013-04603-009. X-4. [pmid: 23398227].
90 Douglas FC, Gray DA, van Teijlingen ER. Using a realist approach to evaluate smoking cessation interventions targeting pregnant women and young people. BMC Health Serv Res. 2010;10:49. X-2. [pmid: 20178559].
91 Duffy J, Coates TJ. Reducing smoking among pregnant adolescents. Adolescence. Spring. 1989;24(93):29-37. X-2, X-3, X-4, X-5, X-6. [pmid: 2728972].
92 Dunkley J. Training midwives to help pregnant women stop smoking. Nurs Times. Jan. 29. Feb. 4. 1997;93(5):64-6. X-5. [pmid: 9070004].
93 Ebert L, van der Riet P, Fahy K. What do midwives need to understand/know about smoking in pregnancy?. Women Birth. Mar. 2009;22(1):35-40. X-2, X-3, X-4, X-5, X-6. [pmid: 19117827].
94 Edwards MJ, Geiser T, Chafin C, et al. S.M.A.R.T. mothers are resisting tobacco: prenatal smoking cessation in WIC mothers. J Allied Health. Fall. 2009;38(3):170-6. X-3, X-4. [pmid: 19753429].
95 Edwards N, Sims-Jones N. Smoking and smoking relapse during pregnancy and postpartum: results of a qualitative study. Birth. Jun. 1998;25(2):94-100. X-3, X-4. [pmid: 9668743].
96 El-Khorazaty MN, Johnson AA, Kiely M, et al. Recruitment and retention of low-income minority women in a behavioral intervention to reduce smoking, depression, and intimate partner violence during pregnancy. BMC Public Health. 2007;7:233. X-4, X-5. [pmid: 17822526].
97 Ellingson JM, Rickert ME, Lichtenstein P, et al. Disentangling the relationships between maternal smoking during pregnancy and co-occurring risk factors. Psychological Medicine. 2012;42(7):1547-57. X-4, X-5. [pmid: 22115276].
98 El-Mohandes AA, El-Khorazaty MN, Kiely M, et al. Smoking cessation and relapse among pregnant African-American smokers in Washington, DC. Matern Child Health J. Dec. Suppl 1. 2011;15:S96-105. X-7. [pmid: 21656058].
99 El-Mohandes AA, Kiely M, Blake SM, et al. An intervention to reduce environmental tobacco smoke exposure improves pregnancy outcomes. Pediatrics. Apr. 2010;125(4):721-8. X-6. [pmid: 20211945].
100 El-Mohandes AA, Kiely M, Gantz MG, et al. Very preterm birth is reduced in women receiving an integrated behavioral intervention: a randomized controlled trial. Matern Child Health J. Jan. 2011;15(1):19-28. X-3, X-5. [pmid: 20082130].
101 El-Mohandes AA, Kiely M, Joseph JG, et al. An intervention to improve postpartum outcomes in African-American mothers: a randomized controlled trial. Obstet Gynecol. Sep. 2008;112(3):611-20. X-7. [pmid: 18757660].
102 Ershoff DH, Aaronson NK, Danaher BG, et al. Behavioral, health, and cost outcomes of an HMO-based prenatal health education program. Public Health Rep. Nov-Dec. 1983;98(6):536-47. X-4. [pmid: 6419268].
103 Ershoff DH, Quinn VP, Boyd NR, et al. The Kaiser Permanente prenatal smoking cessation trial: When more isn't better, what is enough?. American Journal of Preventive Medicine. 1999;17(3):161-8. X-9. [pmid: 10987630].
104 Ershoff DH, Quinn VP, Boyd NR, et al. The Kaiser Permanente prenatal smoking cessation trial: when more isn't better, what is enough?. Tob Control. Suppl 3. 2000;9:III60. X-9. [pmid: 10982909].
105 Everett-Murphy K, Steyn K, Mathews C, et al. The effectiveness of adapted, best practice guidelines for smoking cessation counseling with disadvantaged, pregnant smokers attending public sector antenatal clinics in Cape Town, South Africa. Acta Obstet Gynecol Scand. 2010;89(4):478-89. X-4. [pmid: 20302533].
106 Fendall L, Griffith W, Iliff A, et al. Integrating a clinical model of smoking cessation into antenatal care. British Journal of Midwifery. 2012;20(4):236-42. X-2, X-4.
107 Ferguson J, Bauld L, Chesterman J, et al. The English smoking treatment services: one-year outcomes. Addiction. Apr. Suppl 2. 2005;100:59-69. X-3, X-4, X-6. [pmid: 15755262].
108 Ferreira-Borges C. Effectiveness of a brief counseling and behavioral intervention for smoking cessation in pregnant women. Prev Med. Jul. 2005;41(1):295-302. X-5. [pmid: 15917025].
109 Flenady V, Macphail J, New K, et al. Implementation of a clinical practice guideline for smoking cessation in a public antenatal care setting. Aust N Z J Obstet Gynaecol. Dec. 2008;48(6):552-8. X-3, X-4. [pmid: 19133042].
110 Fox NL, Sexton MJ, Hebel JR. Alcohol consumption among pregnant smokers: effects of a smoking cessation intervention program. Am J Public Health. Feb. 1987;77(2):211-3. X-5. [pmid: 3541653].
111 Franchini M, Caruso C, Perico A, et al. Assessment of foetal exposure to cigarette smoke after recent implementations of smoke-free policy in Italy. Acta Paediatrica. 2008;97(5):546-50. X-3, X-4, X-5, X-6. [pmid: 18394097].
112 French GM, Groner JA, Wewers ME, et al. Staying smoke free: an intervention to prevent postpartum relapse. Nicotine Tob Res. Jun. 2007;9(6):663-70. X-4. [pmid: 17558823].
113 Gaffney KF. Postpartum Smoking Relapse and Becoming a Mother. Journal of Nursing Scholarship. 2006;38(1):26-30. X-2, X-3, X-4, X-5, X-6. [pmid: 16579320].
114 Gebauer C, Kwo CY, Haynes EF, et al. A nurse-managed smoking cessation intervention during pregnancy. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 1998;27(1):47-53. X-4. [pmid: 9475127].
115 Gleeson C, Memon I, Milner M, et al. Aspects of antenatal care. Smoking cessation in pregnancy: a multiple contact approach. British Journal of Midwifery. 1997;5(9):551-4. X-3, X-5.
116 Godin G, Valois P, Lepage L, et al. Predictors of smoking behaviour: An application of Ajzen's theory of planned behaviour. British Journal of Addiction. 1992;87(9):1335-43. X-4, X-5. [pmid: 1392555].
117 Greenberg RA, Strecher VJ, Bauman KE, et al. Evaluation of a home-based intervention program to reduce infant passive smoking and lower respiratory illness. J Behav Med. Jun. 1994;17(3):273-90. X-5. [pmid: 7932681].
118 Grossman J, Donaldson S, Belton L, et al. 5 A's smoking cessation with recovering women in treatment. Journal of Addictions Nursing. 2008;19(1):1-8. X-2, X-4.
119 Gulliver SB, Colby SM, Hayes K, et al. Tobacco cessation treatment for pregnant smokers: incorporating partners and incentives. Med Health R I. Jan. 2004;87(1):9-12. X-3, X-4. [pmid: 14989074].
120 Gupton A, Thompson L, Arnason RC, et al. Pregnant women and smoking. Can Nurse. Aug. 1995;91(7):26-30. X-2, X-3, X-4, X-5, X-6. [pmid: 7648552].
121 Haddow JE, Knight GJ, Kloza EM, et al. Cotinine-assisted intervention in pregnancy to reduce smoking and low birthweight delivery. Br J Obstet Gynaecol. Sep. 1991;98(9):859-65. X-7. [pmid: 1716979].
122 Haddow JE, Palomaki GE, Sepulveda D. Smoking cessation counseling during routine public prenatal care. American Journal of Public Health. 1995;85(10):1451-2. X-2, X-3, X-4, X-5, X-6. [pmid: 7573639].
123 Halliday J, Wilkinson T. Young, vulnerable and pregnant: family support in practice. Community Pract. Oct. 2009;82(10):27-30. X-3, X-4. [pmid: 19899505].
124 Hamilton BH. Estimating treatment effects in randomized clinical trials with non-compliance: the impact of maternal smoking on birthweight. Health Econ. Jul. 2001;10(5):399-410. X-3, X-4, X-5, X-6. [pmid: 11466802].
125 Handel G, Hannover W, Roske K, et al. Naturalistic changes in the readiness of postpartum women to quit smoking. Drug Alcohol Depend. May. 2009;101(3):196-201. X-5. [pmid: 19250773].
126 Hannover W, Thyrian JR, Ebner A, et al. Smoking during pregnancy and postpartum: smoking rates and intention to quit smoking or resume after pregnancy. J Womens Health (Larchmt). May. 2008;17(4):631-40. X-7. [pmid: 18345997].
127 Hannover W, Thyrian JR, Roske K, et al. Smoking cessation and relapse prevention for postpartum women: results from a randomized controlled trial at 6, 12, 18 and 24 months. Addict Behav. Jan. 2009;34(1):1-8. X-7. [pmid: 18804331].
128 Haug K, Aaro LE, Fugelli P. Smoking habits in early pregnancy related to age of smoking debut. Fam Pract. Mar. 1993;10(1):66-9. X-4, X-5. [pmid: 8477897].
129 Haug K, Aaro LE, Fugelli P. Pregnancy--a golden opportunity for promoting the cessation of smoking?. Scand J Prim Health Care. Sep. 1994;12(3):184-9. X-4, X-5. [pmid: 7997697].
130 Haug K, Foss OP, Kvamme JM. Do pregnant women who report a reduction in cigarette consumption consume less tobacco?. Scand J Prim Health Care. Dec. 1994;12(4):269-75. X-5. [pmid: 7863145].
131 Haug K, Fugelli P, Aaro LE, et al. Is smoking intervention in general practice more successful among pregnant than non-pregnant women?. Fam Pract. Jun. 1994;11(2):111-6. X-7. [pmid: 7958571].
132 Haug NA, Svikis DS, Diclemente C. Motivational enhancement therapy for nicotine dependence in methadone-maintained pregnant women. Psychol Addict Behav. Sep. 2004;18(3):289-92. X-3, X-4, X-5. [pmid: 15482085].
133 Haverty S, Macleod Clark J, Elliott K. Helping people to stop smoking. Nurs Times. Jul. 15-21. 1987;83(28):45-9. X-4, X-5, X-6. [pmid: 3650819].
134 Haviland L, Thornton AH, Carothers S, et al. Giving infants a great start: launching a national smoking cessation program for pregnant women. Nicotine Tob Res. Apr. Suppl 2. 2004;6:S181-8. X-2, X-3, X-4, X-5, X-6. [pmid: 15203820].
135 Hayes CB, Collins C, O'Carroll H, et al. Effectiveness of Motivational Interviewing in Influencing Smoking Cessation in Pregnant and Postpartum Disadvantaged Women. Nicotine Tob Res. 2012. Oct. 29. X-4. [pmid: 23109672].
136 Hebel JR, Fox NL, Sexton M. Dose-response of birth weight to various measures of maternal smoking during pregnancy. J Clin Epidemiol. 1988;41(5):483-9. X-7. [pmid: 3367179].
137 Hebel JR, Nowicki P, Sexton M. The effect of antismoking intervention during pregnancy: an assessment of interactions with maternal characteristics. Am J Epidemiol. Jul. 1985;122(1):135-48. X-7. [pmid: 4014191].
138 Heckman CJ, Egleston BL, Hofmann MT. Efficacy of motivational interviewing for smoking cessation: A systematic review and meta-analysis. Tobacco Control: An International Journal. 2010;19(5):410-6. X-4, X-5. [pmid: 20675688].
139 Hemsing N, Greaves L, O'Leary R, et al. Partner support for smoking cessation during pregnancy: a systematic review. Nicotine Tob Res. Jul. 2012;14(7):767-76. X-2, X-4, X-6. [pmid: 22180588].
140 Heppner WL, Ji L, Reitzel LR, et al. The role of prepartum motivation in the maintenance of postpartum smoking abstinence. Health Psychol. Nov. 2011;30(6):736-45. X-3, X-4, X-5. [pmid: 21859215].
141 Heppner WL, Ji L, Reitzel LR, et al. “The role of prepartum motivation in the maintenance of postpartum smoking abstinence”: Correction to Heppner et al. (2011). Health Psychology. 2011;30(6):745. 2011-21144-001. X-2, X-4.
142 Herbert RJ, Gagnon AJ, O'Loughlin JL, et al. Testing an empowerment intervention to help parents make homes smoke-free: a randomized controlled trial. J Community Health. Aug. 2011;36(4):650-7. X-6. [pmid: 21234793].
143 Hesselink AE, van Poppel MN, van Eijsden M, et al. The effectiveness of a perinatal education programme on smoking, infant care, and psychosocial health for ethnic Turkish women. Midwifery. Jun. 2012;28(3):306-13. X-4, X-7. [pmid: 21632158].
144 Hettema JE, Hendricks PS. Motivational interviewing for smoking cessation: A meta-analytic review. Journal of Consulting and Clinical Psychology. 2010;78(6):868-84. X-4, X-5. [pmid: 21114344].
145 Higgins ST, Bernstein IM, Washio Y, et al. Effects of smoking cessation with voucher-based contingency management on birth outcomes. Addiction. Nov. 2010;105(11):2023-30. X-4. [pmid: 20840188].
146 Higgins ST, Heil SH, Badger GJ, et al. Educational disadvantage and cigarette smoking during pregnancy. Drug Alcohol Depend. Oct. 1. Suppl 1. 2009;104:S100-5. X-4, X-5. [pmid: 19442460].
147 Higgins ST, Heil SH, Solomon LJ, et al. A pilot study on voucher-based incentives to promote abstinence from cigarette smoking during pregnancy and postpartum. Nicotine Tob Res. Dec. 2004;6(6):1015-20. X-3, X-4. [pmid: 15801574].
148 Hollander D. Program helps pregnant women reduce exposure to secondhand smoke. Perspectives on Sexual and Reproductive Health. 2010;42(3):215-6. X-2, X-3, X-4, X-5, X-6.
149 Holmes C. Partner involvement in smoking cessation. British Journal of Midwifery. 2001;9(6):357-61. X-4, X-5.
150 Hotham ED, Atkinson ER, Gilbert AL. Focus groups with pregnant smokers: barriers to cessation, attitudes to nicotine patch use and perceptions of cessation counselling by care providers. Drug Alcohol Rev. Jun. 2002;21(2):163-8. X-3, X-4, X-5. [pmid: 12188995].
151 Howard LM, Bekele D, Rowe M, et al. Smoking cessation in pregnant women with mental disorders: a cohort and nested qualitative study. BJOG. Feb. 2013;120(3):362-70. X-4, X-5, X-7. [pmid: 23167511].
152 Howell EM, Dubay L, Kenney G, et al. The impact of Medicaid managed care on pregnant women in Ohio: a cohort analysis. Health Serv Res. Aug. 2004;39(4 Pt 1):825-46. X-5. [pmid: 15230930].
153 Hruba D, Kachlik P. Influence of maternal active and passive smoking during pregnancy on birthweight in newborns. Cent Eur J Public Health. Nov. 2000;8(4):249-52. X-4, X-5, X-6. [pmid: 11125982].
154 Hughes EG, Lamont DA, Beecroft ML, et al. Randomized trial of a “stage-of-change” oriented smoking cessation intervention in infertile and pregnant women. Fertil Steril. Sep. 2000;74(3):498-503. X-5. [pmid: 10973645].
155 Hymowitz N. Paterson COMMIT: a smoke-free community initiative. N J Med. Jan. 1995;92(1):22-4. X-2, X-3, X-4, X-5, X-6. [pmid: 7854569].
156 Hymowitz N, Schwab J, Haddock C, et al. The pediatric resident training on tobacco project: baseline findings from the Parent/Guardian Tobacco Survey. Prev Med. Jul. 2005;41(1):334-41. X-3, X-4, X-5, X-6. [pmid: 15917030].
157 Ibrahim JK, Schauffler HH, Barker DC, et al. Coverage of tobacco dependence treatments for pregnant women and for children and their parents. Am J Public Health. Dec. 2002;92(12):1940-2. X-2, X-3, X-4, X-5, X-6. [pmid: 12453812].
158 Jaakkola N, Zahlsen K, Jaakkola JJ. Effects of a population-based smoking cessation programme on smoking in pregnancy. Eur J Public Health. Dec. 2001;11(4):446-9. X-5. [pmid: 11766488].
159 Jehn L, Lokker N, Matitz D, et al. First Breath prenatal smoking cessation pilot study: preliminary findings. WMJ. 2003;102(3):29-34. X-3, X-4. [pmid: 12822287].
160 Johnston V, Thomas DP, McDonnell J, et al. Maternal smoking and smoking in the household during pregnancy and postpartum: findings from an Indigenous cohort in the Northern Territory. Med J Aust. May. 16. 2011;194(10):556-9. X-5. [pmid: 21644912].
161 Joseph JG, El-Mohandes AA, Kiely M, et al. Reducing psychosocial and behavioral pregnancy risk factors: results of a randomized clinical trial among high-risk pregnant african american women. Am J Public Health. Jun. 2009;99(6):1053-61. X-6, X-7. [pmid: 19372532].
162 Kapur B, Hackman R, Selby P, et al. Trials in pediatric populations. Randomized, double-blind, placebo-controlled trial of nicotine replacement therapy in pregnancy. Current Therapeutic Research. 2001;62(4):274-8. X-3.
163 Katz KS, Blake SM, Milligan RA, et al. The design, implementation and acceptability of an integrated intervention to address multiple behavioral and psychosocial risk factors among pregnant African American women. BMC Pregnancy Childbirth. 2008;8:22. X-6, X-7. [pmid: 18578875].
164 Kazemi A, Ehsanpour S, Nekoei-Zahraei NS. A randomized trial to promote health belief and to reduce environmental tobacco smoke exposure in pregnant women. Health Education Research. 2012;27(1):151-9. X-4, X-5, X-6. [pmid: 22052216].
165 Kelley K, Bond R, Abraham C. Effective approaches to persuading pregnant women to quit smoking: A meta-analysis of intervention evaluation studies. British Journal of Health Psychology. 2001;6(3):207-28. X-4. [pmid: 14596723].
166 Kennison LH. Smoking and pregnancy: reconciling incompatibilities. Holist Nurs Pract. Jan-Feb. 2009;23(1):32-8. X-3, X-4, X-5. [pmid: 19104273].
167 Kientz E, Kupperschmidt B. KICCS: a successful strategy to promote smoking cessation in women during and post pregnancy. Okla Nurse. 2005 Dec-2006 Feb. 50(4):27-30. X-3, X-4, X-5. [pmid: 16372471].
168 Kim SY, England LJ, Kendrick JS, et al. The contribution of clinic-based interventions to reduce prenatal smoking prevalence among US women. Am J Public Health. May. 2009;99(5):893-8. X-3, X-4, X-5, X-6. [pmid: 19299672].
169 Klerman LV, Ramey SL, Goldenberg RL, et al. A randomized trial of augmented prenatal care for multiple-risk, Medicaid-eligible African American women. Am J Public Health. Jan. 2001;91(1):105-11. X-5, X-6. [pmid: 11189800].
170 Kropa L. What is the most effective way to help pregnant smokers quit: telephone counseling or midwife delivered home based counseling?. Internet Journal of Academic Physician Assistants. 2007;6(1):10. X-2.
171 Lamb JM, Albrecht SA, Sereika S. Consideration of factors prior to implementing a smoking cessation program. J Sch Nurs. Feb. 1998;14(1):14-9. X-3, X-4, X-5. [pmid: 9505644].
172 Lando HA, Valanis BG, Lichtenstein E, et al. Promoting smoking abstinence in pregnant and postpartum patients: a comparison of 2 approaches. Am J Manag Care. Jul. 2001;7(7):685-93. X-5, X-7. [pmid: 11464427].
173 Langford ER, Thompson EG, Tripp SC. Smoking and health education during pregnancy: evaluation of a program for women in prenatal classes. Can J Public Health. Jul-Aug. 1983;74(4):285-9. X-7. [pmid: 6627186].
174 Latts LM, Prochazka AV, Salas NM, et al. Smoking cessation in pregnancy: failure of an HMO pilot project to improve guideline implementation. Nicotine Tob Res. Suppl 1. 2002;4:S25-30. X-3, X-4, X-5. [pmid: 11945216].
175 Lawrence T, Aveyard P, Croghan E. What happens to women's self-reported cigarette consumption and urinary cotinine levels in pregnancy?. Addiction. Sep. 2003;98(9):1315-20. X-3, X-4, X-5. [pmid: 12930219].
176 Lee AH. A pilot intervention for pregnant women in Sichuan, China on passive smoking. Patient Education and Counseling. 2008;71(3):396-401. X-3, X-4, X-5, X-6. [pmid: 18406561].
177 Lee M, Hajek P, McRobbie H, et al. Best practice in smoking cessation services for pregnant women: results of a survey of three services reporting the highest national returns, and three beacon services. J R Soc Promot Health. Sep. 2006;126(5):233-8. X-3, X-4, X-5, X-6. [pmid: 17004407].
178 Lee M, Hajek P, McRobbie H, et al. Best practice in smoking cessation services for pregnant women: results of a survey of three services reporting the highest national returns, and three beacon services. Journal of the Royal Society for the Promotion of Health. 2006;126(5):233-8. X-4, X-5, X-9. [pmid: 17004407].
179 LeFevre ML, Evans JK, Ewigman B. Is smoking an indication for prenatal ultrasonography? RADIUS Study Group. Arch Fam Med. Feb. 1995;4(2):120-3. X-7. [pmid: 7842149].
180 Levitt C, Shaw E, Wong S, et al. Systematic review of the literature on postpartum care: Effectiveness of interventions for smoking relapse prevention, cessation, and reduction in postpartum women. Birth: Issues in Perinatal Care. 2007;34(4):341-7. X-4. [pmid: 18021150].
181 Levitt C, Shaw E, Wong S, et al. Systematic Review of the Literature on Postpartum Care: Methodology and Literature Search Results. Birth: Issues in Perinatal Care. 2004;31(3):196-202. X-4. [pmid: 15330882].
182 Lilley J, Forster DP. A randomised controlled trial of individual counselling of smokers in pregnancy. Public Health. Sep. 1986;100(5):309-15. X-7. [pmid: 3538112].
183 Lillington L, Royce J, Novak D, et al. Evaluation of a smoking cessation program for pregnant minority women. Cancer Pract. May-Jun. 1995;3(3):157-63. X-7. [pmid: 7599672].
184 Lin KW, Tarantino DA Jr. Counseling and interventions to prevent tobacco use and tobacco-caused disease in adults and pregnant women. Am Fam Physician. Nov. 15. 2010;82(10):1269. X-2, X-3, X-4, X-5, X-6. [pmid: 21121540].
185 Lin KW, Tarantino DA. Counseling and interventions to prevent tobacco use and tobacco-caused disease in adults and pregnant women: reaffirmation recommendation statement. Am Fam Physician. Nov. 15. 2010;82(10):1266. X-2, X-3, X-4, X-5, X-6. [pmid: 21121539].
186 Lin LPMC, Galvin SL, Dixon SD. Smoking cessation in an OB/GYN residency clinic. Primary Care Update for OB/GYNS. 11//. 2003;10(6):265-9. X-4.
187 Ling SK, Wooderson S, Rees K, et al. A smoking cessation program in the neonatal intensive care unit. Journal of Smoking Cessation. 2008;3(2):73-6. X-4.
188 Loke AY, Lam TH. A randomized controlled trial of the simple advice given by obstetricians in Guangzhou, China, to non-smoking pregnant women to help their husbands quit smoking. Patient Educ Couns. Oct. 2005;59(1):31-7. X-6. [pmid: 16198216].
189 Loukopoulou AN, Vardavas CI, Farmakides G, et al. Design and study protocol of the maternal smoking cessation during pregnancy study, (M-SCOPE). BMC Public Health. 2011;11:903. X-3, X-4, X-5, X-6. [pmid: 22145828].
190 Lowe JB, Balanda KP, Clare G. Evaluation of antenatal smoking cessation programs for pregnant women. Aust N Z J Public Health. Feb. 1998;22(1):55-9. X-7. [pmid: 9599853].
191 Lowe JB, Balanda PK, Stanton WR, et al. Dissemination of an efficacious antenatal smoking cessation program in public hospitals in Australia: a randomized controlled trial. Health Educ Behav. Oct. 2002;29(5):608-19. X-3, X-4, X-5, X-6. [pmid: 12238704].
192 Lowry RJ, Billett A, Buchanan C, et al. Increasing breastfeeding and reducing smoking in pregnancy: a social marketing success improving life chances for children. Perspect Public Health. Nov. 2009;129(6):277-80. X-4. [pmid: 19994645].
193 Lowry RJ, Hardy S, Jordan C, et al. Using social marketing to increase recruitment of pregnant smokers to smoking cessation service: a success story. Public Health. Jun. 2004;118(4):239-43. X-3, X-4, X-5, X-6. [pmid: 15121431].
194 Lu Y, Tong S, Oldenburg B. Determinants of smoking and cessation during and after pregnancy. Health Promotion International. 2001;16(4):355-65. X-2, X-4, X-5. [pmid: 11733454].
195 Lumley J, Chamberlain C, Dowswell T, et al. Interventions for promoting smoking cessation during pregnancy. Cochrane Database of Systematic Reviews. 2009;(3). X-4.
196 Lynagh M, Bonevski B, Sanson-Fisher R, et al. An RCT protocol of varying financial incentive amounts for smoking cessation among pregnant women. BMC Public Health. 2012;12:1032. X-2, X-4, X-5. [pmid: 23181988].
197 Ma Y, Goins KV, Pbert L, et al. Predictors of smoking cessation in pregnancy and maintenance postpartum in low-income women. Matern Child Health J. Dec. 2005;9(4):393-402. X-3, X-4, X-5. [pmid: 16220356].
198 MacArthur C, Knox EG, Lancashire RJ. Effects at age nine of maternal smoking in pregnancy: experimental and observational findings. BJOG. Jan. 2001;108(1):67-73. X-7. [pmid: 11213007].
199 MacArthur C, Newton JR, Knox EG. Effect of anti-smoking health education on infant size at birth: a randomized controlled trial. Br J Obstet Gynaecol. Apr. 1987;94(4):295-300. X-7. [pmid: 3580312].
200 Manfredi C, Cho YI, Warnecke R, et al. Dissemination strategies to improve implementation of the PHS smoking cessation guideline in MCH public health clinics: experimental evaluation results and contextual factors. Health Educ Res. Apr. 2011;26(2):348-60. X-6. [pmid: 21398375].
201 Manfredi C, Crittenden KS, Cho YI, et al. The effect of a structured smoking cessation program, independent of exposure to existing interventions. Am J Public Health. May. 2000;90(5):751-6. X-6. [pmid: 10800424].
202 Manfredi C, Crittenden KS, Warnecke R, et al. Evaluation of a motivational smoking cessation intervention for women in public health clinics. Prev Med. Jan. 1999;28(1):51-60. X-6. [pmid: 9973588].
203 Maxson PJ, Edwards SE, Ingram A, et al. Psychosocial differences between smokers and non-smokers during pregnancy. Addict Behav. Feb. 2012;37(2):153-9. X-4, X-5. [pmid: 22000409].
204 Mayer C, Slachmuylder JL, Vandecasteele H, et al. Smoking relapse prevention programs and factors which predict abstinence: A controlled study comparing the efficacy of workplace group counselling arid proactive phone counselling. Psycho-Oncology. Oct. 2006;15(2):S319-S20. X-5.
205 Mayer JP, Hawkins B, Todd R. A randomized evaluation of smoking cessation interventions for pregnant women at a WIC clinic. Am J Public Health. Jan. 1990;80(1):76-8. X-7. [pmid: 2293809].
206 McBride CM, Baucom DH, Peterson BL, et al. Prenatal and postpartum smoking abstinence a partner-assisted approach. Am J Prev Med. Oct. 2004;27(3):232-8. X-7. [pmid: 15450636].
207 McBride CM, Curry SJ, Lando HA, et al. Prevention of relapse in women who quit smoking during pregnancy. Am J Public Health. May. 1999;89(5):706-11. X-7. [pmid: 10224982].
208 McElroy JA, Bloom T, Moore K, et al. Perinatal mortality and adverse pregnancy outcomes in a low-income rural population of women who smoke. Birth Defects Res A Clin Mol Teratol. Apr. 2012;94(4):223-9. X-4, X-5. [pmid: 22371350].
209 McLeod D, Pullon S, Benn C, et al. Can support and education for smoking cessation and reduction be provided effectively by midwives within primary maternity care?. Midwifery. Mar. 2004;20(1):37-50. X-7. [pmid: 15020026].
210 McParlane EC, Mullen PD, DeNino LA. The cost effectiveness of an education outreach representative to OB practitioners to promote smoking cessation counseling. Patient Educ Couns. Jun. 1987;9(3):263-74. X-4. [pmid: 10312143].
211 Mehl-Madrona LE. Psychosocial Prenatal Intervention to Reduce Alcohol, Smoking and Stress and Improve Birth Outcome Among Minority Women. Journal of Prenatal & Perinatal Psychology & Health. 2000;14(3-4):257-78. X-3, X-4, X-5, X-6.
212 Mejdoubi J, van den Heijkant S, Struijf E, et al. Addressing risk factors for child abuse among high risk pregnant women: design of a randomised controlled trial of the nurse family partnership in Dutch preventive health care. BMC Public Health. 2011;11:823. X-3, X-4, X-5, X-6. [pmid: 22017924].
213 Melvin CL. Pregnant women, infants, and the cost savings of smoking cessation. Tob Control. Suppl 1. 1997;6:S89-91. X-2, X-3, X-4, X-5, X-6. [pmid: 9396132].
214 Melvin CL, Dolan-Mullen P, Windsor RA, et al. Recommended cessation counselling for pregnant women who smoke: a review of the evidence. Tob Control. Suppl 3. 2000;9:III80-4. X-2, X-4. [pmid: 10982917].
215 Melvin CL, Malek SH. Making a difference in infant survival: evidence-based actions to reduce tobacco exposure during pregnancy and infancy in North Carolina. N C Med J. May-Jun. 2004;65(3):164-6. X-2, X-3, X-4, X-5, X-6. [pmid: 15335012].
216 Messimer SR, Hickner JM, Henry RC. A comparison of two antismoking interventions among pregnant women in eleven private primary care practices. J Fam Pract. Mar. 1989;28(3):283-8. X-7. [pmid: 2926343].
217 Moore ML, Elmore T, Ketner M, et al. Reduction and cessation of smoking in pregnant women: the effect of a telephone intervention. Journal of Perinatal Education. 1995;4(1):35-9. X-3.
218 Moore ML, Meis PJ, Ernest JM, et al. A randomized trial of nurse intervention to reduce preterm and low birth weight births. Obstet Gynecol. May. 1998;91(5 Pt 1):656-61. X-4, X-5, X-6. [pmid: 9572206].
219 Mullen PD. How can more smoking suspension during pregnancy become lifelong abstinence? Lessons learned about predictors, interventions, and gaps in our accumulated knowledge. Nicotine & Tobacco Research. 2004;6(Suppl2):S217-S38. X-4. [pmid: 15203823].
220 Mullen PD, Pollak KI, Kok G. Success attributions for stopping smoking during pregnancy, self-efficacy, and postpartum maintenance. Psychology of Addictive Behaviors. 1999;13(3):198-206. X-4, X-5.
221 Mullen PD, Richardson MA, Quinn VP, et al. Postpartum return to smoking: who is at risk and when. Am J Health Promot. May-Jun. 1997;11(5):323-30. X-3, X-4. [pmid: 10167366].
222 Murphy GP, Sciandra R. Helping patients withdraw from smoking. N Y State J Med. Dec. 1983;83(13):1353-4. X-2, X-3, X-4, X-5, X-6. [pmid: 6582394].
223 Murthy P, Subodh BN. Current developments in behavioral interventions for tobacco cessation. Current Opinion in Psychiatry. 2010;23(2):151-6. X-2, X-3, X-4, X-5, X-6. [pmid: 20061954].
224 Nabhan AF, Faris MA. High feedback versus low feedback of prenatal ultrasound for reducing maternal anxiety and improving maternal health behaviour in pregnancy. Cochrane Database of Systematic Reviews. 2010;(4). X-4, X-5.
225 Naughton F, Prevost AT, Sutton S. Self-help smoking cessation interventions in pregnancy: A systematic review and meta-analysis. Addiction. 2008;103(4):566-79. X-4. [pmid: 18339103].
226 Naylor PJ, Adams JS, McNeil D. Facilitating changes in perinatal smoking. The impact of a stage-based workshop for care-providers in British Columbia. Can J Public Health. Jul-Aug. 2002;93(4):285-90. X-3, X-4, X-5, X-6. [pmid: 12154532].
227 Neil-Urban S, LaSala K, Todd SJ. Community collaboration: using nursing students in a smoking cessation program for pregnant women. J Nurs Educ. Feb. 2002;41(2):76-9. X-3, X-4, X-5, X-6. [pmid: 11852987].
228 Niaura R. Long-term treatment with rimonabant for smoking cessation and the maintenance of abstinence: Results from STRATUS-WORLDWIDE trial. Nicotine Tob Res. Aug. 2005;7(4):696-7. X-2, X-6.
229 Norbeck JS, DeJoseph JF, Smith RT. A randomized trial of an empirically-derived social support intervention to prevent low birthweight among African American women. Soc Sci Med. Sep. 1996;43(6):947-54. X-4, X-5, X-6. [pmid: 8888464].
230 Nowicki P, Gintzig L, Hebel JR, et al. Effective smoking intervention during pregnancy. Birth. Winter. 1984;11(4):217-24. X-5. [pmid: 6568824].
231 Oakley A, Rajan L, Grant A. Social support and pregnancy outcome. Br J Obstet Gynaecol. Feb. 1990;97(2):155-62. X-4, X-5, X-6. [pmid: 2317466].
232 O'Connor AM, Davies BL, Dulberg CS, et al. Psychometric properties of health risk attitude measures in predicting cessation among pregnant smokers. Med Care. Jul. 1993;31(7):658-62. X-3, X-4. [pmid: 8326779].
233 Ogburn PL Jr., Hurt RD, Croghan IT, et al. Nicotine patch use in pregnant smokers: nicotine and cotinine levels and fetal effects. Am J Obstet Gynecol. Sep. 1999;181(3):736-43. X-3, X-4, X-5. [pmid: 10486492].
234 Oien T, Storro O, Jenssen JA, et al. The impact of a minimal smoking cessation intervention for pregnant women and their partners on perinatal smoking behaviour in primary health care: a real-life controlled study. BMC Public Health. 2008;8:325. X-4. [pmid: 18808705].
235 Olds DL, Henderson CR Jr., Tatelbaum R, et al. Improving the delivery of prenatal care and outcomes of pregnancy: a randomized trial of nurse home visitation. Pediatrics. Jan. 1986;77(1):16-28. X-4, X-5, X-6. [pmid: 3510017].
236 Oliver S, Oakley L, Lumley J, et al. Smoking cessation programmes in pregnancy: systematically addressing development, implementation, women's concerns and effectiveness. Health Education Journal. 2001;60(4):362-70. X-2.
237 Oncken C. Nicotine replacement for smoking cessation during pregnancy. The New England Journal of Medicine. 2012;366(9):846-7. X-2, X-3, X-4, X-5, X-6. [pmid: 22375978].
238 Oncken CA, Kranzler HR. Pharmacotherapies to enhance smoking cessation during pregnancy. Drug and Alcohol Review. 2003;22(2):191-202. X-2, X-3, X-4, X-5, X-6. [pmid: 12850906].
239 Oncken CA, Kranzler HR. What do we know about the role of pharmacotherapy for smoking cessation before or during pregnancy?. Nicotine & Tobacco Research. 2009;11(11):1265-73. X-2. [pmid: 19717542].
240 Orleans CT, Barker DC, Kaufman NJ, et al. Helping pregnant smokers quit: meeting the challenge in the next decade. Tob Control. Suppl 3. 2000;9:III6-11. X-2, X-3, X-4, X-5, X-6. [pmid: 10982898].
241 Orleans T, Melvin C, Marx J, et al. National action plan to reduce smoking during pregnancy: the National Partnership to Help Pregnant Smokers Quit. Nicotine Tob Res. Apr. Suppl 2. 2004;6:S269-77. X-2, X-3, X-4, X-5, X-6. [pmid: 15203827].
242 Owens C, Springett J. The Roy Castle Fag Ends Stop Smoking Service: A Successful Client-Led Approach to Smoking Cessation. Journal of Smoking Cessation. 2006;1(01):13-8. X-2, X-3, X-4, X-6.
243 Park ER, Quinn VP, Chang Y, et al. Recruiting pregnant smokers into a clinical trial: using a network-model managed care organization versus community-based practices. Prev Med. Mar. 2007;44(3):223-9. X-3, X-4, X-5. [pmid: 17204318].
244 Parker DR, Windsor RA, Roberts MB, et al. Feasibility, cost, and cost-effectiveness of a telephone-based motivational intervention for underserved pregnant smokers. Nicotine Tob Res. Oct. 2007;9(10):1043-51. X-5. [pmid: 17943620].
245 Patten CA. Tobacco cessation intervention during pregnancy among Alaska Native women. J Cancer Educ. Apr. Suppl 1. 2012;27:S86-90. X-2, X-4, X-5, X-6. [pmid: 22311690].
246 Pederson LL. Compliance with physician advice to quit smoking: a review of the literature. Prev Med. Jan. 1982;11(1):71-84. X-2, X-3, X-4, X-5, X-6. [pmid: 7079248].
247 Percival J. Smoking cessation in pregnancy. Nurs Times. Feb. 8-14. 50. 2005;101(6):2. X-2, X-3, X-4, X-5, X-6. [pmid: 15736499].
248 Persky V, Piorkowski J, Hernandez E, et al. The effect of low-cost modification of the home environment on the development of respiratory symptoms in the first year of life. Ann Allergy Asthma Immunol. Dec. 2009;103(6):480-7. X-5, X-6. [pmid: 20084841].
249 Petersen L, Handel J, Kotch J, et al. Smoking reduction during pregnancy by a program of self-help and clinical support. Obstet Gynecol. Jun. 1992;79(6):924-30. X-7. [pmid: 1579315].
250 Pickett KE, Abrams B, Schauffler HH, et al. Coverage of tobacco dependence treatments for pregnant smokers in health maintenance organizations. Am J Public Health. Sep. 2001;91(9):1393-4. X-2, X-3, X-4, X-5, X-6. [pmid: 11527766].
251 Pletsch PK. Reduction of primary and secondary smoke exposure for low-income black pregnant women. Nurs Clin North Am. Jun. 2002;37(2):315-29. viii. X-3, X-4, X-5. [pmid: 12389272].
252 Pletsch PK. A Model for Postpartum Smoking Resumption Prevention for Women Who Stop Smoking While Pregnant. Journal of Obstetric, Gynecologic, & Neonatal Nursing: Clinical Scholarship for the Care of Women, Childbearing Families, & Newborns. 2006;35(2):215-22. X-2, X-3, X-4, X-5, X-6. [pmid: 16620247].
253 Pletsch PK, Morgan S. Smoke free families: a tobacco control program for pregnant women and their families. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 2002;31(1):39-47. X-2, X-3, X-4, X-5, X-6. [pmid: 11843018].
254 Polanska K, Hanke W, Sobala W. Smoking relapse one year after delivery among women who quit smoking during pregnancy. Int J Occup Med Environ Health. 2005;18(2):159-65. X-7. [pmid: 16201207].
255 Polanska K, Hanke W, Sobala W, et al. Efficacy and effectiveness of the smoking cessation program for pregnant women. Int J Occup Med Environ Health. 2004;17(3):369-77. X-7. [pmid: 15683158].
256 Pollak KI, Baucom DH, Peterson BL, et al. Rated helpfulness and partner-reported smoking cessation support across the pregnancy-postpartum continuum. Health Psychol. Nov. 2006;25(6):762-70. X-7. [pmid: 17100504].
257 Pollak KI, Mullen PD. An exploration of the effects of partner smoking, type of social support, and stress on postpartum smoking in married women who stopped smoking during pregnancy. Psychology of Addictive Behaviors. 1997;11(3):182-9. X-4.
258 Pollak KI, Oncken CA, Lipkus IM, et al. Challenges and solutions for recruiting pregnant smokers into a nicotine replacement therapy trial. Nicotine Tob Res. Aug. 2006;8(4):547-54. X-2, X-3, X-4, X-5, X-6. [pmid: 16920652].
259 Powell DR, McCann BS. The effects of a multiple treatment program and maintenance procedures on smoking cessation. Prev Med. Jan. 1981;10(1):94-104. X-3, X-6. [pmid: 7232346].
260 Power FL, Gillies PA, Madeley RJ, et al. Research in an antenatal clinic--the experience of the Nottingham Mothers' Stop Smoking Project. Midwifery. Sep. 1989;5(3):106-12. X-2. [pmid: 2586327].
261 Pullon S, McLeod D, Benn C, et al. Smoking cessation in New Zealand: education and resources for use by midwives for women who smoke during pregnancy. Health Promot Int. Dec. 2003;18(4):315-25. X-2, X-3, X-4, X-5, X-6. [pmid: 14695363].
262 Quinn G, Ellison BB, Meade C, et al. Adapting smoking relapse-prevention materials for pregnant and postpartum women: formative research. Matern Child Health J. May. 2006;10(3):235-45. X-3, X-4, X-5. [pmid: 16341911].
263 Quinn VP. Prenatal smoking intervention in managed care settings: the Kaiser Permanente Southern California prenatal smoking project. Tob Control. Suppl 1. 2000;9:I61. X-2, X-3, X-4, X-5, X-6. [pmid: 10688943].
264 Ranney LM, Melvin CL, Rohweder CL. From guidelines to practice: a process evaluation of the National Partnership to Help Pregnant Smokers Quit. AHIP Cover. Jul-Aug. 2005;46(4):50-2. X-2, X-3, X-4, X-5, X-6. [pmid: 16149661].
265 Ratner PA, Johnson JL, Bottorff JL. Smoking relapse and early weaning among postpartum women: is there an association?. Birth. Jun. 1999;26(2):76-82. X-4, X-5. [pmid: 10687570].
266 Reading AE, Campbell S, Cox DN, et al. Health beliefs and health care behaviour in pregnancy. Psychol Med. May. 1982;12(2):379-83. X-7. [pmid: 7100360].
267 Reichert VC, Seltzer V, Efferen LS, et al. Women and tobacco dependence. Obstet Gynecol Clin North Am. Dec. 2009;36(4):877-90. xi. X-2, X-3, X-4, X-5, X-6. [pmid: 19944306].
268 Ricketts SA, Murray EK, Schwalberg R. Reducing low birthweight by resolving risks: results from Colorado's prenatal plus program. Am J Public Health. Nov. 2005;95(11):1952-7. X-3, X-4, X-5. [pmid: 16195530].
269 Robinson J, Kirkcaldy AJ. ‘Imagine all that smoke in their lungs’: parents' perceptions of young children's tolerance of tobacco smoke. Health Educ Res. Feb. 2009;24(1):11-21. X-4, X-5. [pmid: 18156146].
270 Roske K, Schumann A, Hannover W, et al. Postpartum smoking cessation and relapse prevention intervention: a structural equation modeling application to behavioral and non-behavioral outcomes of a randomized controlled trial. J Health Psychol. May. 2008;13(4):556-68. X-7. [pmid: 18420764].
271 Rosser J. Cochrane made simple. Smoking cessation programmes implemented during pregnancy. Pract Midwife. Mar. 1999;2(3):12-3. X-2, X-3, X-4. [pmid: 10382525].
272 Ruger JP, Emmons KM. Economic evaluations of smoking cessation and relapse prevention programs for pregnant women: A systematic review. Value in Health. 2008;11(2):180-90. X-4. [pmid: 17854435].
273 Ruggiero L, Redding CA, Rossi JS, et al. A stage-matched smoking cessation program for pregnant smokers. Am J Health Promot. Sep-Oct. 1997;12(1):31-3. X-2, X-3, X-4, X-5. [pmid: 10170432].
274 Rush D, Orme J, King J, et al. A trial of health education aimed to reduce cigarette smoking among pregnant women. Paediatr Perinat Epidemiol. Apr. 1992;6(2):285-97. X-7. [pmid: 1584729].
275 Schneider S, Huy C, Schütz J, et al. Smoking cessation during pregnancy: A systematic literature review. Drug and Alcohol Review. 2010;29(1):81-90. X-4. [pmid: 20078687].
276 Scott WJ, McIlvain H. Interactive software: an educational/behavioural approach to smoking cessation for pregnant women and their families. Tob Control. Suppl 3. 2000;9:III56-7. X-4. [pmid: 10982907].
277 Scowen P. Primary care 2010. J Fam Health Care. 2010;20(4):136-40. X-2, X-3, X-4, X-5, X-6. [pmid: 21053664].
278 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Training obstetric and family practice residents to give smoking cessation advice during prenatal care. Am J Obstet Gynecol. May. 1992;166(5):1356-63. X-5. [pmid: 1595791].
279 Secker-Walker RH, Vacek PM. Infant birth weight as a measure of harm reduction during smoking cessation trials in pregnancy. Health Educ Behav. Oct. 2002;29(5):557-69. X-3, X-4, X-5. [pmid: 12238700].
280 Senore C, Battista RN, Shapiro SH, et al. Predictors of smoking cessation following physicians' counseling. Prev Med. May-Jun. 1998;27(3):412-21. X-3, X-6. [pmid: 9612831].
281 Severson HH, Andrews JA, Lichtenstein E, et al. Reducing maternal smoking and relapse: long-term evaluation of a pediatric intervention. Prev Med. Jan-Feb. 1997;26(1):120-30. X-7. [pmid: 9010907].
282 Sexton M, Hebel JR. A clinical trial of change in maternal smoking and its effect on birth weight. JAMA. Feb. 17. 1984;251(7):911-5. X-7. [pmid: 6363731].
283 Sexton M, Nowicki P, Hebel JR. Verification of smoking status by thiocyanate in unrefrigerated, mailed saliva samples. Prev Med. Jan. 1986;15(1):28-34. X-4, X-5. [pmid: 3714657].
284 Shah V, Justice C, Moeykens B. Using Master Settlement Agreement funds to reduce prenatal/postpartum smoking in North Carolina: you quit, two quit. N C Med J. Sep-Oct. 2009;70(5):485-7. X-2, X-3, X-4, X-5, X-6. [pmid: 19999537].
285 Sheahan SL, Wilson SM. Smoking cessation for pregnant women and their partners: a pilot study. J Am Acad Nurse Pract. Jul. 1997;9(7):323-6. X-3, X-4. [pmid: 9274254].
286 Simmons VN, Cruz LM, Brandon TH, et al. Translation and adaptation of smoking relapse-prevention materials for pregnant and postpartum Hispanic women. J Health Commun. Jan. 2011;16(1):90-107. X-3, X-4, X-5. [pmid: 21120739].
287 Sockrider MM, Hudmon KS, Addy R, et al. An exploratory study of control of smoking in the home to reduce infant exposure to environmental tobacco smoke. Nicotine Tob Res. Dec. 2003;5(6):901-10. X-3, X-4, X-5, X-6. [pmid: 14668074].
288 Solomon LJ, Flynn BS. Telephone support for pregnant smokers who want to stop smoking. Health Promot Pract. Jan. 2005;6(1):105-8. X-3, X-4. [pmid: 15574535].
289 Solomon LJ, Secker-Walker RH, Skelly JM, et al. Stages of change in smoking during pregnancy in low-income women. J Behav Med. Aug. 1996;19(4):333-44. X-5. [pmid: 8836825].
290 Springett J, Owens C, Callaghan J. The challenge of combining ‘lay’ knowledge with ‘evidence-based’ practice in health promotion: Fag Ends Smoking Cessation Service. Critical Public Health. 2007/09/01. 2007;17(3):243-56. X-2, X-3, X-4, X-5, X-6.
291 Stanton WR, Lowe JB, Moffatt J, et al. Randomised control trial of a smoking cessation intervention directed at men whose partners are pregnant. Prev Med. Jan. 2004;38(1):6-9. X-5, X-6. [pmid: 14672636].
292 Stead LF, Lancaster T. Behavioural interventions as adjuncts to pharmacotherapy for smoking cessation. Cochrane Database of Systematic Reviews. 2012;(12). Language: English. Entry Date: 20130208. Revision Date: 20130510. X-2, X-4.
293 Stotts AL, DeLaune KA, Schmitz JM, et al. Impact of a motivational intervention on mechanisms of change in low-income pregnant smokers. Addict Behav. Nov. 2004;29(8):1649-57. X-3. [pmid: 15451133].
294 Strecher VJ, Bauman KE, Boat B, et al. The development and formative evaluation of a home-based intervention to reduce passive smoking by infants. Health Education Research. 1989;4(2):225-32. X-4, X-5.
295 Strecher VJ, Bishop KR, Bernhardt J, et al. Quit for keeps: tailored smoking cessation guides for pregnancy and beyond. Tob Control. Suppl 3. 2000;9:III78-9. X-7. [pmid: 10982916].
296 Subramanian S, Katz KS, Rodan M, et al. An integrated randomized intervention to reduce behavioral and psychosocial risks: pregnancy and neonatal outcomes. Matern Child Health J. Apr. 2012;16(3):545-54. X-7. [pmid: 21931956].
297 Tappin DM, Lumsden MA, McIntyre D, et al. A pilot study to establish a randomized trial methodology to test the efficacy of a behavioural intervention. Health Educ Res. Aug. 2000;15(4):491-502. X-3, X-4, X-5. [pmid: 11066466].
298 Tappin DM, Lumsden MA, McKay C, et al. The effect of home-based motivational interviewing on the smoking behaviour of pregnant women: a pilot randomized controlled efficacy study. Ambulatory Child Health. 2000;6:34-5. X-4.
299 Thompson KA, Parahoo AK, Blair N. A nurse-led smoking cessation clinic -- quit rate results and views of participants. Health Education Journal. 2007;66(4):307-22. X-4, X-6.
300 Thorsen N, Khalil L. Cost savings associated with smoking cessation for low-income pregnant women. WMJ. 2004;103(5):67-9. 73. X-3, X-4, X-5. [pmid: 15553568].
301 Thyrian JR, Freyer-Adam J, Hannover W, et al. Adherence to the principles of Motivational Interviewing, clients' characteristics and behavior outcome in a smoking cessation and relapse prevention trial in women postpartum. Addict Behav. Oct. 2007;32(10):2297-303. X-7. [pmid: 17307300].
302 Thyrian JR, Freyer-Adam J, Hannover W, et al. Population-based smoking cessation in women post partum: adherence to motivational interviewing in relation to client characteristics and behavioural outcomes. Midwifery. Apr. 2010;26(2):202-10. X-7. [pmid: 18653261].
303 Thyrian JR, Hannover W, Grempler J, et al. An intervention to support postpartum women to quit smoking or remain smoke-free. J Midwifery Womens Health. Jan-Feb. 2006;51(1):45-50. X-5. [pmid: 16399610].
304 Tsoh JY, Kohn MA, Gerbert B. Promoting smoking cessation in pregnancy with Video Doctor plus provider cueing: a randomized trial. Acta Obstet Gynecol Scand. 2010;89(4):515-23. X-3. [pmid: 20196678].
305 Tunstall CD, Ginsberg D, Hall SM. Quitting smoking. International Journal of the Addictions. 1985;20(6-7):1089-112. X-2, X-3, X-4, X-5, X-6. [pmid: 3908337].
306 Tuten M, Fitzsimons H, Chisolm MS, et al. Contingent incentives reduce cigarette smoking among pregnant, methadone-maintained women: results of an initial feasibility and efficacy randomized clinical trial. Addiction. Oct. 2012;107(10):1868-77. X-6. [pmid: 22716774].
307 Valanis B, Labuhn KT, Stevens NH, et al. Integrating prenatal-postnatal smoking interventions into usual care in a health maintenance organization. Health Promot Pract. Jul. 2003;4(3):236-48. X-2, X-3, X-4, X-5, X-6. [pmid: 14610994].
308 Valanis B, Lichtenstein E, Mullooly JP, et al. Maternal smoking cessation and relapse prevention during health care visits. Am J Prev Med. Jan. 2001;20(1):1-8. X-4. [pmid: 11137767].
309 Valbo A, Eide T. Smoking cessation in pregnancy: the effect of hypnosis in a randomized study. Addict Behav. Jan-Feb. 1996;21(1):29-35. X-7. [pmid: 8729705].
310 Valbo A, Nylander G. Smoking cessation in pregnancy. Intervention among heavy smokers. Acta Obstet Gynecol Scand. Mar. 1994;73(3):215-9. X-7. [pmid: 8122501].
311 Valbo A, Schioldborg P. Smoking cessation in pregnancy. Mode of intervention and effect. Acta Obstet Gynecol Scand. 1991;70(4-5):309-13. X-7. [pmid: 1746255].
312 Valbo A, Schioldborg P. Smoking in pregnancy: a follow-up study of women unwilling to quit. Addict Behav. May-Jun. 1993;18(3):253-7. X-4, X-5. [pmid: 8342437].
313 Valbo A, Schioldborg P. Smoking Cessation in Pregnancy - the Effect of Self-Help Manuals. Journal of Maternal-Fetal Investigation. Sum. 1994;4(3):167-70. X-7.
314 Van't Hof SM, Wall MA, Dowler DW. Randomised controlled trial of a postpartum relapse prevention intervention. Tob Control. Suppl 3. 2000;9:III64-6. X-7. [pmid: 10982911].
315 Vendittelli F, Riviere O, Crenn-Hebert C, et al. Do perinatal guidelines have an impact on obstetric practices?. Rev Epidemiol Sante Publique. Oct. 2012;60(5):355-62. X-4, X-5, X-7. [pmid: 22981161].
316 Vodopivec-Jamsek V, de Jongh T, Gurol-Urganci I, et al. Mobile phone messaging for preventive health care. Cochrane Database of Systematic Reviews. 2012;(12). X-2, X-3, X-4, X-6, X-7.
317 Wakefield M, Jones W. Effects of a smoking cessation program for pregnant women and their partners attending a public hospital antenatal clinic. Aust N Z J Public Health. 1998;22(3 Suppl):313-20. X-3, X-4. [pmid: 9629815].
318 Wall M. Pre- and postnatal smoking intervention in managed care settings. Tob Control. Suppl 1. 2000;9:I63. X-2, X-3, X-4, X-5, X-6. [pmid: 10688945].
319 Wall MA, Severson HH, Andrews JA, et al. Pediatric office-based smoking intervention: impact on maternal smoking and relapse. Pediatrics. Oct. 1995;96(4 Pt 1):622-8. X-7. [pmid: 7567321].
320 Waller CS, Zollinger TW, Saywell RW Jr., et al. The Indiana Prenatal Substance Use Prevention Program: its impact on smoking cessation among high-risk pregnant women. Indiana Med. Mar-Apr. 1996;89(2):184-7. X-3, X-4. [pmid: 8867420].
321 Walsh R, Redman S. Smoking cessation in pregnancy: Do effective programmes exist?. Health Promotion International. 1993;8(2):111-27. X-4.
322 Washio Y, Higgins ST, Heil SH, et al. Examining maternal weight gain during contingency-management treatment for smoking cessation among pregnant women. Drug Alcohol Depend. Mar. 1. 2011;114(1):73-6. X-4, X-5. [pmid: 20870365].
323 Wheeler JG, Jones J. Pregnancy and tobacco use. J Ark Med Soc. Oct. 2010;107(5):84-5. X-2, X-3, X-4, X-5, X-6. [pmid: 20961022].
324 Wiggins M, Oakley A, Roberts I, et al. Postnatal support for mothers living in disadvantaged inner city areas: a randomised controlled trial. J Epidemiol Community Health. Apr. 2005;59(4):288-95. X-6. [pmid: 15767382].
325 Wilkinson SA, McIntyre HD. Evaluation of the ‘healthy start to pregnancy’ early antenatal health promotion workshop: a randomized controlled trial. BMC Pregnancy Childbirth. 2012;12:131. X-5, X-7. [pmid: 23157894].
326 Wilkinson SA, Miller YD, Watson B. The effects of a woman-focused, woman-held resource on preventive health behaviors during pregnancy: the pregnancy pocketbook. Women Health. Jun. 2010;50(4):342-58. X-5, X-6. [pmid: 20711948].
327 Windsor R, Clark J, Cleary S, et al. Effectiveness of the smoking cessation and reduction in pregnancy treatment (script) dissemination project: A science to prenatal care practice partnership. Maternal and Child Health Journal. 2013. 2013-08964-001. X-4.
328 Windsor R, Morris J, Cutter G, et al. Sensitivity, specificity and predictive value of saliva thiocyanate among pregnant women. Addict Behav. 1989;14(4):447-52. X-3, X-4, X-5. [pmid: 2782126].
329 Windsor RA, Boyd NR, Orleans CT. A meta-evaluation of smoking cessation intervention research among pregnant women: Improving the science and art. Health Education Research. 1998;13(3):419-38. X-4. [pmid: 10186452].
330 Windsor RA, Li CQ, Boyd NR Jr., et al. The use of significant reduction rates to evaluate health education methods for pregnant smokers: a new harm reduction behavioral indicator?. Health Educ Behav. Oct. 1999;26(5):648-62. X-2, X-3, X-4, X-5, X-6. [pmid: 10533170].
331 Winickoff JP, Healey EA, Regan S, et al. Using the postpartum hospital stay to address mothers' and fathers' smoking: the NEWS study. Pediatrics. Mar. 2010;125(3):518-25. X-5. [pmid: 20123776].
332 Wisborg K, Henriksen TB, Jespersen LB, et al. Nicotine patches for pregnant smokers: a randomized controlled study. Obstet Gynecol. Dec. 2000;96(6):967-71. X-7. [pmid: 11084187].
333 Wood C, Meers A, Heber W, et al. The role of the nurse in smoking cessation counseling for pregnant women. Clinical Excellence for Nurse Practitioners. 2002;6(2):45-50. X-8.
334 Woodby LL, Windsor RA, Snyder SW, et al. Predictors of smoking cessation during pregnancy. Addiction. Feb. 1999;94(2):283-92. X-4. [pmid: 10396795].
335 Wright LN, Pahel-Short L, Hartmann K, et al. Statewide assessment of a behavioral intervention to reduce cigarette smoking by pregnant women. Am J Obstet Gynecol. Aug. 1996;175(2):283-7. discussion 7-8. X-4. [pmid: 8765243].
336 Zapka J, Goins KV, Pbert L, et al. Translating efficacy research to effectiveness studies in practice: lessons from research to promote smoking cessation in community health centers. Health Promot Pract. Jul. 2004;5(3):245-55. X-2, X-3, X-4, X-5, X-6. [pmid: 15228779].
337 Ziebland S, Mathews F. How important is the smoking status of the woman's partner as a predictor of smoking cessation in pregnancy? A literature review. Health Education Journal. 1998;57(1):70-80. X-2, X-4.
338 Correa-Fernández V, Ji L, Castro Y, et al. Mediators of the association of major depressive syndrome and anxiety syndrome with postpartum smoking relapse. Journal of Consulting and Clinical Psychology. 2012;80(4):636-48. 2012-05394-001. Related to an included study; does not address a Key Question. [pmid: 22390410].
339 Fish LJ, Peterson BL, Namenek Brouwer RJ, et al. Adherence to nicotine replacement therapy among pregnant smokers. Nicotine Tob Res. May. 2009;11(5):514-8. Related to an included study; does not address a Key Question. [pmid: 19351783].
340 Hegaard HK, Kjærgaard H, Møller LF, et al. Long-term nicotine replacement therapy. British Journal of Midwifery. 2004;12(4):214. Related to an included study; does not address a Key Question.
341 Kendzor DE, Businelle MS, Costello TJ, et al. Breast feeding is associated with postpartum smoking abstinence among women who quit smoking due to pregnancy. Nicotine Tob Res. Oct. 2010;12(10):983-8. Related to an included study; does not address a Key Question. [pmid: 20713441].
342 Ruger JP, Emmons KM, Kearney MH, et al. Measuring the costs of outreach motivational interviewing for smoking cessation and relapse prevention among low-income pregnant women. BMC Pregnancy Childbirth. 2009;9:46. Related to an included study; does not address a Key Question. [pmid: 19775455].
343 Windsor RA. An application of the PRECEDE model for planning and evaluating health education methods for pregnant smokers. Hygie. Sep. 1986;5(3):38-44. Related to an included study; does not address a Key Question. [pmid: 3759094].
344 Windsor RA, Lowe JB, Artz L, et al. Smoking cessation and pregnancy intervention trial: preliminary mid-trial results. Prog Clin Biol Res. 1990;339:107-17. Related to an included study; does not address a Key Question. [pmid: 2202988].
345 Windsor RA, Warner KE, Cutter GR. A cost-effectiveness analysis of self-help smoking cessation methods for pregnant women. Public Health Rep. Jan-Feb. 1988;103(1):83-8. Related to an included study; does not address a Key Question. [pmid: 3124203].