# Thresholds for Quality Assessment

## A Quality Assessment Thresholds for Cochrane Risk of Bias (RoB) Tool

There are three categories for describing the quality of studies: “Good”, “Fair”, and “Poor”. To categorize studies, we used the Cochrane Collaboration interpretation of risk of bias within a study to establish the threshold between good and fair quality studies and between fair and poor quality studies. We assessed study quality using the following criteria:

- Good quality: low risk of bias for all domains.
- Fair quality: unclear risk of bias for one or more domains and no known important limitation that could invalidate its results.
- Poor quality: high risk of bias for one or more domains.

Table F1 Threshold for study quality

Risk of bias | Interpretation | Within a study | Across studies
Low | Plausible bias unlikely to seriously alter the results. | Low risk of bias for all key domains. | Most information is from studies at low risk of bias.
Unclear | Plausible bias that raises some doubt about the results. | Unclear risk of bias for one or more key domains. | Most information is from studies at low or unclear risk of bias.
High | Plausible bias that seriously weakens confidence in the results. | High risk of bias for one or more key domains. | The proportion of information from studies at high risk of bias is sufficient to affect the interpretation of results.

Adapted from the Cochrane Handbook Chapter 8

## B Quality Assessment Thresholds for the Newcastle-Ottawa Scale

The Newcastle-Ottawa Scale includes 3 categories, with a maximum of 9 points, based on:

- Selection (maximum of 4 points)
  1. Representativeness of the exposed cohort (one point)
  2. Selection of the non-exposed cohort (one point)
  3. Ascertainment of exposure (one point)
  4. Demonstration that outcome of interest was not present at start of study (one point)
- Comparability (maximum of 2 points)
  1. Comparability of cohorts on the basis of the design or analysis
    a. Study controls for age (one point)
    b. Study controls for any additional factor (one point)
- Outcome (maximum of 3 points)
  1. Assessment of outcome (one point)
  2. Was follow-up long enough for outcomes to occur (one point)
  3. Adequacy of follow up of cohorts (one point)

Table F2 Scoring algorithm for risk of bias assessment

Quality rating | Selection Domain | Comparability Domain | Outcome Domain
Good | ≥3 | ≥2 | ≥2
Fair | 2 | ≥1 | ≥2
Poor | 0-1 | 0 | 0-1