# Screening Forms

Abstract Review Form

This is 26 pages of forms the authors used to decide which studies to include. They evaluated study titles, abstracts, and texts.

Full Text Review Form

This is 26 pages of forms the authors used to decide which studies to include. They evaluated study titles, abstracts, and texts.