# Literature Search Strategies

Last updated: May 15, 2013

Table A1 Search strategy and results from PubMed (PubMed.gov interface)

Search terms | | Search results
#1 | smoking/th[mh] OR tobacco use cessation[mh] OR tobacco use disorder/th[mh] OR tobacco use cessation products[mh] OR “smoking cessation”[tiab] OR (smoking[tiab] AND (quit[tiab] OR cessation[tiab] OR quitting[tiab] OR stop[tiab] OR stopping[tiab] OR stopped[tiab])) OR “smoking abstinence”[tiab] OR “tobacco abstinence”[tiab] | 39310
#2 | pregnancy[mh] OR pregnant women[mh] OR postpartum period[mh] OR postnatal care[mh] OR pregnancy[tiab] OR pregnant[tiab] OR postpartum[tiab] OR post-partum[tiab] OR postnatal[tiab] OR post-natal[tiab] OR prenatal[tiab] OR pre-natal[tiab] | 841048
#3 | #1 AND #2 NOT (comment[pt] OR letter[pt] OR review[pt] OR guideline[pt] OR case reports[pt] OR editorial[pt] OR news[pt] OR patient education handout[pt] OR legal cases[pt] OR meta-analysis[pt] OR newspaper article[pt] OR news[pt] OR historical article[pt] OR jsubsetk) | 1804
#4 | #3 AND English[la] AND humans[mh] | 1458

Key: [tiab] title or abstract word; [th] therapy; [la] language; [mh] medical subject heading; [pt] publication type; “jsubsetk” consumer health journal subset

Table A2 Search strategy and results from CINAHL (EBSCO Host interface)

Search Terms | | Search results
#1 | MH “Smoking/DT/DH/TH/PC” OR (MH “Smoking Cessation”) OR (MH “Smoking Cessation Programs”) OR (smoking AND (cessation OR quit OR quitting OR stop OR stopping OR stopped)) | 15319
#2 | (MH “reproduction+”) OR (MH “obstetric care+”) OR (MH “attitude to pregnancy”) OR pregnancy OR pregnant OR prenatal OR pre-natal OR postnatal OR postpartum OR post-natal OR post-partum | 129706
#3 | #1 AND #2 | 1161
#4 | #3 AND limiters: English Language; Peer Reviewed; Research Article; Exclude MEDLINE records | 84

Key: MH CINAHL medical subject heading; + explode term; DT/DH/TH/PC: therapy subheadings

Table A3 Search strategy and results from PsycINFO (ProQuest interface)

Search terms | | Search results
#1 | SU.EXACT.EXPLODE(“Smoking Cessation”) OR SU.EXACT.EXPLODE(“Tobacco Smoking”) OR “smoking cessation” OR (smoking AND (quit OR cessation OR quitting OR stop OR stopping OR stopped)) OR “smoking abstinence” OR “tobacco abstinence” | 24899
#2 | SU.EXACT.EXPLODE(“Pregnancy”) OR SU.EXACT.EXPLODE(“Adolescent Pregnancy”) OR pregnancy OR pregnant OR prenatal OR pre-natal OR postnatal OR postpartum OR post-natal OR post-partum | 54089
#3 | #1 AND #2, limited to human, English language, peer-reviewed scholarly journals | 1309

Key: SU.EXACT.EXPLODE explode subject term to include more specific related concepts