# Abbreviations and Acronyms

5A's Model: Ask, Advise, Assess, Assist, and Arrange
ACOG: American College of Obstetricians
AHRQ: Agency for Healthcare Research and Quality
BCI: Bayesian credible interval
CBT: Cognitive Behavior Therapy
CI: Confidence Interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CO: Carbon Monoxide
g: Gram
G: Group
HMO: Health Maintenance Organization
kg: Kilogram
KQ: Key Question
LBW: Low Birth Weight
MeSH: Medical Subject Heading
mg: milligram
ml: milliliter
N: Number
ng: nanogram
NICU: Neonatal Intensive Care Unit
NRT: Nicotine Replacement Therapy
NS: Non-significant
OR: Odds ratio
PICOTS: Population, Interventions, Comparators, Outcomes, Timing, Settings
ppm: Parts Per Million
RCT: Randomized Controlled Trials
RR: Relative Risk
SCRIPT: Smoking Cessation or Reduction in Pregnancy Treatment Program
SOE: Strength of Evidence
TEP: Technical Expert Panel
U.S.: United States
VLBW: Very Low Birth Weight
WIC: Women, Infants, and Children
wks.: weeks