# Results—Key Question 2: Dissemination Strategies to Clinicians and Patients

## Introduction

The analytic framework presented in the Introduction guided the literature search, abstraction and analysis for Key Question (KQ) 2. KQ2 concerns dissemination to clinicians or patients. As discussed in the Methods section, we included dissemination strategies that met two main criteria. First, they attempted to increase reach, ability, or motivation or used multicomponent approaches addressing one or more of these strategies. We categorized specific dissemination tactics as comprising reach, ability, motivation or multicomponent approaches as described previously. Second, they attempted to address health-related decisions and behaviors, clinical outcomes, or knowledge. We included only randomized controlled trials (RCTs) or cluster RCTs (cRCTs)—hereafter referred to as trials.

This section presents the results that compare the dissemination strategies noted above. Some trials compared strategies directly with each other (e.g., ability strategies vs. motivation strategies) and can be regarded as head-to-head trials for comparative effectiveness analyses. Some trials compared strategies to a usual care or no-treatment control group, but we included them in our analysis if they had at least two trial arms that addressed our inclusion criteria and if we believed that we might glean information about the relative effectiveness of one strategy versus another. In many cases where there was not a direct comparison significant tests or confidence intervals were likely also not reported, and we note this in the summary tables.

We divided the trials by dissemination strategies and by outcomes for clinicians and patients. The included studies were very heterogeneous with regard to the specific health-related decisions and behaviors, clinical outcomes or knowledge studied. They were also very heterogeneous with regard to specific dissemination strategies reflecting the reach, ability, motivation, and multicomponent approaches. Because of this heterogeneity, we chose to present summary tables in this section that describe trial results in words rather than numerically. Information reflects the comparisons as presented by the original investigators, which in some cases do not reflect precisely the constructs or directionality of our conceptual framework and definitions of strategies. Detailed evidence tables containing additional statistical results presenting numerical findings for abstracted trials appear in Appendix E.

Figure 1 in the previous section presents the flow diagram that accounts for all titles/abstracts and full-text articles reviewed and the final set of articles for all three KQs. In all, 163 articles were relevant to KQ 2. After full-text review, we retained 42 articles that met inclusion criteria; they report on 38 unique trials (including one trial that reported on different outcomes in multiple articles) about dissemination strategies.

In this section, we do not present summary tables that classify studies by the mode of delivery, agent, and communication goal. However, we examined this alternate presentation of results to ensure we were not missing any major conclusions about dissemination conceived in this alternate manner. This alternative organization did not reveal any different conclusions. This is likely due to the non-significant findings across studies and the fact that in almost all cases there was confounding among the various variables we used to classify dissemination strategies.

## Description of Included Studies

Two team members independently assessed study quality for 163 articles related to KQ 2. When there were disagreements they were adjudicated by 2–3 team members. We used 38 trials in the KQ 2 analysis. Of these, we assessed 15 as low risk of bias83–100 and 23 as moderate risk of bias.72,78,101–122 Those assessed as high risk of bias were not abstracted or used for analysis.

These 38 trials reported a wide variety of primary and secondary outcomes that spanned a range of health-related or clinical problems; these are documented in the outcome column in Tables 14–30. Even though some trials examined similar outcomes, e.g., guideline-concordant care, they may have used different dissemination strategies or focused on different problems or clinical issues. Because of this heterogeneity, we were not able to combine trials to conduct a quantitative analysis of the effect of dissemination to clinicians or patients.

Table 16 Strength of evidence: Dissemination to clinicians for health-related decisions and behavior outcomes

Strategy | Number of Trials; Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Results and Strength of Evidence
Reach strategies vs. ability strategies | 4; N_c_=199 N=213 3 cRCT83,90,96 1 RCT119 | Low | Consistent | Direct | Imprecise | Ability strategies not better than reach strategies. All studies found no significant differences between groups receiving these two approaches. Low for no differences
Reach strategies vs. motivation strategies | 1; N=363; RCT109 | Moderate | Unknown (single study) | Direct | Precise | Motivation strategy significantly better than reach strategy. Low
Reach strategies vs. multicomponent strategies | 7; N_c_=256; N=5,300 4cRCT85,95,97,122 3 RCT102,113,121 | Moderate | Consistent | Direct | Precise | Multicomponent strategies better than reach strategies. Almost all studies (6/7) using multicomponent strategies found significant differences between groups receiving these two approaches. Moderate for multicomponent strategies
Ability strategies vs. multicomponent strategies | 3; N_c_=382 N=2624 2 cRCT110,116 1 RCT118 | Moderate | Consistent | Direct | Precise | Results appear to favor multicomponent strategy over ability strategy. However, no confidence intervals or statistical test reported for comparisons between arms for one of the trials. Low
Motivation strategies vs. multicomponent strategies | 1; N_c_=42 N=616 cRCT98 | Low | Unknown (single study) | Direct | Precise | Multicomponent strategy significantly better than motivation strategy. Low
Reach strategies vs. ability strategies vs. multicomponent strategies | 1; N_c_=61 N=61 cRCT120 | Moderate | Unknown (single study) | Direct | Imprecise | Multicomponent strategy not better than either reach or ability strategies Insufficient

Notes: cRCT = cluster randomized controlled trial; N = number; N_c_ = number of clusters; RCT = randomized controlled trial.

Table 17 Summary of trials examining dissemination to clinicians for health-related decisions and behavior outcomes

Author, Year, Design Sample Size Duration Risk of Bias | Setting Sample Characteristics | Intervention Groups | Outcome | Results
Trials that compared reach strategies with ability strategies
Bahrami et al., 2004^83^ cRCT N_c_=51 Two 4-month periods pre and 2 4-month periods post intervention Low | Clinical Practices associated with the Scottish Dental Practice Board | G1: Mailed guideline (increase reach) G2: Guideline + audit and feedback (AF) (not abstracted) G3: Computer-assisted learning (CAL) (increase ability) G4: CAL + AF (not abstracted) | Guideline compliance (proportion of patients whose treatment complied with the guideline) (P) | Confidence intervals or p values not reported for this comparison
Jousimaa et al., 2002^90^ cRCT N_c_=139 1-month postintervention Low | Clinical Recently qualified physicians who would work in a Finnish health center for at least 2 months | G1: Computerized version of guidelines (increase ability) G2: Textbook-based version of guidelines (increase reach) | Physicians’ compliance with guideline recommendations about laboratory, radiologic, physical, and other examinations; procedures; nonpharmacologic and pharmacologic treatments; physiotherapy; and referrals (P) | G1=G2 No significant difference between groups
Simon et al., 2005^96^ cRCT N_c_=9 N (clinicians) = 781 N (patients) = 9,820 Baseline, 1-year followup, 2-year followup Low | Clinical All patients with hypertension receiving primary care at 1 of 9 study sites; all clinicians providing primary care for adults at the 9 study sites | G1: Mailed educational materials (increase reach) G2: Individual academic detailing (increase ability) G3: Group academic detailing (increase ability) | Change in guideline adherence (proportion of patients with new hypertension receiving a diuretic or beta blocker) (P) | G1=G2 G1=G3 No significant difference among groups Confidence intervals or p values not reported for G2 vs. G3 comparison
Sullivan et al., 2010^119^ RCT N=213 Baseline, immediate posttest, 60-day posttest Moderate | Clinical Residents in internal medicine | G1: VA guidelines for pain management (increase reach) G2: COPE: web-based education program for pain management (increase ability) | Use of four core management strategies for pain management (2nd) | G1=G2 No significant difference between groups
Trials that compared reach strategies with motivation strategies
Junghans et al., 2007^109^ RCT N=363 Immediate posttest Moderate | Clinical Members of the British Cardiac Society or general practioners in the primary care trusts that referred patients to 9 cardiothoracic centers in England and Scotland | G1: Conventional guideline (increase reach) G2: Ratings about specific patients in vignettes (increase motivation) | Physician testing behavior (agreement of physicians’ recommendations with those made by 2 independent expert panels) (P) | G2>G1 Patient-specific ratings endorsed by experts significantly more effective than conventional guidelines.
Trials that compared reach strategies with multicomponent strategies
Banait et al., 2003^121^ RCT N=114 7 months pre and post intervention Moderate | Clinical All general practices in Greater Manchester, England | G1: Mailed guidelines (increase reach) G2: Educational outreach (Multicomponent) | Uptake of dyspepsia management guidelines, including:; - Appropriateness of referrals for open access endoscopy (P); - Findings at open access endoscopy (P) | G2>G1 Educational outreach significantly more effective than postal dissemination for appropriateness of referrals for open access endoscopy G2=G1 for findings at open access endoscopy
Beaulieu et al., 2004^102^ RCT N=3293 6 month followup Moderate | Clinical Quebec physicians who had to be a primary prescribing physician (responsible for more than half of all anti-anginal prescriptions) for at least one patient (moe than 65 years of age) | G1: Control (not abstracted) G2: Guideline (increase reach) G3: Guideline + reminder notice and stickers for patients’ charts (multicomponent) | Prescribing practices in line with guildelines (prescription of 3 cardiovascular medications) (P) | Confidence intervals or p values not reported for comparisons
Bekkering et al., 2005^85^ cRCT N_c_=68 N (physiotherapist) = 113 N (patient) =511 Baseline unspecified followup Low | Clinical Physcial therapy practices that were members of the Royal Dutch Society for Physical Therapy in the Netherlands whose physiotherapists expected to treat at least 5 patients with low back pain during the enrolment period | G1: Mailed guideline (improve reach) G2: Multifaceted (multicomponent) | Guideline adherence: (P); - Proportion of patients for whom each and all 4 guidelines were fullfilled | G2>G1 Arm with multifaceted education, role playing and reminders (multicomponent) significantly more effective than arm with paper-based mailed guideline dissemination
Murtaugh et al., 2005^113^ RCT N=354 Within 45 days after initial home health RN assessment Moderate | Clinical English- or Spanish-speaking patients, ages18 or older, with a primary diagnosis of heart failure | G1: Usual care (not abstracted) G2: Basic intervention email reminder (increase reach) G3: Augmented intervention of email reminder + package of supporting materials (multicomponent) | Practice of evidence-based care: (P); - Recording key assessment items and instructions to patients; - Instructing patients with key educational elements related to symptoms and side effects; - Assessment of patient diet and medication side effects | Confidence intervals or p values not reported for comparison
Rebbeck et al. 2006^95^ cRCT N_c_=27 N=99 Baseline, 1.5 months, 3 months, 6 months, and 12 months Low | Clinical Physiotherapy clinics in Australia Clinic: Clinics in 2 states in Australia that had seen at least 5 whiplash cases in the previous year Patient: Patients, 18 years and older, involved in a motor vehicle accident within the previous 6 weeks who presented to the clinic with acute whiplash | G1: Dissemination of guidelines by mail (increase reach) G2: Implementation group (multicomponent) | Physiotherapist prescribing correct treatments (medication, exercise, and function) (2nd) Advising to act as usual (2nd) | G1=G2 Physiotherapist prescribing correct treatments (medication, exercise, and function) no significant differences between groups G2>G1 Multicomponent arm more effective than reach strategy for advising to act as usual
Rycroft-Malone et al., 2012^122^ cRCT N_c_=19 N=1,440 (pre) N=1,761 (post) 4 times preintervention and 4 times postintervention; up to 2 months interval between data collection points Moderate | Clinic: Acute care National Health Service (NHS) Trusts across the UK conducting elective surgery Patients: aged 18 and over, insured | G1: Standard dissemination via postal mail (increase reach) G2: Standard dissemination + a Web-based education package championed by an opinion leader (Multicomponent) G3: Standard dissemination + plan-do-study-act (Multicomponent) | Duration of fluid fast prior to induction of anaesthesia | G1=G2=G3 Multicomponent arms not more effective than reach strategy for duration of fluid fast prior to anaesthesia induction
Wolters et al., 2005^97^ cRCT N_c_=142 Baseline, up to 1 year post intervention Low | Clinical Patients: Men with lower urinary tract symptoms older than 50 years visiting partipating clinics in the Netherlands | G1: Control mailed guidelines (increase reach) G2: Intervention involving package for learning, supporting materials, decision tree, and information leaflets for patients (multicomponent) | General practice management of men with lower urinary tract symptoms:; - Number of PSA requests (P); - Medication prescribed (P); - Referral rate to a urologist (P); - Provision of patient education materials (2nd); - Discussion of the PSA evidence (2nd) | G2>G1 Multicomponent strategy significantly more effective than paper-based mailed guidelines dissemination for referral rates to a urologist and provision of patient education materials G1=G2 No difference between arms for number of PSA requests, medication prescribed, and discussion of the PSA evidence
Trials that compared ability strategies with multicomponent strategies
Laprise et al., 2009^110^ cRCT N_c_=133 N=2,344 Baseline; 6-month followup Moderate | Community-based settings All practicing GPs in 5 regions of Quebec, Canada, who had to see at least 25 patients 55 years of age or older in any 2-week period. | G1: CME (increase ability) G2: CME + practice enablers and reinforcers (multicomponent) | Guideline adherence:; - Proportion of patients receiving at least one prescription for managing cardiovascular disease (P); - Prescription of anti-platelets, angiotensine converting ensyme inhibitor, lipid lowering agents, beta blockers for undermanaged patients (2nd) | G2>G1 CME plus practice enablers and reinforcers significantly more effective than only CME for proportion of patients receiving at least one prescription, prescription, and for angiotensine converting enzyme but not for anti-platelets, beta blockers, or lipid lower agents
Rahme et al., 2005^116^ cRCT N_c_=249 135 to 1 day preintervention; 1 to 136 days post intervention Moderate | Clinical GP: All GPs registered in 1 of 8 selected towns in Canada Patients: All patients 65 years or older who who had at least 1 diagnosis for osteoarthritis and filled a prescription for an NSAID, COX-2 inhibitor, or acetaminophen written by a GP in the study | G1: No treatment control (not abstracted) G2: Decision tree (increase ability) G3: Workshop (increase ability) G4: Workshop + decision tree (multicomponent) | Dispensed prescriptions (prescription adequacy) (P) | Confidence intervals or p values not reported for comparison
Soler et al., 2010^118^ RCT N=2,624 45 days post training and continued for 3 months Moderate | Clinical GP: Physicians working at 1 of 40 general practices in Spain | G1: Control (not abstracted) G2: Training session on the SEPAR guidelines (increase ability) G3: G2 + portable device for spirometry (multicomponent) | Management of COPD per guidelines: (P); - Improved diagnosis; - Severity classification; - Treatment regimen | Confidence intervals or p values not reported for comparison.
Trials that compared motivation strategies with multicomponent strategies
Wright et al., 2008^98^ cRCT N_c_=42 360 days before intervention, 360 days after intervention Low | Clinical Hospitals in Ontario, Canada, that identified a local opinion leader in colon cancer | G1: Standardized lecture by expert opinion leader (increase motivation) G2: Standardized lecture by expert opinion leader + academic detailing and a toolkit (multicomponent) | Guideline adherence: (P); - Mean number of lymph nodes assessed in patients with stage II colon cancer; - Number of lymph nodes removed | Inconsistent results. G2>G1: Lymph node assessment G2=G1: Lymph node removal Adding academic detailing and a toolkit to a standardized lecture by an expert opinion leader significantly more effective than standard lecture by expert opinion leader for lymph node assessment. No significant differences between groups for lymph node removal.
Studies that compared reach strategies, ability strategies, and multicomponent strategies
Watson et al., 2002^120^ cRCT N_c_=61 Baseline, immediate posttest Moderate | Community-based settings NR | G1: Guideline materials by postal mail (increase reach) G2: Education outreach (EO) session and guidelines (increase ability) G3: Continuing professional education (CPE) session and guidelines (increase ability) G4: Guidelines + EO and CPE (multicomponent) | Guideline adherence: (P); - Proportion of visits resulting in an appropriate sale of an anti-fungal product | G1=G2=G3=G4 No significant differences among groups

Note: In most cases, the labels of the intervention groups represent the labels that study authors had originally used, except if they were merely labeled control or intervention. Information in parentheses represents the strategy that the authors of this review believed best captured the intervention components. When authors used nondescriptive or vague labels for the intervention groups (e.g., Group 1, Intervention A) we used a summary of their description of the group as a label. For a full description of the studies intervention components refer to Appendix E.

2nd = secondary outcome; CME = continuing medical education; COX-2 = Cyclooxygenase-2 inhibitor; GP = general practitioner; NR = not reported; NSAID = nonsteroidal anti-imflammatory drug; P = primary outcome; PSA = prostate-specific antigen; RN = registered nurse; + = plus.

Table 18 Strength of evidence: Studies examining dissemination to clinicians for clinical outcomes

Strategy | Number of Trials; Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Results and Strength of Evidence
Reach strategies versus ability strategies | 1; N_c_=9^96^ N patients=9,820 N clinicians=781 cRCT | Low | Unknown (single study) | Direct | Precise | No significant differences among groups receiving reach or ability strategies, and confidence intervals or p values not reported for some comparisons Low
Reach strategies versus multicomponent strategies | 4; N_c_= 186 N=2010 cRCT86,95,100,106 | Low | Consistent | Direct | Precise | No significant differences in any trial between groups receiving reach or multicomponent strategies. Low for no difference
Reach strategies, ability strategies, and Multicomponent strategies | 1; N_c_=18 N=539 cRCT108 | Moderate | Unknown (single study) | Direct | Precise | No significant differences between groups receiving multicomponent reach, or ability strategies. Low

Notes: cRCT = cluster randomized controlled trial; RCT = randomized controlled trial.

Table 19 Summary of trials examining dissemination to clinicians for clinical outcomes

Author, Year, Design Sample Size Duration Risk of Bias | Setting Sample Characteristics | Intervention Groups | Outcome | Results
Trials that compared reach strategies with abilty strategies
Simon et al., 2005^96^ cRCT N_c_ = 9 N (clinicians) = 781 N (patients) = 9,820 Baseline, 1-year followup, 2-year followup Low | Clinical All patients with hypertension receiving primary care at 1 of 9 study sites; all clinicians providing primary care for adults at the 9 study sites | G1: Mailed educational materials (increase reach) G2: Individual academic detailing (increase ability) G3: Group academic detailing (increase ability) | Rates of hospitalization (2nd) Blood pressure control (2nd) | G1=G2 G1=G3 No significant difference among groups for blood pressure control. Confidence intervals or p values not reported for G2 vs. G3 comparison for blood pressure control. Confidence intervals or p values not reported for any group comparisons for rates of hospitalizations.
Trials that compared reach strategies with multicomponent strategies
Bekkering et al., 2005^86^ cRCT N_c_= 68 N (physiotherapist) = 113 N (patient) =511 Baseline, 6, 12, 26, and 52 weeks after baseline Low | Clinical Physcial therapy practices that were members of the Royal Dutch Society for Physical Therapy (KNGF) located in or around the cities of Utrecht, Amersfoort, and Hilversum in the Netherlands | G1: Received guidelines by mail (increase reach) G2: Received guidelines + active training strategy (multicomponent) | Patient physical functioning (P) Pain (P) | G2=G3 No significant difference between groups.
Davis et al., 2004^106^ cRCT N_c_=68 N= 2,025 Baseline, 12 month followup Moderate | Clinical GP: All general practices in Tayside, UK Patient: Patients on the lists of participating GPs who were receiving medication for epilepsy and were older than 16 years | G1: Control—guidelines by mail (increase reach) G2: Intermediate (multicomponent) G3: High intervention (multicomponent) | SF-36 general health-related quality-of-life instrument (P) | G1=G2=G3 No significant difference between groups as reported by authors, no CI or p value reported for comparison
Jain et al., 2006^100^ cRCT N_c_=50 Baseline, 12 month followup Low | Clinical Practice: ICU in Canada with at least 8 beds and a dietician Patient: All mechanically ventilated ICU patients who remained in the ICU for > 72 hours | G1: Passive intervention—guidelines by mail (incease reach) G2: Active intervention (multicomponent) | Nutritional adequacy of enteral nutrition (P) Glycemic control (2nd) Duration of ICU or hospital stay (2nd) 28 day mortality (2nd) | G1=G2 No significant difference between groups for nutritional adequacy, duration of ICU or hospital stay, and 28 day mortality, although p values or CI were only reported for nutritional adequacy. G2>G1 for 3 measures of glycemic control
Rebbeck et al. 2006^95^ cRCT N_c_=27 N=99 Baseline, 1.5 months, 3 months, 6 months, and 12 months Low | Clinical Physiotherapy clinics in Australia Clinic: Clinics in 2 states in Australia that had seen at least 5 whiplash cases in the previous year Patient: Patients, 18 years and older, involved in a motor vehicle accident within the previous 6 weeks who presented to the clinic with acute whiplash | G1: Dissemination of guidelines by mail (increase reach) G2: Implementation group (multicomponent) | Patient disability (P) | G1=G2 No significant difference between groups.
Trials that compared reach strategies, ability strategies and multicomponent strategies
Hagmolen et al., 2008^108^ cRCT N_c_=18 Baseline, 12-month followup Moderate | Clinical Children ages 7 to 17 years, who had at least two prescriptions of β2-agonists or ICS in the year before invitation | G1: Guideline dissemination (increase reach) G2: Guideline dissemination + educational program (increase ability) G3: Guideline dissemination + educational program + individualized treatment advice based on airway responsiveness and symptoms (multicomponent) | Change in airway hyper-resonsiveness in children after 1 year (P) Change in asthma symptom scores (2nd); - Total sypmtoms score; - Noctural symptoms score; Usage of asthma medication (2nd):; - Inhaled corticosteroids; - B_2_-agonist | G1= G2=G3 No significant differences among groups total asthma symptom score, and use of B_2_-agonist, G1 and G3>G2 for nocturnal asthma symptoms with largest improvement in G1 G3>G1 and G2 for Inhaled corticosteroids

Note: In most cases, the labels of the intervention groups represent the labels that study authors had originally used, except if they were merely labeled control or intervention. Information in parentheses represents the strategy that the authors of this review believed best captured the intervention components. When authors used nondescriptive or vague labels for the intervention groups (e.g., Group 1, Intervention A) we used a summary of their description of the group as a label. For a full description of the studies intervention components refer to Appendix E.

2nd = secondary outcome; + = Plus; COPD = chronic obstructive pulmonary disease; cRCT = cluster randomized controlled trial; GP = general practitioners; ICS = inhaled corticosteroids; ICU = intensive care unit; P = primary outcome; RCT = randomized controlled trial; SEPAR = Sociedad Española de Neumología y Cirugía Torácica.

Table 20 Strength of evidence: Trials examining dissemination to clinicians for knowledge outcomes

Strategy | Number of Studies; Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Results and Strength of Evidence
Reach strategies versus ability strategies | 1; N=213 RCT119 | Moderate | Unknown (single study) | Direct | Imprecise | Ability strategy significantly more effective than reach strategy Low
Reach strategies versus multicomponent strategies | 1; N_c_=27 N=99 cRCT95 | Low | Unknown (single study) | Direct | Imprecise | Multicomponent strategy significantly more effective than reach strategy Low
Reach strategies, ability strategies, and multicomponent strategies | 1; Nc=61 cRCT120 | Moderate | Unknown (single study) | Direct | Imprecise | No significant differences between groups receiving reach, ability, and multicomponent approaches Insufficient

Notes: cRCT = cluster randomized controlled trial; RCT = randomized controlled trial.

Table 21 Summary of studies examining dissemination to clinicians for knowledge outcomes

Author, Year, Design Sample Size Duration Risk of Bias | Setting Sample Characteristics | Intervention Groups | Outcome | Results
Trials that compared reach strategies with ability strategies
Sullivan et al., 2010^119^ RCT N=213 Baseline, immediate posttest, 60-day posttest Moderate | Clinical Residents in internal medicine | G1: VA guidelines for pain management (increase reach) G2: COPE: web-based education program for pain management (increase ability) | Residents’ knowledge and competence with managing opioids for chronic non-cancer pain (P) | G2>G1 Group with interactive web-based training significantly better knowledge scores than the group with standard guidelines.
Trials that compared reach strategies with multicomponent strategies
Rebbeck et al. 2006^95^ cRCT N_c_=27 N=99 Baseline, 1.5 months, 3 months, 6 months, and 12 months Low | Clinical Physiotherapy clinics in Australia Clinic: Clinics in 2 states in Australia that had seen at least 5 whiplash cases in the previous year Patient: Patients, 18 years and older, involved in a motor vehicle accident within the previous 6 weeks who presented to the clinic with acute whiplash | G1: Dissemination of guidelines by mail (increase reach) G2: Implementation group (multicomponent) | Knowledge about evidence (P) | G2>G1 Group with multicomponent strategy significantly better knowledge scores than group with standard dissemination.
Trials that compared reach strategies, ability strategies, and multicomponent strategies
Watson et al., 2002^120^ cRCT N_c_ = 61 Baseline, immediate posttest Moderate | Community-based settings Community pharmacies in Scotland | G1: Guideline materials by postal mail (increase reach) G2: One education outreach (EO) session and guidelines (increase ability) G3: Continuing professional education (CPE) session (increase ability) G4: Gudielines + EO + CPE (multicomponent) | Pharmacists’ knowledge of the treatment of vaginal candidiasis (P) | G1=G2=G3=G4 No significant differences among groups as reported by authors. Confidence intervals or p values not reported for comparison.

Note: In most cases, the labels of the intervention groups represent the labels that study authors had originally used, except if they were merely labeled control or intervention. Information in parentheses represents the strategy that the authors of this review believed best captured the intervention components. When authors used nondescriptive or vague labels for the intervention groups (e.g., Group 1, Intervention A) we used a summary of their description of the group as a label. For a full description of the studies intervention components refer to Appendix E.

COPE = Collaborative Opioid Prescribing Education; cRCT = cluster randomized controlled trial; P = primary outcome; RCT = randomized controlled trial; VA = Department of Veterans Affairs.

Table 22 Strength of evidence: Trials examining dissemination to patients for health-related decisions and behavior outcomes

Strategy | Number of Studies; Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Results and Strength of Evidence
Reach strategies of various sorts | 3; N= 1,710 RCT107,114,115 | Moderate | Inconsistent | Direct | Imprecise | Inconsistent effects of comparisons for various reach strategies Insufficient
Reach strategies versus motivation strategies | 4; N=1,609 4 RCT91,101,104,111 | Moderate | Inconsistent | Direct | Imprecise | Inconsistent effects of reach and motivation strategies on mammography screening adherence and physical activity. Insufficient
Reach strategies versus multicomponents strategies | 4; N= 2,591 4 RCT78,92,99,117 | Moderate | Inconsistent | Direct | Precise | Inconsistent effects of reach and multicomponent strategies on dietary behaviors, mammography or smoking cessation. Insufficient
Motivation strategies versus multicomponent strategies | 1; N=287 fRCT103 | Moderate | Unknown (single study) | Direct | Imprecise | No results reported for comparisons between active comparators. Insufficient

Notes: fRCT = factorial randomized controlled trial; RCT = randomized controlled trial.

Table 23 Summary of trials examining dissemination to patients for health-related decisions and behavior outcomes

Author, Year, Design Sample Size Duration Risk of Bias | Setting Sample Characteristics | Intervention Groups | Outcome | Results
Trials that compare reach strategies
Gattellari and Ward, 2005^107^ RCT N=421 21 days median length between pretest and posttest Moderate | Community-based settings Men ages 50 to 70 with no known history of prostate cancer | G1: Leaflet (increase reach) G2: Video (increase reach) G3: Booklet (increase reach) | Intention to get PSA screening in next year (2nd) | G1=G2=G3 No significant differences between groups.
Paradis et al., 2011^114^ RCT N=137 Baseline, 2 weeks and 2 months postintervention Moderate | Academic health care institutions Parents or primary caregivers over18 years old of newborns less than 1 month old presenting for their first visit to the pediatrician’s office. | G1: Paper handouts (increase reach) G2: Educational DVD (increase reach) | Self-efficacy for infant care skills (P) Five health care utilization measures (2nd) | G1=G2 No significant difference between groups for self-efficacy. Mixed findings for utilization measures: G2>G1 Educational DVD more effective at reducing professional consultations and office visits G1=G2 No significant differences for additional clinic visits, parent phone calls to clinic, and emergency department visits
Partin et al, 2004^115^ RCT N=1152 1 week post Moderate | Clinical Male veterans ages 50 and older who had no prostate cancer and a scheduled primary care appointment at 1 of 4 Veteran Affairs facilities in the Midwest | G1: Usual care (not abstracted) G2: Pamphlet (increase reach) G3: Video (increase reach) | Discussion about the evidence (2nd) Behavioral intention to get PSA test in next year (2nd) Getting PSA screening (2nd) | Confidence intervals or p values not reported for comparison for these outcomes
Trials that compare reach strategies with motivation strategies
Carney et al., 2005^104^ RCT N=258 Baseline, 12 and 27 month followup Moderate | Community-based settings Women ages 50 and older, without a history of breast cancer, who were eligible for routine mammogram screening | G1: Mailed health information (increase reach) G2: Telephone counseling (increase motivation) | Adherence to mammography screening (P) Time between screening exams (2nd) | G2>G1 Tailored telephone counseling significantly more effective in the short term (up to1 year postintervention) than mailed guideline for adherence to mamography screening and time between screening G2>G1 Tailored telephone counseling significantly more effective in the long term (up to 27 months postintervention) than mailed guideline for time between screenings
Kennedy et al., 2003^91^ RCT N=894 Baseline (6-weeks preconsultation), immediate postconsulation, 6, 12, and 24 months postconsultation Low | Clinical Women referrred to 1 of 28 consultant gynecologists from 6hospitals in England with a new episode of menorrhagia | G1: Control (not abstracted) G2: Information (increase reach) G3: Interview (increase motivation) | Behavioral intentions (treatment preferences) (2nd) Treatments undertaken for menorrhagia (2nd) | Confidence intervals or p values not reported for comparison for behavioral intentions G2=G3 No significant difference between groups for treatment undertaken
King et al., 2007^101^ RCT N=218 Baseline, 6, and 12 months Moderate | Community-based settings Inactive men and women ages 55 and older | G1: Attention control (not abstracted) G2: Counselor via phone (increase motivation) G3: Automated counselor via phone (increase reach) | Physical activity measures: (P); - Stanford 7-day physical activity recall; - CHAMPS | G2=G3 No significant difference between groups.
Marcus et al., 2009^111^ RCT N=239 Baseline, 6 months and 12 months Moderate | Community-based settings Sedentary, healthy adults ages 18 to 65 | G1: Contact control treatment delayed group (not abstracted) G2: Telephone-based individualized feedback (increase motivation) G3: Print-based individualized feedback (increase reach) | 7-day physical activity recall: (P); - Behavioral intentions to exercise (decisional balance) (2nd); - Self-efficacy for exercising (2nd) | G3>G2 Print-based feedback significantly more effective than telephone-based feedback for physical activity and self-efficacy at 12 months but not at 6 months G3=G2 Print-based feedback not significantly more effective than telephone-based feedback for behavioral intentions at any time point
Trials that compared reach strategies with multicomponents strategies
Elder et al., 2005;^78^ 2006^72^ RCT N=357 Baseline, 12-week, and 12-month followups Moderate | Community-based settings Spanish-language-dominant women between 18 and 65 years | G1: Culturally targeted print-materials + activity inserts (increase reach) G2: Tailored print materials + activity inserts + supporting materials (multicomponent). G3: Tailored print materials + in-person promotora (multicomponent) | Percent calories from fat (P) Number of daily grams of fiber (P) Nine dietary variables (2nd):; - Energy intake; - Total fat; - Total saturated fat; - Soluble dietary fiber; - Insoluble dietary fiber; - Total carbohydrates; - Glucose; - Fructose; - Sucrose | G1=G2=G3 No significant differences among groups at 12 weeks or 12 months G3>G1 for energy intake and total carbohydrates at 12 weeks, not 12 months Tailored print materials plus promotora more effective than culturally targed materials in decreasing energy intake and total carbohydrates G3>G2 for total fat, total saturated fat, glucose and fructose at 12 weeks, not 12 months Tailored print materials plus promotora more effective than tailored print materials in decreasing total fat, total saturated fat, glucose and fructose intake.
Lien et al., 2007^92,a^ Svetkey et al., 2003^94^ Young et al., 2009^93^ RCT (single trial; different outcomes) Baseline, 3, 6, 12 and 18 months N=810 Low | Clinical Generally health adults over 25 years old with prehypertension or stage-1 hypertension | G1: Advice only (increase reach) G2: Advice + behavioral counseling using established intervention (multicomponent) G3: Established intervention + DASH dietary recommendations (multicomponent) | Meeting at least 3 dietary and fitness goals (P) | G3>G2>G1 Both strategies involving behavioral counseling significantly more effective than the individual advice without behavioral counseling at 6 months. G1=G2; G3>G2; G3>G1 Multicomponent approach involving DASH diet and behavioral counseling significantly more effective than the individual advice without behavioral counseling at 18 month and behavioral counseling with established intervention.
Rimer et al., 2001^117^ RCT N=1,127 Yearly Moderate | Clinical Women in their mid-40s and mid-50s | G1: No treatment control/usual care (not abstracted) G2: Tailored print (TP) (increase reach) G3: TP + telephone counselling (TC) (multicomponent) | Adherence to yearly screening mammography (P) | G2=G3 No significant difference between groups.
Wetter et al., 2006^99^ RCT N=297 Baseline, 5-week followup, 12-week followup Low | Community-based settings Spanish-speaking smokers, ages 18 and older, who called the National Cancer Institute Cancer Information Service to request smoking cessation | G1: Single standard telephone-counseling session (increase reach) G2: Multiple enhanced telephone counseling sessions (multicomponent) | Smoking abstinence (P) | G2>G1 Proactive (enhanced, multiple sessions) telephone counseling plus culturally tailored information significantly more effective than standard single session) telephone-counseling.
Trials that compared motivation strategies with multicomponent strategies
Campbell et al., 2004^103^ fRCT N=287 Baseline, 12-month followup Moderate | Community-based settings Adults, age 18 and older, that were active members of participating church | G1: Control (not abstracted) G2: Lay health advsior (LHA) (increase motivation) G3: Tailored and targeted print and video (TPV) (multicomponent) G4: TPV and LHA (multicomponent) | Fruit and vegetable consumption (P) Physical activity (P) Fat intake (P) CRC screening (2nd) | G3>G2, G3>G4 Tailored print and video significantly more effective than LHA or multicomponent approach for increasing fruit and vegetable intake and physical activity G2=G3=G4 No significant differences for CRC screening and fat intake

Note: In most cases, the labels of the intervention groups represent the labels that study authors had originally used, except if they were merely labeled control or intervention. Information in parentheses represents the strategy that the authors of this review believed best captured the intervention components. When authors used nondescriptive or vague labels for the intervention groups (e.g., Group 1, Intervention A) we used a summary of their description of the group as a label. For a full description of the studies intervention components refer to Appendix E.

2nd = secondary outcome; + = plus; CRC = colorectal cancer; P = primary outcome.

Table 24 Strength of evidence: Trials examining dissemination to patients for clinical outcomes

Strategy | Number of Studies; Subjects; Design/ | Risk of Bias | Consistency | Directness | Precision | Results and Strength of Evidence
Reach strategies versus motivation strategies | 1; N= 894 RCT91 | Low | Unknown (single study) | Direct | Imprecise | No significant differences between groups. Low
Reach strategies versus multicomponent strategies | 1^a^; N= 810 RCT92–94 | Low | Unknown (single trial population but different outcomes) | Direct | Precise | Multicomponent groups more effective than reach groups. Low

a These articles reported on the same sample population but reported slightly different outcomes. We combined information from these articles and report them as one article in text.

Notes: N = number; RCT = randomized controlled trials.

Table 25 Summary of trials examining dissemination to patients for clinical outcomes

Author, Year, Design Sample Size Duration Risk of Bias | Setting Sample Characteristics | Intervention Groups | Outcome | Results
Trials that compared reach strategies with motivation strategies
Kennedy et al., 2003^91^ RCT N=894 Baseline (6-weeks preconsultation), immediate postconsulation, 6, 12, and 24 months postconsultation Low | Clinical Women referrred to 1 of 28 consultant gynecologists from 6 hospitals in England with a new episode of menorrhagia | G1: Control (not abstracted) G2: Information (increase reach) G3: Interview (increase motivation) | Health-related quality of life measured by the Medical Outcomes Study Short Form (SF-36) questionnaire (P) | G2=G3 No significant difference between groups.
Trials that compared reach strategies with multicomponent strategies
Lien et al., 2007^92,a^ Svetkey et al., 2003^94^ Young et al., 2009^93^ RCT (single trial; different outcomes) Baseline, 3, 6, 12 and 18 months N=810 Low | Clinical Generally health adults over 25 years old with prehypertension or stage-1 hypertension | G1: Advice only (increase reach) G2: Advice + behavioral counseling using established intervention (multicomponent) G3: Established intervention + DASH dietary recommendations (multicomponent) | Change in systolic blood pressure at 6 months (P) Change in weight (2nd) | G2>G1; G3>G1 G3=G2 Both strategies involving behavioral counseling significantly more effective than the individual advice without behavioral counseling for reducing blood pressure and weight.

Note: In most cases, the labels of the intervention groups represent the labels that study authors had originally used, except if they were merely labeled control or intervention. Information in parentheses represents the strategy that the authors of this review believed best captured the intervention components. When authors used nondescriptive or vague labels for the intervention groups (e.g., Group 1, Intervention A) we used a summary of their description of the group as a label. For a full description of the studies intervention components refer to Appendix E.

2nd = secondary outcome; DASH = Dietary Approaches to Stop Hypertension; P = primary outcome.

Table 26 Strength of evidence: Trials examining dissemination to patients for knowledge outcomes

Strategy | Number of Studies; Subjects; Design/ | Risk of Bias | Consistency | Directness | Precision | Results and Strength of Evidence
Reach strategies of various sorts | 3; N=1,710 RCT107,114,115 | Moderate | Inconsistent | Indirect | Imprecise | Inconsistent findings about the benefit of print or video reach strategies. Insufficient
Reach strategies versus motivation strategies | 1; N=894 RCT | Low | Unknown (single study) | Indirect | Imprecise | Confidence intervals or p values not reported for this comparison Insufficient
Reach strategies versus multicomponent strategies | 1; N=1,127 RCT117 | Moderate | Unknown (single study) | Indirect | Precise | Inconsistent findings across two knowledge outcomes in one study. Insufficient

Table 27 Summary of trials examining dissemination to patients for knowledge outcomes

Author, Year, Design Sample Size Duration Risk of Bias | Setting Sample Characteristics | Intervention Groups | Outcome | Results
Trials that compared reach strategies
Gattellari and Ward, 2005^107^ RCT N=421 21 days median length between pretest and posttest Moderate | Community-based settings Men ages 50 to 70 with no known history of prostate cancer | G1: Leaflet (increase reach) G2: Video (increase reach) G3: Booklet (increase reach) | Knowledge about prostate cancer screening (P) | G3>G2, G3>G1 G2=G1 Booklet significantly more effective than either leaflet or video.
Paradis et al., 2011^114^ RCT N=137 Baseline, 2 weeks and 2 months postintervention Moderate | Academic health care institutions Parents or primary caregivers over 18 years old of newborns less than 1 month old presenting for their first visit to the pediatrician’s office. | G1: Paper handouts (increase reach) G2: Educational DVD (increase reach) | Parent knowledge of infant development (P) | G1=G2 No significant difference between groups.
Partin et al, 2004^115^ RCT N=1152 1 week post Moderate | Clinical Male veterans ages 50 and older who had no prostate cancer and a scheduled primary care appointment at 1 of 4 Veteran Affairs facilities in the Midwest | G1: Usual care (not abstracted) G2: Pamphlet (increase reach) G3: Video (increase reach) | Prostate Cancer screening knowledge (P) | G2=G3 No significant difference between groups as reported by authors, no significance tests or CI reported.
Trials that compared reach strategies with motivation strategies
Kennedy et al., 2003^91^ RCT N=894 Baseline (6-weeks preconsultation), immediate postconsulation, 6, 12, and 24 months postconsultation Low | Clinical Women referrred to 1 of 28 consultant gynecologists from 6 hospitals in England with a new episode of menorrhagia | G1: Control (not abstracted) G2: Information (increase reach) G3: Interview (increase motivation) | Knowledge of available treatment options (2nd) | Confidence intervals or p values not reported for this outcome
Trials that compared reach strategies with multicomponent strategies
Rimer et al., 2001^117^ RCT N=1127 Yearly Moderate | Clinical Women in their mid 40s and mid 50s | G1: No treatment control/usual care (not abstracted) G2: Tailored print (increase reach) G3: Tailored print + telephone counselling (multicomponent) | Knowledge for:; - Accuracy of risk perception (P); - Mammogram effectiveness (P) | Inconsistent findings G3>G2 for risk perception accuracy; G3=G2 for mammogram effectiveness Multicomponent strategy was more effective than tailored print intervention for increasing knowledge about risk for cancer than the reach strategy, but the stragegies did not differ in knowledge about mammogram effectiveness.

Note: In most cases, the labels of the intervention groups represent the labels that study authors had originally used, except if they were merely labeled control or intervention. Information in parentheses represents the strategy that the authors of this review believed best captured the intervention components. When authors used nondescriptive or vague labels for the intervention groups (e.g., Group 1, Intervention A) we used a summary of their description of the group as a label. For a full description of the studies intervention components refer to Appendix E.

2nd = secondary outcome; P = primary outcome; RCT = randomized controlled trial.

Table 28 Strength of evidence: Trials examining dissemination to clinicians and patients for health-related decisions and behavior outcomes

Strategy | Number of Studies; Subjects; Design/ | Risk of Bias | Consistency | Directness | Precision | Results and Strength of Evidence
Reach strategies versus multicomponent strategies | 4; N= 1,676 Nc=116,N=1378 2 RCT87,89 fRCT105 1cRCT84 | Low | Inconsistent | Direct | Imprecise | Results inconsistent or authors did not present significance tests or confidence intervals for comparisons Insufficient
Ability strategies versus multicomponent strategies | 1; Nc=30 N=4,239 cRCT88 | Low | Unknown (single study) | Direct | Imprecise | No significant differences between groups Insufficient
Studies that compared Multicomponent strategies | 1; N=45 N_c_=548 cRCT112 | Moderate | Unknown (single study) | Direct | Imprecise | Authors did not report significant tests for comparisons Insufficient

Table 29 Summary of studies examining dissemination to clinicians and patients for health-related decisions and behavior outcomes

Author, Year, Design Sample Size Duration Risk of Bias | Setting Sample Characteristics | Intervention Groups | Outcome | Results
Trials that compare reach strategies with multicomponent strategies
Becker et al., 2008^84^ cRCT N_c_=116 N=1,378 Baseline, 6- and 12-month followup Low | Clinical GPs: General practices in semi-rural region of Germany Patients: Patients ages 19 and older presenting symptoms of lower back pain on the day of recruitment | G1: Mailed guideline (Increase clinician reach) G2: Guideline implementation (multicomponent, clinicians only) G3: Guideline implementation and motivational counseling directed at patient (multicomponent, clinicians and patients) | Overall physical activity (2nd) | Confidence intervals or p values not reported for this comparison
Bishop & Wing, 2006^87^ RCT N=462 0–4 weeks, 5–12 weeks, >12 weeks Low | Clinical Patients with acute low back pain symptoms for more than 2 weeks and less than 4 weeks and an accepted claim with the Workers’ Compensation Board of British Columbia relating to an injury | G1: Control (not abstracted) G2: Physician only (increase reach) G3: Physician and patient (multicomponent) | Guideline-concordant treatment advice and procedures (education, exercise, non-narcaotic medication, spinal manipulation, physical therapy) or guideline-discordant treatment advice and procedures (>4 days bed rest, continued passive therapy, routine use of narcotic analgesics) (P) | Confidence intervals or p values not reported for this comparison
Christakis et al., 2006^105^ fRCT N=887 Baseline, up to 365 days after baseline. Moderate | Clinical Children under 11 years of age who were patient at a participating clinic and who needed to make a well-child visit during the study period. | G1: Usual care (not abstracted) G2: Parental content Alone (increase reach) G3: Provider notification alone (not abstracted) G4: Parental content and provider notification (multicomponent) | Discussion of MyHealthy Child topics (P) Parent mplementation of MyHealthy Child topics (P) | Confidence intervals or p values not reported for this comparison
Feldstein et al., 2006^89^ RCT N=327 6 months post intervention Low | Clinical Women ages 50 to 89 who had suffered a fracture in 1999 and had not received bone mineral density measurement or medication for osteoporosis | G1: Usual care (not abstracted) G2: EMR reminder (increase reach for clinicians) G3: EMR reminder and patient reminder (via letter with educational materials (multicomponent) | Proportion of study population receiving a pharmacological treatment (P) Proportion of study population receiving bone mineral density measurement within 6 months after the intervention (P) Total calcium intake (2nd) Regular physical activity (2nd) Weekly caloric expenditure (2nd) | G2=G3 No significant differences between groups For secondary outcomes confidence intervals or p values not reported for these comparisons
Trials that compare ability strategies with multicomponent strategies
Eaton et al., 2011^88^ cRCT N_c_=30 N=4,239 Low | Clinical Primary care practices in Southeastern New England; other inclusion criteria not reported | G1: 1-hour academic detailing (increase clinician ability) G2: Academic detailing plus a patient education toolkit, a computer kiosk with patient activation software, and a clinician PDA-based decision support tool (multicomponent) | Percentage of patients screened for hyperlipidemia treated for their low-density lipoprotein and non–high-density lipoprotein (HDL) cholesterol (P) | G1=G2 No significant difference between groups
Trials comparing multicomponent strategies
Maxwell et al., 2010^112^ cRCT N_c_=548 Baseline, 6-month followup Moderate | Community-based settings Filipino-Americans, ages 50 to 70, who are not current with colorectal cancer screening | G1: Control (not abstracted) G2: Educational session + letter to provider (multicomponent) G3: Educational session + letter to provider + FOBT kit (multicomponent) | Self-reported CRC screening rates (P) | Confidence intervals or p values not reported for this comparison

Note: In most cases, the labels of the intervention groups represent the labels that study authors had originally used, except if they were merely labeled control or intervention. Information in parentheses represents the strategy that the authors of this review believed best captured the intervention components. When authors used nondescriptive or vague labels for the intervention groups (e.g., Group 1, Intervention A) we used a summary of their description of the group as a label. For a full description of the studies intervention components refer to Appendix E.

2nd = secondary outcome; + = Plus; CRC = colorectal cancer; cRCT = cluster randomized controlled trial; EMR, electronic medical record; FOBT, fecal occult blood test; fRCT = factorial randomized controlled trial; Nc, number of clusters; P = primary outcome.

Table 30 Strength of evidence: Trial examining dissemination to clinicians and patients for clinical outcomes

Strategy | Number of Studies; Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Results and Strength of Evidence
Reach strategies versus multicomponent strategies | 1; N_c_ = 116 N=1,378 cRCT84 | Low | Unknown (single study) | Direct | Imprecise | Likely no difference between groups; authors did not report confidence intervals or significance tests for comparisons. Insufficient

Notes: cRCT = cluster randomized controlled trial; Nc = number of clusters.

We graded the SOE for trials at the level of dissemination strategy (increasing reach, ability, motivation, or multicomponent) and outcome category (health-related decision or behavior, clinical outcome or knowledge). In some cases, only one trial was relevant to the analysis (i.e., a single study for which SOE could be graded); in other cases we had as many as six trials on a strategy-outcome topic, but they were different enough to preclude any meta-analysis.

The trials were conducted in the United States, Canada, England, Germany, Finland, the Netherlands, Scotland, and Spain. Sample sizes ranged from 114 participants to 3,293 participants. For the cRCTs, cluster sizes ranged from 9 to 249.

In the tables below (Tables 14–30), we summarize the intervention comparisons that the authors had used along with our classification of specific strategies attempting to affect reach, ability, motivation or a combination of these aims. The summary tables show the following: author, year of publication, study design (RCT or cRCT), number of study participants (N) and/or number of clusters (N_c_) randomized (if reported), study duration, quality rating for the trial; setting and sample characteristics; study intervention groups (e.g., G1,…GX); and the outcomes as defined by the authors; and a summary of the trial’s results.

We described summary results in several ways. If one group (e.g., G1) had a stronger effect than another group (e.g., G2) we denoted this as G1>G2. If significance tests or confidence intervals were reported for the direct comparison, and they indicated statistical significance, we described these in the table as significant differences. In some cases there were no significance tests or confidence intervals reported for the comparisons of interest; instead, the active arms were compared to a control group and we note this in the tables as no significance tests or confidence intervals reported for the comparison of interest.

If groups did not differ we noted this in summary tables as G1=G2. Here again, if statistical significance tests or confidence intervals were reported for the direct comparison we described these as no significant differences. As previously mentioned, in some cases there were no significance tests or confidence intervals reported. In these cases we noted this in the tables no significance tests or confidence intervals reported for the comparison of interest.

In the next three sections we review the evidence for dissemination strategies focused on clinicians and patients. In the first section we focus on clinicians, in the second section on patients, and in the third section on studies that targeted both clinicians and patients. In each section summarize key points, present the strength of evidence table for each comparison category and summarize the evidence in tables and the narrative. The summary tables describe the study and key findings. The narrative describes additional details, including the specific dissemination tactics a trial used.

## Key Question 2 Disseminating Evidence to Clinicians

### Key Points: Clinician Trials

- Ability strategies are not more effective than reach strategies related to clinician behavior (4 trials, low SOE).
- Multicomponent strategies that address a combination of reach, ability, or motivation appear to be more effective than one strategy alone for affecting clinicians’ behaviors, particularly guideline adherence (7 trials; moderate SOE) and for clinical outcomes although many comparisons examining clinical outcomes were not significant (6 trials, low SOE.)
- The strength of evidence is low or insufficient for most comparisons related to clinical outcomes and knowledge for clinicians because we had only single trials in each case.

### Detailed Synthesis: Dissemination Strategies for Clinicians and Health-Related Decisions or Behaviors

Table 16 documents the strength of evidence grading for each of the dissemination comparisons focused on clinicians for health-related decisions and behaviors and gives the overall SOE grade.

Table 15 describes the clinician-focused trials and summarizes their results for decision or behavioral outcomes. The text accompanying the table describes trials that compare (a) reach and ability strategies, (b) reach and motivation strategies, (c) reach versus multicomponent strategies, (d) ability versus multicomponent strategies, (e) motivation versus multicomponent strategies, and (f) ability, or motivation and multicomponent strategies.

#### Strategies To Increase Reach Versus Strategies To Increase Ability

Four trials tested dissemination strategies to affect clinician health-related decisions and behaviors by increasing reach or increasing ability (Table 17). Three were cRCTs,83,90,96 and one was a RCT.119 Reach strategies included delivering guidelines by mail or computer; increasing ability strategies included computer assisted learning, textbooks, and individual or group academic detailing. The followup periods ranged from 1 month to 2 years after the intervention. All trials examined guideline-concordant care, but for different behaviors and conditions. Across these trials, intervention groups did not differ significantly for any of the primary outcomes reported.

#### Strategies To Increase Reach Versus Strategies To Increase Motivation

One trial tested dissemination strategies to affect clinician behavior by increasing reach versus increasing motivation (Table 17).109 This trial compared conventional guideline delivery with a scheme that contained vignettes involving patient-specific ratings from an expert panel as part of the guideline message. For example “the expert panels recommend exercise testing (rating 7),” where the rating corresponded to the appropriateness of that test for a specific patient portrayed in a vignette (e.g., patient specific ratings). The outcome measure was the agreement between the physician’s test ordering and recommendations of two independent expert panels. Immediate posttest measures after the intervention showed providing this vignette-driven, patient-specific information about the appropriateness of applying a guideline was significantly more effective than simply providing traditional guidelines.

#### Strategies To Increase Reach Versus Multicomponent Strategies

Seven trials tested dissemination strategies to affect clinician behavior by increasing reach against multicomponent strategy (Table 17).85,95,97,102,113,121,122 Four trials were cRCTs. Each trial compared multicomponent approaches that involved some type of educational component and written or in-person reminders or decisions support materials with reach strategies that entailed postal or emailed guidelines. One study used an opinion leader delivering guidelines as the reach strategy.95 The followup periods ranged from 45 days to 1 year after the intervention. Across these six trials, five of the seven found that multicomponent strategies were more effective at changing outcomes compared to reach strategies. In one trial102 statistical significance tests were not reported for this comparison.

#### Strategies To Increase Ability Versus Multicomponent Strategies

Three trials tested dissemination strategies to affect clinician behavior by increasing ability against a multicomponent approach (Table 17).110,116 One was a cRCT with a followup period of up to 136 days after the intervention assessing whether a workshop that provided education about evidence-based medicine and decision support via a decision tree (multicomponent) was better than either the workshop alone (ability) or decision tree alone (ability) in promoting appropriate prescriptions for patients with osteoarthritis.116 The authors reported only significant comparisons of each of these intervention arms with a no-treatment control group and did not compare the intervention arms to each other. The authors suggested that the multicomponent approach they used may confer a weak advantage compared with either of the ability strategies alone, but they presented no specific statistical analyses supporting this statement. The second cRCT with a 6-month followup period tested whether continuing medical education (CME) (ability strategy) that also provided practice enablers and reinforcers (motivation strategy) was better than CME alone in promoting guideline adherence.110 Enablers and reinforcers took the form of a nurse providing prompts to reevaluate care for patients who might have undermanaged, high-risk cardiovascular disease and a checklist of the most recent and relevant clinical practice guidelines. The arm with the CME plus these reinforcing intervention elements was significantly better than CME alone. The RCT in this category was large (N=2,624). They compared an ability strategy (training sessions) with a multicomponent strategy (training sessions plus provision of portable spirometry) to improve diagnosis and severity classification of chronic obstructive pulmonary disease.118 The authors compared both arms with a no-treatment control group, but not to each other, and did not report confidence intervals or significance tests for our comparisons of interest.

#### Strategies To Increase Motivation Versus Multicomponent Strategies

One trial tested a dissemination strategy to affect clinician behavior by increasing motivation against a multicomponent strategy (Table 17);98 it used a cRCT design with a 360-day followup. The primary outcome was guideline adherence related to lymph node assessment and biopsy. The authors compared a motivation strategy involving an expert opinion leader with a multicomponent strategy that involved the expert opinion leader plus academic detailing and a toolkit. The multicomponent arm was more effective for one of the outcomes, i.e., lymph node assessment; the groups did not differ significantly, however, for lymph node removal.

#### Strategies To Increase Reach and Ability Versus Multicomponent Strategies

One four-arm cRCT study compared a reach strategy (guidelines by mail), two different ability strategies (one educational session with guidelines and a continuing professional education session with guidelines), and a multicomponent strategy that involved all these steps to affect the dispensing of antifungal medications for vulvovaginal candidiasis in community-based pharmacies (Table 17).120 This trial assessed the primary outcome by having trained actors visit pharmacies presenting with particular clinical symptoms that might or might not require anti-fungal medication. The groups did not differ significantly immediately after the intervention.

### Detailed Synthesis: Dissemination Strategies for Clinicians and Clinical Outcomes

Table 18 documents the strength of evidence grading for six trials that examined dissemination strategies focused on clinicians and assessed clinical outcomes and gives the overall SOE grade.

Table 19 describes clinician-focused trials and summarizes their results for clinical outcomes. Text accompanying the table describes trials that compare (a) reach and ability strategies, (b) reach and multicomponent strategies, and (c) reach, ability, or multicomponent strategies.

#### Strategies To Increase Reach Versus Strategies To Increase Ability

One cRCT compared a reach strategy with two ability strategies.96 The reach strategy involved mailed information. The ability strategies involved group academic detailing in one group and individual academic detailing in the other group. Over a two year followup period there were no significant differences among groups for guideline adherence related to treatment of hypertension patients.

#### Strategies To Increase Reach Versus Multicomponent Strategies

Four studies compared reach strategies with multicomponent strategies.86,95,100,106 Three were cRCTs that had 1-year followup assessing patient outcomes such as physical functioning and pain,86 nutrition support,100 or quality of life.106 One study was a cRCT with followup at 1.5, 3, 6, and 12 months.95 Three studies used mailed guidelines as the reach strategy; multicomponent approaches involved educational training, use of supportive decision aids, opinion leaders, or a nurse specialist for consultation.86,95,106 Jain et al. compared giving written materials with an extensive multicomponent intervention providing education, web-based tools, and interpersonal support to dieticians providing nutritional support to critically ill adults on mechanical ventilation in an intensive care unit.100 The reach and multicomponent approaches did not differ significantly for any of these studies at followup assessment.

#### Strategies To Increase Reach, Ability, and Multicomponent Strategies

One trial tested the effect of dissemination strategies to improve clinical outcomes by increasing reach versus increasing ability versus a multicomponent approach.108 Reach strategy included dissemination of a guideline regarding childhood asthma treatment, ability strategy included the addition of education, and the multicomponent approach added individualized treatment advice. Study groups did not differ significantly in in airway responsiveness at 12-month followup.

### Detailed Synthesis: Dissemination Strategies for Clinicians and Knowledge Outcomes

Table 20 documents the strength of evidence grading for each of the dissemination comparisons focused on clinicians for clinical outcomes and gives the overall SOE grade.

Table 21 describes clinician-focused trials and summarizes their results for knowledge outcomes. Text accompanying the table describes trials that compare (a) reach and ability strategies, (b) reach and multicomponent strategies, and (c) reach, ability, or multicomponent strategies.

#### Strategies To Increase Reach Versus Strategies To Increase Ability

One trial compared a reach strategy (dissemination of guidelines via email) with an ability strategy (guidelines and a web-based education program) and measured enhancement of residents’ knowledge of the use of opioids for managing pain.119 At the end of a 60-day followup period, residents receiving the ability strategy had significantly higher scores on a knowledge and competence measure.

#### Strategies To Increase Reach Versus Multicomponent Strategies

One study compared a reach strategy (dissemination of guidelines via mail) with a multicomponent strategy that involved a one-day workshop led by opinion leaders. During the workshop materials supporting guideline practice for whiplash were provided to participants. The workshop was followed by a two-hour outreach visit six months later. The multicomponent approach was significantly better at increasing knowledge about how to treat whiplash.

#### Strategies To Increase Reach, Strategies To Increase Ability, and Multicomponent Strategies

This four-arm cRCT study (previously described in Table 16) also assessed clinician knowledge as a primary outcome.120 They compared a reach strategy (guidelines by mail), two ability strategies (educational session with guidelines and CME with guidelines), and a multicomponent strategy that involved all these combined strategies. The outcome measure appropriate dispensing of antifungal medications for vulvovaginal candidiasis in community-based pharmacies. The groups did not differ significantly in knowledge scores assessed with self-report prepost intervention questionnaires

## Key Question 2 Disseminating Evidence to Patients

### Key Points

- Evidence is inconsistent for determining the benefit of reach, ability, motivation, or multicomponent approaches for patients focused on changing health-related decisions and behaviors (12 trials; insufficient SOE).
- Evidence is insufficient for determining the benefit of reach, ability, motivation or multicomponent approaches for patients focused on changing clinical outcomes (2 trials; 1 low; 1 insufficient SOE due to one trial in each category).
- Evidence is insufficient for determining the benefit of reach, ability, motivation or multicomponent approaches for patients focused on changing knowledge outcomes (3 trials; insufficient SOE due to inconsistent findings or one trial in a category).

### Detailed Synthesis: Dissemination Strategies for Patients and Health-Related Decisions or Behaviors

Table 22 documents the strength of evidence grading for each of the dissemination comparisons focused on patients for health-related decisions and behavior outcomes and gives the overall SOE grade.

Table 23 describes patient-focused trials and summarizes their results for health-related decisions and behavior outcomes. Text accompanying the table describes trials that (a) compare reach strategies of various types, (b) reach and motivation strategies, (c) reach and multicomponent strategies, and (d) motivation and multicomponent strategies.

#### Strategies To Increase Reach

Three trials compared reach strategies with other reach strategies with respect to patient health-related decisions and behaviors including intention to get a PSA screening,107,115 self-efficacy for infant care, health care utilization,114 and evidence discussions.115 These RCTs had samples sizes ranging from 137 to 1,152, took place in community-based, academic health care, and outpatient clinical settings. Followup assessment ranged from 1 week to 2 months after the interventions. Results across the trials were inconsistent, but generally did not find any significant differences between the reach strategies compared. The two studies that compared printed materials with electronic methods—i.e., a DVD114 or a video115 found no significant differences between groups on outcomes, except that the DVD was significantly more effective at reducing two measures of health care utilization114 among parents caring for infants.

#### Strategies To Increase Reach Versus Strategies To Increase Motivation

Four trials (N ranging from 218 to 894) compared strategies to enhance reach with strategies to enhance motivation. Two trials examined findings over a 6- and 12-month followup periods, and two used 24- or 27-month followup periods. One aimed to encourage adherence to mammography screening guidelines;104 two encouraged physical activity among older adults in community settings,101,111 and the other examined treatment preferences and treatments undertaken for menorrhagia.91 Interpersonal telephone counseling, categorized as a motivational strategy, produced inconsistent effects. In one trial, telephone counseling was significantly better than a reach strategy involving mailed information, at prompting recipients to get mammography screening.104 In another trial, interpersonal telephone counseling and automated telephone counseling did not differ in encouraging physical activity over 1 year;101 in a third trial, print-based feedback was more effective than telephone-based counseling in promoting physical activity over 1 year at at the 12-, but not 6-month, followup.111 In the trial that compared provision of an information packet (reach) to a preference elicitation interview with a nurse (motivation) found no differences for the outcomes studied.91

#### Strategies To Increase Reach Versus Multicomponent Strategies

Four trials (N ranging from 297 to 1,127) compared reach strategies with multicomponent approaches. Two took place in community settings and focused on enhancing Latino health, with one focused on changing nutrition intake72,78 and one focused on smoking cessation.99 Both trials had a 12-week followup. Another trial also focused on increasing dietary and fitness goals.92 Both trials had a 12-week followup and one of these subsquently reported as 12-month followup.72 The other trial, in a clinical setting, focused on improving adherence to mammography screening.117 Two of these trials compared reach strategies (print materials) with a multicomponent strategy (print materials plus interpersonal counseling via telephone or in person); groups did not differ significantly in the primary outcomes studied, percent calories from fat or number of daily grams of fiber,78,117 and of the nine secondary outcomes related to dietary intake only three were significantly increased in the group that received tailored print materials plus an interpersonal counselor at the 12-week followup.78 These findings were not replicated at the 12 month followup.72 The trial that compared single-session telephone counseling (motivation strategy) with more intensive telephone counseling plus supporting materials (multicomponent) and found the multicomponent strategy to be more effective than the motivation strategy at the 12-week followup.99 The trial that compared the provision of advice and information to two differenent behavioral counseling approaches that differed by the type of dietary recommendations provided found inconsistent results.92 Both multicomponent strategies involving behahavioral counseling were more effective than just the provision of individual advise at a six month followup. However, at an 18-month followup the multicomponent strategy involving the DASH dietary recommendations was signficantly more effective than the other groups.

#### Strategies To Increase Motivation Versus Multicomponent Strategies

One trial compared an interpersonal motivation strategy (lay health advisors [LHA]) with two different multicomponent approaches─one that involved tailored and targeted print and video materials (TPV), and another that involved LHAs plus the print and video materials (LHA+TPV).103 TPV was significantly better than control, and a LHA or a multicomponent approach that involved both TPV and LHA for fruit and vegetable intake and physical activity; the more intense multicomponent approach (LHA+TPV) was not significantly better than control or other active comparators for any outcome. There were no significant differences among groups related to fat intake or CRC screening.

### Detailed Synthesis: Dissemination Strategies to Patients for Clinical Outcomes

Table 24 documents the strength of evidence grading for each of the dissemination comparisons focused on patients and assessing clinical outcomes and gives the overall SOE grade.

Table 25 describes patient-focused trials and summarizes their results for clinical outcomes. Text accompanying the table describes trials that compare (a) reach and motivation strategies, and (b) reach and multicomponent strategies.

#### Strategies To Increase Reach Versus Strategies To Increase Motivation

One trial compared a reach strategy that involved providing written and video-based information with a preference elicitation interview for 894 women with menorrhagia in outpatient clinics.91 Followup measures at 6, 12, and 24 months showed no differences between groups on a health status measure.

#### Strategies To Increase Reach Versus Multicomponent Strategies

One trial compared a reach strategy involving providing advice in an in-person meeting with registered dietitian with two different multicomponent strategies that entailed lifestyle behavioral counseling with slightly different informational content.92–94 Participants were adults with or at risk for hypertension. The two multicomponent groups did not differ significantly at 6-month followup, but both were superior to advice only in affecting blood pressure at 6-month followup.

### Detailed Synthesis: Dissemination Strategies for Patients and Knowledge Outcomes

Table 26 documents the strength of evidence grading for each of the dissemination comparisons focused on patients for knowledge outcomes and gives the overall SOE grade.

Table 27 describes patient-focused trials and summarizes their results for knowledge outcomes. Text accompanying the table describes trials that compare (a) various reach strategies, (b) reach and motivation strategies, and (c) reach and multicomponent strategies.

#### Strategies To Increase Reach

Three trials compared reach strategies with other reach strategies with respect to patient knowledge. These RCTs had samples sizes ranging from 137 to 1,152, took place in community-based, academic health care, and outpatient clinical settings. Followup assessment ranged from 1 week to 2 months after the interventions. Two studies related to prostate cancer screening knowledge; the other focused on parental knowledge of infant development. Results across the trials were inconsistent. The two studies that compared printed materials with electronic methods—i.e., a DVD114 or a video115 found no significant differences between groups on knowledge outcomes. The two studies that examined prostate cancer screening knowledge showed inconsistent results.107,115 In one, a decision aid in the form a booklet was significantly more effective in increasing knowledge than either a video or leaflets;107 by contrast, groups receiving written materials or a video did not differ significantly (although these were not designed as decision aids).115

#### Strategies To Increase Reach Versus Strategies To Increase Motivation

One trial (N=894) compared a strategy to enhance reach with a strategy to enhance motivation using a 6-, 12-, and 24-month followup period. This trial did not report significance tests or confidence intervals for the group comparisons examining knowledge of treatment options for menorrhagia.91

#### Strategies To Increase Reach Versus Multicomponent Strategies

One trial (described in Table 22 for behavioral outcomes) also compared a reach strategy that used print materials with a multicomponent strategy that used print materials plus interpersonal counseling by telephone to increase two types of knowledge─accuracy of risk perceptions and mammography effectiveness.117 For knowledge outcomes, results were inconsistent. The multicomponent approach was more effective than the reach strategy for accuracy of risk perceptions but not for mammography effectiveness.

## Key Question 2 Disseminating Information to Clinicians and Patients

### Key Points

- Evidence is inconsistent for determining the benefit of reach, ability, motivation, or multicomponent strategies that target both providers and patients for health-related decisions and behaviors (6 trials; insufficient SOE).
- Evidence is inconsistent for determining the benefit of reach, ability, motivation, or multicomponent strategies that target both providers and patients for clinical outcomes (1 trial; insufficient SOE).

### Detailed Synthesis: Dissemination Strategies for Clinicians and Patients for Health-Related Decisions and Behavior Outcomes

Table 28 documents the strength of evidence grading for each of the dissemination comparisons focused on clinicians and patients for health-related decisions and behavior outcomes and gives the overall SOE grade.

Table 29 describes clinician and patient-focused trials and summarizes their results for health-related decisions and behavior outcomes. Text accompanying the table describes trials that compare (a) reach and multicomponent strategies, (b) ability and multicomponent strategies, and (c) various multicomponent strategies.

#### Strategies To Increase Reach Versus Multicomponent Strategies

Three RCTs and one cRCT compared reach strategies with multicomponent strategies to affect health-related decisions and behavior outcomes. Sample sizes ranged from 327 to 1387; and followup periods ranged from 12 weeks to 1 year. Reach strategies included dissemination to either a patient105 or clinicians.84,87,89 The multicomponents strategies involved dissemination to both patients and physicians. Across these four trials there was either no significant difference between groups or significance test or confidence intervals were not reported for comparisons between active comparators.

#### Strategies To Increase Ability Versus Multicomponent Strategies

One cRCT study compared an academic detailing session (increase clinician ability) with a multicomponent strategy that included academic detailing and tools and resources for both patients and providers.88 Patient resources included a patient education toolkit (with a companion Web site) and a computer kiosk with patient activation software. Physicians received with a decision support tool based on a personal digital assistant, which included four booster academic detailing sessions. The clinician only and multicomponent group focused on both clinicians and patients did not differ significantly.

#### Comparisons of Multicomponent Strategies

One cRCT compared two multicomponent arms to a control condition in an effort to enhance self-reported CRC screening in a community-based setting.112 In each arm patients received educational information about CRC and a letter was also sent to the patient’s physician. In one of the arms patients also received additional materials in the form of a fecal occult blood test (FOBT) kit. The authors did not make a direct comparison of the multicomponent arms to each other, although both were significantly better than the control group.

### Detailed Synthesis: Dissemination Strategies for Clinicians and Patients for Clinical Outcomes

Table 30 documents the strength of evidence grading for the dissemination comparison focused on clinicians and patients for clinical outcomes and gives the overall SOE grade. Table 31 describes the single trial in this category.

Table 31 Summary of studies examining dissemination to clinicians and patients for clinical outcomes

Author, Year, RefID Design Sample Size Duration | Setting Sample Characteristics | Intervention Groups | Outcome | Results
Studies that compare Reach strategies with Multicomponent strategies
Becker et al., 2008^84^ cRCT N_c_=116 N=1,378 Baseline, 6- and 12-month followup Low | Clinical GPs: General practices in semi-rural region of Germany Patients: Patients ages 19 and older presenting symptoms of lower back pain on the day of recruitment | G1: Mailed guideline (Increase clinician reach) G2: Guideline implementation (multicomponent, clinicians only) G3: Guideline implementation and motivational counseling directed at patient (multicomponent, clinicians and patients) | Functional capacity (Hannover Functional Ability Questionnaire) (P) Quality of Life (2nd) | Confidence intervals or p values not reported for this comparison.

Note: In most cases, the labels of the intervention groups represent the labels that study authors had originally used, except if they were merely labeled control or intervention. Information in parentheses represents the strategy that the authors of this review believed best captured the intervention components. When authors used nondescriptive or vague labels for the intervention groups (e.g., Group 1, Intervention A) we used a summary of their description of the group as a label. For a full description of the studies intervention components refer to Appendix E.

Abbreviations: 2nd = secondary outcome; cRCT = cluster randomized controlled trial; GP, general practitioners; N_c_, number of clusters; P = primary outcome.

One trial compared a reach strategy (mailed guidelines) with two multicomponent strategies that involved providing either education and academic detailing or education, academic detailing, and motivational counseling for patients.84 This cRCT examined functional capacity among patients with low back pain using 6- and 12-month followup assessments. The groups did not differ significantly on functional capacity at either followup.