# References

1 Helfand M, Tunis S, Whitlock EP, et al. (2011). A CTSA agenda to advance methods for comparative effectiveness research. Clin Transl Sci.
2 Greenhalgh T, Robert G, Macfarlane F, et al. (2004). Diffusion of innovations in service organizations: systematic review and recommendations. Milbank Q.
3 Office of Disease Prevention and Health Promotion, Office of the Assistant Secretary for Health. Health.gov.
4 Rabin BA, Brownson RC, Haire-Joshu D, et al. (2008). A glossary for dissemination and implementation research in health. J Public Health Manag Pract.
5 Brownson RC, Colditz GA, Proctor EK. (2012). Dissemination and Implementation Research in Health.
6 Lomas J. (1993). Diffusion, dissemination, and implementation: who should do what?. Ann N Y Acad Sci.
7 National Institutes of Health. (2007). Building the Science of Dissemination and Implementation in the Service of Public Health.
8 McGuire WJ. (1968). Personality and attitude change: an information processing theory. Greenwald AG, Brock TC, Ostrom TM, editors. Psychological Foundations of Attitudes.
9 Wyer RS. (1980). The acquisition and use of social knowledge: Basic postulates and representative research. Pers Soc Psychol Bull.
10 Petty RE, Cacioppo JT. (1986). The Elaboration Likelihood Model of persuasion. Berkowitz L, editor. Advances in experimental socialpsychology.
11 Noar SM, Benac CN, Harris MS. (2007). Does tailoring matter? Meta-analytic review of tailored print health behavior change interventions. Psychol Bull.
12 Lustria MLA, Noar SMC J, Van Stee SK, et al. A meta-analysis of web-delivered, tailored health behavior change interventions. J Health Commun.
13 Slater MD. (1995). Choosing segmentation strategies and methods for health communication. Maibach E, Parrot EL, editors. Designing health messages.
14 Noar SM, Palmgreen P, Chabot M, et al. (2009). A 10-year systematic review of HIV/AIDS mass communication campaigns: Have we made progress?. J Health Commun.
15 Hinyard LJ, Kreuter MW. (2007). Using narrative communication as a tool for health behavior change: A conceptual, theoretical, and empirical overview. Health Educ Behav.
16 Winterbottom A, Bekker HL, Conner M, et al. (2008). Does narrative information bias individual’s decision making? A systematic review. Soc Sci Med.
17 O’Keefe DJ, Jensen JD. (2007). The relative persuasiveness of gain-framed and loss-framed messages for encouraging disease prevention behaviors: a meta-analytic review. J Health Commun.
18 Latimer AE, Brawley LR, Bassett RL. (2010). A systematic review of three approaches for constructing physical activity messages: What messages work and what improvements are needed?. Int J Behav Nutr Phys Act.
19 Rimer BK, Kreuter MW. (2006). Advancing tailored health communication: A persuasion and message effects perspective. J Commun.
20 Hawkins RP, Kreuter M, Resnicow K, et al. (2008). Understanding tailoring in communicating about health. Health Educ Res.
21 Kreuter MW, Wray RJ. (2003). Tailored and targeted health communication: strategies for enhancing information relevance. Am J Health Behav.
22 Noar SM, Harrington NG, Aldrich RS. (2009). The role of message tailoring in the development of persuasive health communication messages. Communication Yearbook.
23 Slater MD, Buller DB, Waters E, et al. (2003). A test of conversational and testimonial messages versus didactic presentations of nutrition information. J Nutr Educ Behav.
24 Wise M, Han JY, Shaw B, et al. (2008). Effects of using online narrative and didactic information on healthcare participation for breast cancer patients. Patient Educ Couns.
25 O’Keefe DJ, Jensen JD. (2009). The relative persuasiveness of gain-framed and loss-framed messages for encouraging disease detection behaviors: A meta-analytic review. J Commun.
26 Tabak RG, Khoong EC, Chambers DA, et al. (2012). Bridging research and practice: models for dissemination and implementation research. Am J Prev Med.
27 Curry SJ. (2000). Organizational interventions to encourage guideline implementation. Chest.
28 Ellen ME, Lavis JN, Ouimet M, et al. (2011). Determining research knowledge infrastructure for healthcare systems: A qualitative study. Implement Sci.
29 Green LW, Orleans CT, Ottoson JM, et al. (2006). Inferring strategies for disseminating physical activity policies, programs, and practices from the successes of tobacco control. Am J Prev Med.
30 (2006). Nurse-led cardiac clinics for adults with coronary heart disease. Nurs Stand.
31 Bero LA, Grilli R, Grimshaw JM, et al. (1998). Closing the gap between research and practice: An overview of systematic reviews of interventions to promote the implementation of research findings. BMJ.
32 Grimshaw JM, Shirran L, Thomas R, et al. (2001). Changing provider behavior: an overview of systematic reviews of interventions. Med Care.
33 Majumdar SR, Soumerai SB. (2003). Why most interventions to improve physician prescribing do not seem to work. CMAJ.
34 Sales A, Smith J, Curran G, et al. (2006). Models, strategies, and tools. Theory in implementing evidence-based findings into health care practice. J Gen Intern Med.
35 Bernhardt JM, Mays D, Kreuter MW. (2011). Dissemination 2.0: closing the gap between knowledge and practice with new media and marketing. J Health Commun.
36 Han PK, Klein WM, Arora NK. (2011). Varieties of uncertainty in health care: a conceptual taxonomy. Med Decis Making.
37 Babrow AS, Kasch CR, Ford LA. (1998). The many meanings of uncertainty in illness: toward a systematic accounting. Health Commun.
38 Djulbegovic B. (2007). Articulating and responding to uncertainties in clinical research. J Med Philos.
39 Rowe WD. (1994). Understanding uncertainty. Risk Anal.
40 Mishel MH, Braden CJ. (1987). Uncertainty. A mediator between support and adjustment. West J Nurs Res.
41 Squiers LB, Holden DJ, Dolina SE, et al. (2011). The public’s response to the U.S. Preventive Services Task Force’s 2009 recommendations on mammography screening. Am J Prev Med.
42 Lipschitz R, Strauss O. (1997). Coping with uncertainty: a naturalistic decision-making analysis. Organ Behav Hum Decis Process.
43 Brashers DE. (2001). Communication and uncertainty management. J Commun.
44 McGettigan P, Sly K, O’Connell D, et al. (1999). The effects of information framing on the practices of physicians. J Gen Intern Med.
45 Edwards A, Elwyn G, Covey J, et al. (2001). Presenting risk information—a review of the effects of “framing” and other manipulations on patient outcomes. Journal of Health Communication.
46 Moxey A, O’Connell D, McGettigan P, et al. (2003). Describing treatment effects to patients. J Gen Intern Med.
47 Covey J. (2007). A meta-analysis of the effects of presenting treatment benefits in different formats. Medical decision making : an international journal of the Society for Medical Decision Making.
48 Visschers VH, Meertens RM, Passchier WW, et al. (2009). Probability information in risk communication: a review of the research literature. Risk Anal.
49 Cuite CL, Weinstein ND, Emmons K, et al. (2008). A test of numeric formats for communicating risk probabilities. Med Decis Making.
50 Woloshin S, Schwartz LM. (2011). Communicating data about the benefits and harms of treatment: a randomized trial. Ann Intern Med.
51 Garcia-Retamero R, Galesic M. (2009). Communicating treatment risk reduction to people with low numeracy skills: a cross-cultural comparison. Am J Public Health.
52 Politi MC, Han PK, Col NF. (2007). Communicating the uncertainty of harms and benefits of medical interventions. Med Decis Making.
53 Mishel MH, Braden CJ. (1988). Finding meaning: antecedents of uncertainty in illness. Nurs Res.
54 Tannert C, Elvers HD, Jandrig B. (2007). The ethics of uncertainty. In the light of possible dangers, research becomes a moral duty. EMBO Rep.
55 Fox RC. (1980). The evolution of medical uncertainty. Milbank Mem Fund Q.
56 Morgan MG, Henrion M. (1990). Uncertainty: A Guide to Dealing With Uncertainty in Quantitative Risk and Policy Analysis.
57 Walker VR. (1991). The siren songs of science: Toward a taxonomy of scientific uncertainty for decision makers. Connecticut Law Review.
58 Smithson M. (1993). Knowledge: creation, diffusion, utilization. Ignorance and Uncertainty.
59 Smithson M. (1990). Ignorance and disasters. International Journal of Mass Emergencies and Disasters.
60 Owens DK, Lohr KN, Atkins D, et al. (2011). Grading the strength of a body of evidence when comparing medical interventions.
61 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med.
62 Sawaya GF, Guirguis-Blake J, LeFevre M, et al. (2007). Update on the methods of the U.S. Preventive Services Task Force: estimating certainty and magnitude of net benefit. Ann Intern Med.
63 Agency for Healthcare Research and Quality. (2012). Effective Health Care: What Is the Effective Health Care Program.
64 Institute of Medicine. (2000). Initial priorities for comparative effectiveness research.
65 (2011). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
66 Kick EL, McKinney LA, McDonald S, et al. (2011). A Multiple-Network Analysis of the World System of Nations, 1995–1999. Scott J, Carrington P, editors. Sage Handbook of Social Network Analysis.
67 Moher D, Liberati A, Tetzlaff J, et al. (2009). Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol.
68 Viswanathan M, Berkman ND. (2012). Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol.
69 Higgins JPT, Altman DG. (2008). Assessing risk of bias in included studies. Cochrane Handbook for Systematic Reviews of Interventions.
70 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care program. J Clin Epidemiol.
71 Atkins D, Chang SM, Gartlehner G, et al. (2011). Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
72 Elder JP, Ayala GX, Campbell NR, et al. (2006). Long-term effects of a communication intervention for Spanish-dominant Latinas. Am J Prev Med.
73 Cox D, Cox AD. (2001). Communicating the consequences of early detection: the role of evidence and framing. J Market.
74 Schneider TR, Salovey P, Apanovitch AM, et al. (2001). The effects of message framing and ethnic targeting on mammography use among low-income women. Health Psychol.
75 Jibaja-Weiss ML, Volk RJ, Kingery P, et al. (2003). Tailored messages for breast and cervical cancer screening of low-income and minority women using medical records data. Patient Educ Couns.
76 Vernon SW, del Junco DJ, Tiro JA, et al. (2008). Promoting regular mammography screening II. Results from a randomized controlled trial in US women veterans. J Natl Cancer Inst.
77 del Junco DJ, Vernon SW, Coan SP, et al. (2008). Promoting regular mammography screening I. A systematic assessment of validity in a randomized trial. J Natl Cancer Inst.
78 Elder JP, Ayala GX, Campbell NR, et al. (2005). Interpersonal and print nutrition communication for a Spanish-dominant Latino population: Secretos de la Buena Vida. Health Psychol.
79 Yu N, Shen FY. (2013). Benefits for me or risks for others: a cross-culture investigation of the effects of message frames and cultural appeals. Health Commun.
80 Myers RE, Sifri R, Hyslop T, et al. (2007). A randomized controlled trial of the impact of targeted and tailored interventions on colorectal cancer screening. Cancer.
81 Markus H, Kitayama S. (1991). Culture and the self: Implications for cognition, emotion, and involvement. Psychol Rev.
82 Oyserman D, Coon HM, Kemmelmeier M. (2002). Rethinking individiualism and collectivism: Evaluation of theoretical assumptions and meta-analyses. Psychol Bull.
83 Bahrami M, Deery C, Clarkson JE, et al. (2004). Effectiveness of strategies to disseminate and implement clinical guidelines for the management of impacted and unerupted third molars in primary dental care, a cluster randomised controlled trial. Br Dent J.
84 Becker A, Leonhardt C, Kochen MM, et al. (2008). Effects of two guideline implementation strategies on patient outcomes in primary care: a cluster randomized controlled trial. Spine (Phila Pa 1976).
85 Bekkering GE, Hendriks HJ, van Tulder MW, et al. (2005). Effect on the process of care of an active strategy to implement clinical guidelines on physiotherapy for low back pain: a cluster randomised controlled trial. Qual Saf Health Care.
86 Bekkering GE, van Tulder MW, Hendriks EJ, et al. (2005). Implementation of clinical guidelines on physical therapy for patients with low back pain: randomized trial comparing patient outcomes after a standard and active implementation strategy. Phys Ther.
87 Bishop PB, Wing PC. (2006). Knowledge transfer in family physicians managing patients with acute low back pain: a prospective randomized control trial. Spine J.
88 Eaton CB, Parker DR, Borkan J, et al. (2011). Translating cholesterol guidelines into primary care practice: a multimodal cluster randomized trial. Ann Fam Med.
89 Feldstein A, Elmer PJ, Smith DH, et al. (2006). Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc.
90 Jousimaa J, Mäkelä M, Kunnamo I, et al. (2002). Primary care guidelines on consultation practices: the effectiveness of computerized versus paper-based versions. A cluster randomized controlled trial among newly qualified primary care physicians. Int J Technol Assess Health Care.
91 Kennedy ADM, Sculpher MJ, Coulter A, et al. (2003). A multicentre randomised controlled trial assessing the costs and benefits of using structured information and analysis of women’s preferences in the management of menorrhagia. Health Technol Assess.
92 Lien LF, Brown AJ, Ard JD, et al. (2007). Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension.
93 Young DR, Vollmer WM, King AC, et al. (2009). Can individuals meet multiple physical activity and dietary behavior goals?. Am J Health Behav.
94 Svetkey LP, Harsha DW, Vollmer WM, et al. (2003). Premier: A clinical trial of comprehensive lifestyle modification for blood pressure control: rationale, design and baseline characteristics. Ann Epidemiol.
95 Rebbeck T, Maher CG, Refshauge KM. (2006). Evaluating two implementation strategies for whiplash guidelines in physiotherapy: a cluster randomised trial. Aust J Physiother.
96 Simon SR, Majumdar SR, Prosser LA, et al. (2005). Group versus individual academic detailing to improve the use of antihypertensive medications in primary care: a cluster-randomized controlled trial. Am J Med.
97 Wolters R, Wensing M, Klomp M, et al. (2005). Effects of distance learning on clinical management of LUTS in primary care: a randomised trial. Patient Educ Couns.
98 Wright FC, Gagliardi AR, Law CH, et al. (2008). A randomized controlled trial to improve lymph node assessment in stage II colon cancer. Arch Surg.
99 Wetter DW, Mazas C, Daza P, et al. (2007). Reaching and treating Spanish-speaking smokers through the National Cancer Institute’s Cancer Information Service. A randomized controlled trial. Cancer.
100 Jain MK, Heyland D, Dhaliwal R, et al. (2006). Dissemination of the Canadian clinical practice guidelines for nutrition support: results of a cluster randomized controlled trial. Crit Care Med.
101 King AC, Friedman R, Marcus B, et al. (2007). Ongoing physical activity advice by humans versus computers: The Community Health Advice by Telephone (CHAT) trial. Health Psychol.
102 Beaulieu MD, Brophy J, Jacques A, et al. (2004). Drug treatment of stable angina pectoris and mass dissemination of therapeutic guidelines: a randomized controlled trial. QJM.
103 Campbell MK, James A, Hudson MA, et al. (2004). Improving multiple behaviors for colorectal cancer prevention among African American church members. Health Psychol.
104 Carney PA, Harwood BG, Greene MA, et al. (2005). Impact of a telephone counseling intervention on transitions in stage of change and adherence to interval mammography screening (United States). Cancer Causes Control.
105 Christakis DA, Zimmerman FJ, Rivara FP, et al. (2006). Improving pediatric prevention via the internet: a randomized, controlled trial. Pediatrics.
106 Davis J, Roberts R, Davidson DL, et al. (2004). Implementation strategies for a Scottish national epilepsy guideline in primary care: results of the Tayside Implementation of Guidelines in Epilepsy Randomized (TIGER) trial. Epilepsia.
107 Gattellari M, Ward JE. (2005). A community-based randomised controlled trial of three different educational resources for men about prostate cancer screening. Patient Educ Couns.
108 Hagmolen of ten Have W, van den Berg NJ, van der Palen J, et al. (2008). Implementation of an asthma guideline for the management of childhood asthma in general practice: a randomised controlled trial. Prim Care Respir J.
109 Junghans C, Feder G, Timmis AD, et al. (2007). Effect of patient-specific ratings vs conventional guidelines on investigation decisions in angina: Appropriateness of Referral and Investigation in Angina (ARIA) Trial. Arch Intern Med.
110 Laprise R, Thivierge R, Gosselin G, et al. (2009). Improved cardiovascular prevention using best CME practices: a randomized trial. J Contin Educ Health Prof.
111 Marcus BH, Napolitano MA, King AC, et al. (2007). Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychol.
112 Maxwell AE, Bastani R, Danao LL, et al. (2010). Results of a community-based randomized trial to increase colorectal cancer screening among Filipino Americans. Am J Public Health.
113 Murtaugh CM, Pezzin LE, McDonald MV, et al. (2005). Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res.
114 Paradis HA, Conn KM, Gewirtz JR, et al. (2011). Innovative delivery of newborn anticipatory guidance: a randomized, controlled trial incorporating media-based learning into primary care. Acad Pediatr.
115 Partin MR, Nelson D, Radosevich D, et al. (2004). Randomized trial examining the effect of two prostate cancer screening educational interventions on patient knowledge, preferences, and behaviors. J Gen Intern Med.
116 Rahme E, Choquette D, Beaulieu M, et al. (2005). Impact of a general practitioner educational intervention on osteoarthritis treatment in an elderly population. Am J Med.
117 Rimer BK, Halabi S, Sugg Skinner C, et al. (2001). The short-term impact of tailored mammography decision-making interventions. Patient Educ Couns.
118 Soler N, Ballester E, Martin A, et al. (2010). Changes in management of chronic obstructive pulmonary disease (COPD) in primary care: EMMEPOC study. Respir Med.
119 Sullivan MD, Gaster B, Russo J, et al. (2010). Randomized trial of web-based training about opioid therapy for chronic pain. Clin J Pain.
120 Watson MC, Bond CM, Grimshaw JM, et al. (2002). Educational strategies to promote evidence-based community pharmacy practice: a cluster randomized controlled trial (RCT). Fam Pract.
121 Banait G, Sibbald B, Thompson D, et al. (2003). Modifying dyspepsia management in primary care: a cluster randomised controlled trial of educational outreach compared with passive guideline dissemination. Br J Gen Pract.
122 Rycroft-Malone J, Seers K, Crichton N, et al. (2012). A pragmatic cluster randomised trial evaluating three implementation interventions. Implement Sci.
123 Schwartz LM, Woloshin S. (2011). Communicating uncertainties about prescription drugs to the public: a national randomized trial. Arch Intern Med.
124 Han PKJ, Klein WMP, Lehman T, et al. (2011). Communication of uncertainty regarding individualized cancer risk estimates: effects and influential factors. Med Decis Making.
125 Brewer NT, Richman AR, DeFrank JT, et al. (2012). Improving communication of breast cancer recurrence risk. Breast Cancer Res Treat.
126 Akl EA, Guyatt GH, Irani J, et al. (2012). “Might” or “suggest”? No wording approach was clearly superior in conveying the strength of recommendation. J Clin Epidemiol.
127 Perneger TV, Schiesari L, Cullati S, et al. (2011). Does information about risks and benefits improve the decision-making process in cancer screening—randomized study. Cancer Epidemiol.
128 Perneger TV, Cullati S, Schiesari L, et al. (2010). Impact of information about risks and benefits of cancer screening on intended participation. Eur J Cancer.
129 McCormack L, Treiman K, Bann C, et al. (2011). Translating medical evidence to promote informed health care decisions. Health Serv Res.
130 McCormack LA, Bann CM, Williams-Piehota P, et al. (2009). Communication message strategies for increasing knowledge about prostate cancer screening. J Cancer Educ.
131 Longman T, Turner RM, King M, et al. (2012). The effects of communicating uncertainty in quantitative health risk estimates. Patient Educ Couns.
132 Sheridan SL, Golin C, Bunton A, et al. (2012). Shared decision making for prostate cancer screening: the results of a combined analysis of two practice-based randomized controlled trials. BMC Med Inform Decis Mak.
133 Rothman A, Salovey P, Antone C, et al. (1993). The influence of message framing on intentions to perform health behaviors. J Exp Soc Psychol.
134 Rothman AJ, Salovey P. (1997). Shaping perceptions to motivate healthy behavior: the role of message framing. Psychol Bull.
135 Ryan GL, Skinner CS, Farrell D, et al. (2001). Examining the boundaries of tailoring: The utility of tailoring versus targeting mammography interventions for two distinct populations. Health Educ Res.
136 Vernon SW, Bartholomew LK, McQueen A, et al. (2011). A randomized controlled trial of a tailored interactive computer-delivered intervention to promote colorectal cancer screening: sometimes more is just the same. Ann Behav Med.
137 Rogers RW. (1983). Cognitive and physiological processes in fear appeals and attitude change: A revised theory of protection motivation. Cacioppo JT, Petty RE, editors. Social psychophysiology.
138 Rosenstock IM. (1974). Historical origins of the health belief model. Health Educ Monogr.
139 Rosenstock IM, Strecher VJ, Becker MH. (1988). Social learning theory and the Health Belief Model. Health Educ Q.
140 Bandura A. (1997). Self-efficacy: The exercise of control.
141 Fishbein M, Ajzen I. (2010). Predicting and changing behavior: The reasoned action approach.
142 Lazarus RS, Cohen JB. (1977). Environmental stress. Altman I, Wohlwill JF, editors. Human behavior and environment.
143 Prochaska JO. (1984). Systems of psychotherapy: A transactional analysis.
144 Kreuter MW, Green MC, Cappella JN, et al. (2007). Narrative communication in cancer prevention and control: a framework to guide research and application. Ann Behav Med.
145 West SL, Squiers LB, McCormack L, et al. Communicating Quantitative Risks and Benefits in Promotional Prescription Drug Labeling or Print Advertising.
146 Grimshaw G, Stanton A. (2006). Tobacco cessation interventions for young people. Cochrane Database of Systematic Reviews.
147 Lancaster T, Silagy C, Gray S, et al. (1998). The effectiveness of training health professional to provide smoking cessation interventions: systematic review of randomized controlled trials (Cochrane Review).
148 Lewis MA, DeVellis B, Sleath B. (2002). Interpersonal communication and social influence. Glanz K, Lewis FM, Rimer BK, editors. Health behavior and health education: Theory, research, and practice.
149 Heaney CA, Israel BA. (2008). Social networks and social support. Glanz K, Rimer BK, Viswanath K, editors. Health behavior and health education: Theory, research, and practice.
150 Powell BJ, McMillen JC, Proctor EK, et al. (2012). A compilation of strategies for implementing clinical innovations in health and mental health. Med Care Res Rev.
151 Bartholomew LK, Parcel GS, Kok G, et al. (2001). Intervention Mapping: Designing theory- and evidence-based health promotion programs.
152 Frambach RT, Schillewaert N. (2002). Organizational innovation adoption: A multi-level framework of determinants and opportunities for future research. J Bus Res.
153 Weiner BJ, Lewis MA, Clauser SB, et al. (2012). In search of synergy: strategies for combining interventions at multiple levels. J Natl Cancer Inst.
154 Green LW, Ottoson JM, Garcia C, et al. (2009). Diffusion theory and knowledge dissemination, utilization, and integration in public health. Annu Rev Public Health.
155 Mendel P, Meredith LS, Schoenbaum M, et al. (2008). Interventions in organizational and community context: A framework for building evidence on dissemination and implementation in health services research. Adm Policy Ment Health.
156 Wandersman A, Duffy J, Flaspohler P, et al. (2008). Bridging the gap between prevention research and practice: the interactive systems framework for dissemination and implementation. Am J Community Psychol.
157 Dearing JW, Maibach EW, Buller DB. (2006). A convergent diffusion and social marketing approach for disseminating proven approaches to physical activity promotion. Am J Prev Med.
158 Gagliardi AR, Brouwers MC, Palda VA, et al. (2011). How can we improve guideline use? A conceptual framework of implementability. Implement Sci.
159 McMullen CK, Ash JS, Sittig DF, et al. (2011). Rapid assessment of clinical information systems in the healthcare setting: an efficient method for time-pressed evaluation. Methods Inf Med.
160 McNall M, Foster-Fishman PG. (2007). Methods of rapid evaluation, assessment, and appraisal. Am J Eval.
161 Oxman AD, Thomson MA, Davis DA, et al. (1995). No magic bullets—a systematic review of 102 trials of interventions to improve professional practice. Can Med Assoc J.
162 Akl EA, Maroun N, Guyatt G, et al. (2007). Symbols were superior to numbers for presenting strength of recommendations to health care consumers: a randomized trial. J Clin Epidemiol.
163 Cuello Garcia CA, Pacheco Alvarado KP, Perez Gaxiola G. (2011). Grading recommendations in clinical practice guidelines: randomised experimental evaluation of four different systems. Arch Dis Child.
164 Shakespeare TP, Gebski V, Tang J, et al. (2008). Influence of the way results are presented on research interpretation and medical decision making: the PRIMER collaboration randomized studies. Med Decis Making.
165 Ibrekk H, Morgan MG. (1987). Graphical communication of uncertain quantities to nontechnical people. Risk Anal.
166 Kuhn KM, Budescu DV. (1996). The relative importance of probabilities, outcomes, and vagueness in hazard risk decisions. Organ Behav Hum Decis Process.
167 Kuhn KM, Budescu DV, Hershey JR, et al. (1999). Attribute tradeoffs in low probability/high consequence risks: The joint effects of dimension preference and vagueness. Risk Decision and Policy.
168 McAuliff BD, Kovera MB, Nunez G. (2009). Can jurors recognize missing control groups, confounds, and experimenter bias in psychological science?. Law Hum Behav.
169 Sheridan SL, Halpern DJ, Viera AJ, et al. (2011). Interventions for individuals with low health literacy: a systematic review. J Health Commun.
170 Balas EA, Boren SA. (2000). Managing Clinical Knowledge for Health Care Improvement. Bemmel J, McCray A, editors. Yearbook of Medical Informatics: patient-centered systems.
171 Glasgow R, Klesges L, Dzewaltowski D, et al. (2004). The future of health behavior change research: What is needed to improve translation of research into health promotion practice?. Ann Behav Med.
172 Kreuter MW, Bernhardt JM. (2009). Reframing the dissemination challenge: a marketing and distribution perspective. Am J Public Health.
173 Bowen DJ, Sorenson G, Weiner BJ, et al. (2009). Dissemination research in cancer control: where are we and where should we go?. Cancer Causes Control.
174 Timbie JW, Fox DS, Van Busum K, et al. (2012). Five reasons that many comparative effectiveness studies fail to change patient care and clinical practice. Health Aff (Millwood).
175 Avorn J, Fischer M. (2010). ‘Bench to behavior’: translating comparative effectiveness research into improved clinical practice. Health Aff (Millwood).