# Discussion

This report presented three separate, but topically related, systematic reviews. The overarching topic involves providing health-related evidence effectively to patients and clinicians. Specifically, we were asked to examine various strategies for communicating and disseminating evidence to these target audiences. As discussed more fully later, communication and dissemination lies on a continuum that ends with effective adoption and implementation. Finally, we were charged with exploring ways to explain uncertainty in evidence about preventive health and health care services.

Some of our findings are pertinent only to one Key Question (KQ); other findings can inform and provide context for two or all three KQs. In this final section of the report, we first discuss each Key Question individually in terms of principal findings, limitations and applicability, and future research. In the last part of this chapter, we discuss some issues that cut across all three KQs, noting where important synergies and differences arise, and end with implications.

## Key Question 1 Communication Strategies

### Key Findings and Strength of Evidence

We found seven unique randomized trials (RCTs) examining the effects of alternate communication strategies; these approaches entail tailoring messages to individuals, targeting messages to audience segments, using narratives to convey messages, and using framing to convey messages to various end-users. Overall, the strength of the evidence on communication strategies was poor. Specifically, the trial testing various approaches to framing against using narratives (i.e., anecdotal) or statistical evidence did not show long-term differences between groups, and evidence was insufficient for drawing any conclusions. Two trials comparing framing and targeting both showed that loss framed messages used in combination with targeting more broadly (i.e., either using a multicultural or collectivistic appeal) was more persuasive than other targeting approaches at least in the short term. Four trials tested targeting against tailoring messages (n=3) did not demonstrate that tailoring was superior to targeting when encouraging screening or changing diet and nutritional behaviors, (all received grades of low or insufficient strength of evidence).

### Findings in Relationship to What Is Already Known

Investigators used different strategies to convey evidence (frequently presented as risk and benefit information) to promote informed choices among study participants. The literature suggests that how information is presented can influence health related decisions.45 On their own, the four strategies we examined have been effective in impacting selected health related outcomes (see Introduction section). We are unable to determine at this time which, if any, of the four strategies are better than any other, or whether or not a particular combination of strategies is better than a single strategy. It may be most prudent to consider using multiple strategies since they are not mutually exclusive.

Nonetheless, our review revealed some intriguing insights about the potential comparative strengths of the four strategies that add to the existing literature. The preponderance of the literature on framing focuses on gain and loss framed messages. It supports that loss-framed messages are more effective than gain frame messages because detection behaviors are perceived as risky in the short term because of their ability to detect disease.133 Rothman and Salovey134 concluded that the effect of gain versus loss framing on health behavior was dependent on the function (prevention versus detection) of the behavior.134 The results of the three trials in our review that used loss framed prevention messages were consistent with the literature; they showed loss framed messages were more persuasive in terms of screening behavior, at least in the short-term (6 months). However, all three studies used framing in conjunction with another strategy (targeting and narratives).

The included KQ 1 trials chiefly involved targeting and tailoring strategies. Investigators hypothesized that tailored interventions would be more effective in promoting screening relative to targeted interventions because they are more personalized. We are aware of at least one study (that did not meet our criteria for evidence) that quantified the contribution of individual tailoring over groups targeting.135 Three trials directly compared the effectiveness of targeting to tailoring,75,78 but they produced either nonsignificant or counterintuitive findings. Another trial expected the combination of tailoring and targeting would be more effective than targeting alone,136 but this was not the case.

The communication strategies we examined are rooted in theory. Framing and targeting may influence beliefs about illness severity and likelihood, which are thought to motivate health behavior change.137,138 The Health Belief Model139 supports the notion that providing personalized risk information may increase a person’s perceived susceptibility of the disease and motivate their behavior. The belief that a person can undertake a behavior─self-efficacy─is a key variable in numerous health behavior theories137,139–143 and is frequently an important mediating variable. Two studies examined mediating variables directly. One study found that mediating variables were not influenced by the framing and targeting interaction.74 However, another study found that gain framed/self-focused and loss-framed/other-focused appeals promoted behavioral intention through changing people’s cognitive perceptions about screening and attitudes toward the behavior.79

Narrative communication has emerged a promising approach for cancer prevention and control.144 Only one trial used some form of narratives in an attempt to improve how effectively the risk and benefit information was conveyed. This study compared using a narrative (anecdotal) approach versus a (non-narrative/statistical) approach, but the investigators did not implement the study design or analyze the data in such a way to uniquely examine each component of the framing versus narratives aspect of the intervention. Instead, they focused on the message framing (gain versus loss). Nonetheless, the results suggest that the loss framed and narrative approach was more persuasive in promoting self-reported likelihood of screening in an immediate posttest. A recent review of the literature found that numeric information appears to improve understanding of risks and benefits relative to non-numeric presentation; presenting both numeric and non-numeric information when possible may be best practice.145

In general, few studies set out to examine the comparative effectiveness of these four communication strategies. The strategies are not necessarily substitutes for each other, but are complementary. Using more than one strategy at a time could be synergistic. Thus, one should consider whether looking at comparative effectiveness of two strategies is the most appropriate analytic approach.

### Mode of Communication

Most studies delivered the interventions via postal mail or in person. One trial augmented a targeted and tailored intervention by using lay health workers to communicate the information in the intervention to the target audience. In such an approach, communication and dissemination strategies were arguably comingled. Using individuals to help to communicate the messages also did not appear to make any difference in the main outcomes of this trial, even though interpersonal communication is generally viewed as the best approach for communication but also the most expensive.

Advances in technology have made it easier to tailor interventions based on information provided by an individual. Data for tailoring the interventions in the trials were derived from medical record data and from baseline surveys of study participants. Neither of these elements appeared to have any effects on the primary outcomes of interest.

### Limitations of the Evidence Base or the Review Process

The evidence base for addressing comparisons of communication strategies of interest was extremely sparse (i.e., only seven trials of direct comparisons). Perhaps most telling, four of trials addressed breast and cervical cancer screening interventions. The evidence basis for breast cancer screenings has changed in the recent past. As new evidence emerges in the media, such as modifying the target age group or recommended frequency of screening, the result can be confusion among patients41 and potential interference with the impact of interventions.41 In addition, one trial had the high baseline screening rates in the study population, so the intervention may have failed to have much of an impact because of a cancer screening ceiling effect.

Another trial addressed dietary recommendations. Modifying eating behaviors is notoriously difficult, as is measuring diet changes (e.g., calories from fat; dietary fiber levels). That this one trial (of moderate risk of bias) found no statistically significant effects may reflect these challenges.78

One major drawback to these trials is the disproportionate use of convenience samples. While randomizing a convenience sample increases the likelihood of equal distribution of characteristics, unmeasured confounding may exist because of selection bias with the sample. All of these trials studies used self-reported data, which can be subject to social desirability bias. For behaviors such as screening or dietary intake, this may pose another limitation.

Investigators did not control for a variety of potentially confounding variables, such as mode of communication (e.g., use of mailed materials), amount of content (e.g., one-page letter versus multicomponent intervention), or apply modeling techniques that might have clarified the impact (or lack of it) of such factors.

We used rigorous EPC procedures in addressing this KQ that increase the rigor and quality of the review: systematic searches of the literature, appropriate methods for rating quality of studies and grading strength of evidence, rigorous data abstraction techniques, and so forth. We also obtained consultation and input from a wide range of external experts in the field on the development and execution of the review. Despite these strengths, certain tradeoffs were necessary that limited the scope of the review. We emphasize that categorizing the trials proved challenging because the interventions in some cases seemed to be an amalgam of communication techniques. Per our protocol, we did not examine some communication strategies in which some stakeholders might have been interested, such as use of plain language, because we viewed this as a best practice.

### Applicability

Applicability can be addressed in terms of PICOTS—i.e., populations, interventions, comparators, outcomes, timeframes for followup, and settings. The generalizability of these findings is limited to the study populations in which they were undertaken. This was weighted toward adult women eligible for cancer screening (breast or cervical). No study was relevant to children or adolescents or to the elderly. Some of the trials clearly addressed an ethnic population group (Latinas). The interventions and comparators, as noted above under limitations, were also relatively narrowly conceived. Given the focus on presentation and screening, the outcomes are somewhat limited; followup was reasonably lengthy (e.g., 1 year in most cases), and the trials concern a mixture of settings—outpatient or community settings. The results of the trials may only be directly applicable to screening and dietary behavior and perhaps other communications where recommended behaviors are clearly supported by a body of evidence. We are unable to differentiate findings by socioeconomic and clinical characteristics of the study subjects.

### Research Gaps

Perhaps a critical step in future research is to reconsider the core communication strategies in light of these findings, theoretical models, research principles and methods, and other indications. The communication strategies were ostensibly evidence based—a crucial factor for selecting interventions or comparators. Much of the literature to date examines the four communication strategies that we studied relative to ‘usual care,’ as opposed to comparing them to each other. Future research should compare single strategies head to head and various combinations of strategies with each other. When doing so, investigators should clearly explain how they are defining the “usual care” and the control group arm if one is included. We found it difficult in some cases to determine what investigators considered ‘usual care’ and if or how this differed from the “standard of care.”

Investigators targeted and tailored the interventions based on different factors. Targeting is often done based on demographic factors such as age or gender, and sometimes based on culture. One study targeted their intervention to those who were not up-to-date with screening, which is a less common approach.80 Tailoring is done at the individual (versus group) level and can be based on a wide range of potential factors generally based on data provided by an individual. For example, interventions can be tailored based on perceived barriers to performing a behavior or other psychological variables. Given the limited literature base comparing the two strategies overall, there is also a sizable gap in comparing (and controlling for) the effectiveness of particular targeting and tailoring categories.

There was a notable gap in the use of information technology for communicating the information to patients or clinicians. While our analytic framework focused specifically on patients, we recognize that patients and consumers and not necessarily the same, although there is clearly an overlap between these two groups. The findings from this report should be considered in light of this differential and addressed in future research.

Future research should examine the effectiveness of communication strategies in different subpopulations. Similarly, as the U.S. population ages, research to highlight promising communication approaches for the elderly (including perhaps even persons 85 years of age and older) might be undertaken. Finally, how best to communicate health-related information to children (even quite young children, insofar as they are increasingly conversant with computer and web-based applications) and adolescents will also be important.

As noted above, all seven trials for KQ 1 focused on preventive health care issues. This might suggest that the body of literature from which these studies emerged is weighted toward preventive health. If so, future research should compare the effectiveness of different communication strategies beyond screening to other content areas. In particular, strategies for communicating evidence vary when a widely agreed upon clinical path exists versus when it does not. When consensus is lacking about what clinical intervention is best for either prevention or treatment, one should present both the potential benefits and harms of different options in a balanced manner. It can also be helpful to acknowledge the uncertainty as a context for explaining why more than one option exists. In many cases, shared decisionmaking is the action that message should convey along with the information about choices. This promotes making a decision based on individual values and preferences.

We applaud that fact that all the included trials except one were quite large (hundreds or thousands of subjects); this feature is important when only relatively small changes or differences between groups are expected. Four had followup assessments after the intervention of at least 1 year, which is an important factor in understanding the stability of changes, but the others were relatively short term. We would encourage efforts to measure effects over relatively long periods, especially for trials of communication about disease trajectories, self-management, and treatment to clarify whether the interventions produce lasting impacts

Nevertheless, we note as well that future research should be attentive to methods issues (e.g., study design, clarity surrounding the intervention, analytic and statistical methods). These trials reflect generally accepted methods in the health behavior and education fields, but in some ways they do not report the rigorous standards for health services and policy research. Trials may or may not have implemented these standards in research protocols, but they are not typically reported in the journals that commonly publish these studies. More attention to recruitment and sampling, broader examination of social, psychological and environmental variables that might explain the outcomes, and greater use of modeling techniques (e.g., multilevel modeling, path analyses) is recommended. Interdisciplinary research teams are likely to strengthen this line of research.

## Key Question 2 Dissemination Strategies

### Key Findings and Strength of Evidence

We had 38 studies, including cluster RCTs, that focused on evidence dissemination to either clinicians or patients (broadly defined) or to both. All used either “single” strategies focusing on increasing the reach, ability, or motivation for the target populations or a multicomponent approach with more than one such technique. The aim of these investigations was to enhance health-related decisions or behaviors, clinical outcomes, or knowledge.

Generally, the multicomponent intervention approaches had the best strength of evidence (moderate) relative to an intervention relying on a single method (such as a strategy related to increasing reach to clinicians or patients), and particular when used for changing clinician behavior. Multicomponent intervention approaches for clinicians related to clinical outcomes had low strength of evidence due to inconsistent findings across studies.

Evidence was inconsistent or not statistically significant for all other comparisons for clinicians and patients related to behaviors, clinical outcomes and knowledge resulting in insufficient strength of evidence judgment for most categories we compared. In addition, the strength of evidence was low or insufficient, often because only a single trial addressed a specific comparison.

We did not find any evidence that any particular single strategy directed at increasing ability or motivation was better than reach strategies. Although here again there were many single studies in these categories that influenced the strength of evidence ratings.

### Findings in Relationship to What Is Already Known

The findings about the positive impact of multicomponent dissemination efforts is consistent with earlier research and prior reviews showing that dissemination strategies that are passive or involve only a single component do not perform as well as more active, multicomponent approaches.32–34 Specifically, we found multicomponent strategies to be more effective than a single strategy for affecting clinicians’ behaviors, particularly guideline adherence which was one of the more common outcomes examined. Grimshaw and colleagues conducted the most comprehensive examination of dissemination interventions to date—an overview of systematic reviews—and it also focused on changing provider behavior.32 In particular, they concluded that multifaceted interventions were more successful when they targeted different barriers to change. Examples of barriers include access to care and the physical environment. Interventions that targeted awareness of these issues and behavior cues to serve as reminders were more promising. However, in subsequent systematic reviews of multifaceted interventions Grimshaw et al.146 concluded that the effectiveness of multifaceted interventions did not increase incrementally as the number of components increased. As with our included trials, they observed that studies did not provide an explicit rationale for why particular interventions, or combinations of components, should work. Our analysis of the multicomponent approaches was at a more macro level, and did not account for the exact number or type of components included. A finer grained analysis of the exact number or component type may have produced results consistent with Grimshaw et al.’s146 more recent systematic review.

Past research shows the effectiveness of patient-directed interventions decreased with the number of interventions used, whereas the effectiveness of provider-directed interventions increased when up to three interventions were used.147 The analysis of our included trials did not address this issue. We cannot conclude that specific dissemination tactics to providers or patients or the exact number in a multicomponent approach is more effective. However, it is likely that more intense multicomponent interventions, i.e., those using more than one additional component, likely were more successful, if they address the determinants of the dissemination problem and provide a clear rationale for why they should work.32

Thus, our review is consistent with many of the conclusions offered by Grimshaw and colleagues32,146 about strengthening the evidence base for comprehensive multicomponent interventions. Our work builds on their work by also suggesting that the finding applies to both primary and secondary outcomes.

None of the trials we examined deemed interventions that involved both patients and clinicians as more effective. However, only a limited number of studies examined this combined approach. Prior research indicated that interventions that targeted both professionals and patients were less successful, but interventions that targeted each of these groups individually were both effective.147 Dissemination studies that examine strategies involving multiple people, such as providers, patients or their family members, and examine the conditions under which dissemination is more successful in changing behavior, would advance this research area. If formative research shows that discussions and communication between patients and providers is an important determinant of the problem then interventions that address their mutual interdependence could work.148 However, if the determinants of the problem center on separate issues not central to their interactions and communication, then targeting each group individually may be effective as well.

As noted above, we categorized studies into the domains of reach, ability, and motivation. One might expect that dissemination strategies that explicitly seek to motivate the target audience to change their behavior would be more effective than those seeking mainly to distribute the information (see Heaney & Israel, 2008^2,149^ for review). However, our analysis did not support this conclusion due to insufficient evidence for many of these comparisons due to either a single study in a category, inconsistent findings across studies or non-significant findings. Systematic reviews that address these single strategies would help identify the benefit of these approaches.

### Limitations of the Evidence Base or the Review Procedures

Several conceptual and methodological limitations emerged from the literature about dissemination strategies, and some clouded the evidence base about communication as well. First, the significant heterogeneity in how the field references and classifies dissemination strategies continues to confound dissemination and implementation approaches.4 Authors of other recent reviews have also acknowledged the difficulty in identifying patterns across heterogeneous dissemination studies or data.26,150

Not surprisingly, then, the lack of consistency across investigator teams and studies hampered our efforts to classifying a strategy into one of our domain groupings. We had established these domains conceptually at the outset of the work, based on the literature, and with input from a group of technical expects; those domains specified goals of extending the reach, the ability, or the motivation for target populations for single strategies or reflected or multicomponent strategies (which might have had more than one such goal).

Second, a related drawback was that many studies, particularly clinically oriented trials, provided little theoretical or conceptual justification for the dissemination strategy employed or a hypothesis for why particular strategy was expected to be more effective than another. With no underlying framework, the investigators, and we, found null findings difficult to interpret and explain. For example, some studies found no effect but cited already high guideline adherence rates by clinicians as the explanation for the lack of impact of the tested dissemination strategy. Understanding why subgroups of clinicians, patients, or other end users, remain resistant to change may benefit from theoretical approaches that draw on social influence, organization theory, and systems science; that is, investigators in the future should (and can) develop stronger rationales underlying the choice of dissemination approaches.151–157

Third, studies often confounded the mode of distribution with other variables related to communication. Therefore, we could not tease apart the effect of mode, channel, and content of the intervention on the outcome of interest. As part of our analysis, we mapped each group in every trial to identify the number of components used for that group (single, more than one) and the mode of evidence distribution (e.g., postal mail, face-to-face, electronic, telephone); because the way the evidence was actually conveyed could have been the same or different from mode. For example, postal distribution of evidence could have involved sending a DVD, which was electronic transmission of information to the end user.

As noted previously, the overlap between mode of distribution and other elements of interventions blend communication (KQ 1) and dissemination (KQ 2) together. Evidence dissemination is a specialized form of communication. Future dissemination studies that pay attention to both general communication strategies like those we examined in KQ 1 and that address communication variables such as mode, channel and content will advance this area of research and practice.

Fourth, this body of evidence was quite heterogeneous. Across the included studies the health conditions examined included cardiovascular disease, cancer, pain, hypertension, among others. The types of behaviors targeted for change included adherence, smoking cessation, surgery, preventive screening, among others. In addition, we also included various types of clinical outcomes and knowledge. Even when investigators studied a similar issue, physical activity or quality of life for example, different measures were used. Moreover, the trials were also diverse with respect to target audience (clinicians, patients, or both). For clinicians, trials may have targeted primary care physicians, residents or nurses. Patients differed on multiple dimensions including the type of behavior change required, the health condition they were managing, and by other background factors such as sociodemographic factors.

To address this heterogeneous and complicated body of work, we classified the trials in broad terms. Nonetheless, this effort still left too few studies in some categories with which to make meaningful conclusions about the relative impact of a particular dissemination strategy. As explained in the results presented in Chapter 4, we could not pursue any quantitative (pooling) analyses, and we summarized results with text, rather than numbers in our summary tables as other investigators have done.148 (Data supporting our summary can be found in the evidence tables in Appendix E). Further, many times the mode of communication was confounded with other variables we examined which made it impossible to disentangle if a particular strategy was effective above and beyond the mode or channel used to send the information. Synthesis examining mode or agent did not change the pattern or results, likely due to the extensive non-significant findings across included studies.

Fifth, appropriate followup points, including length before final assessment of impact, is critical. Many studies used followup periods of six or 12 months. The most appropriate timing for followup should be investigated, and the typical followup period used in research protocols may not always be the best for testing dissemination hypotheses. Assessments made at an inappropriate time could fail to detect meaningful changes in the outcome of interest. In other words, if the evaluations were done prematurely, they could have underestimated the true effect size of the intervention. It is important to remember that behavior change is a process, not an event, and the evaluation measures should account for that by monitoring outcomes variables at multiple time points that are specific to the outcome of interest.

Finally, many studies did not consistently compare strategies directly to each other, but instead compared to a usual care or control condition or at times made direct comparisons for only some outcomes. This factor, which limited our ability to draw conclusions about the comparative effectiveness of one approach versus another, may be partially an artifact of the conceptual confusion discussed above.

With respect to drawbacks of our review procedures, as noted, we used the same stringent EPC procedures for this KQ on dissemination as noted for KQ 1. Per the agreed-upon protocol, we included a broad range of behaviors, clinical conditions, target populations, and dissemination strategies. The resulting heterogeneity in this evidence base actually reflects a commonly encountered attribute of dissemination research.26,150

We excluded trials that used strategies that crossed into “implementation research,” for example, strategies that related to the point of care, such as clinical reminders or changes in policies and practices that support evidence implementation. Many of our included studies measured outcomes that are closer to those found in implementation research, such as changes in clinical practice or clinical outcomes. These types of outcomes may have underestimated the impact of particular dissemination approaches, because they are conceptually more distal. We recognize that these studies can also inform what we know about the effectiveness of dissemination strategies because the two are integrally linked.

### Applicability

As noted above, applicability can be addressed in terms of PICOTS—i.e., populations, interventions, comparators, outcomes, timeframes for followup, and settings. The generalizability of these findings is limited to the study populations in which they were undertaken. This was chiefly health care clinicians given the larger number of studies focusing on this population. Studies addressed a variety of target populations: adults with chronic and acute illness, parents, and clinicians of various backgrounds or specialties. No included studies addressed children or adolescents. Few trials addressed an ethnic population group, although two specifically focused on Latinos. The interventions and comparators, as noted above under limitations, were also relatively narrowly conceived. Followup was reasonably lengthy, and the trials occurred in multiple setting types.

### Research Gaps

To advance dissemination science and practice, future research should address the limitations noted above. Studies should provide a theoretical rationale for strategies used, address and discuss potential confounding, conduct more fine-grained analyses of the determinants of the problem under study, and interpret the findings in greater context given the particular outcome under study. Future research should use a variety of methodologies, beyond RCT and cRCTs to examine dissemination and link dissemination and implementation more closely, and conduct formative dissemination research.154 These approaches will enhance the external validity of dissemination research.

To improve dissemination, the knowledge base needs to be expanded to incorporate new concepts and methods that will advance dissemination research and practice and link those efforts with emerging ideas in implementation science (as discussed later in this chapter).26,156,158 Despite the large number of dissemination studies we identified (certainly relative to communication studies), including previous systematic reviews in the field,2,31,32 much more needs to be learned about successful dissemination, adoption and implementation of evidence-based practices. More research, using rapid evaluation methodologies,159,160 would speed evidence generation on this topic and complement the bulk of research in this area that focuses on understanding long-term impacts and stability of those impacts. The lack of significant findings across so many included studies indicates a large disjuncture between an understanding of the dissemination problem, and the theoretical and operational approach to solving these problems. Using different methods and approaches could help bridge this disjuncture.

Specific research ideas worth pursuing include:

- What types of multicomponent approaches, or component combinations, are most effective? Do they affect prevention and treatment behaviors similarly? Does the clinical problem (e.g., cardiovascular disease, cancer, pain) or behavior required to implement the evidence (e.g., guideline adherence, discussions with patients, etc.) make a difference?
- What types of communication strategies (e.g., targeting, tailoring, and narratives) can be used in dissemination to clinicians?
- How can formative research be applied to enhance the development of dissemination interventions to enhance effectiveness?
- Can planning models, typically used in public health to develop interventions, also be used to increase the effectiveness of dissemination interventions?
- Do dissemination strategies work equally well in various underrepresented target populations?

The most successful strategy identified in this review was the use of a multicomponent dissemination approach for clinicians when trying to change their behaviors. Despite the heterogeneity of studies included in our review, this finding is consistent with other reviews showing the importance of a multicomponent approach. As was true in 1995 when Oxman and colleagues161 published their systematic review on improving professional practice, there is no “magic bullet” for dissemination of evidence. A multidisciplinary, multimethod approach, but one that harmonizes terminology and methods will advance dissemination research and practice.

## Key Question 3 Communication of Uncertainty

### Key Findings and Strength of Evidence

In our systematic review on uncertainty, we found nine unique studies that met our inclusion criteria and examined alternate ways to communicate the precision, directness, net benefit of evidence, and overall strength of recommendations. In general, evidence on communicating precision and overall strength of recommendations was insufficient. We found no studies examining the effects of alternate ways to communicate information about the overall strength of evidence, risk of bias, consistency, or applicability of evidence.

By contrast, studies examining ways to communicate directness and net benefit demonstrated that several interventions may be helpful in communicating concepts related to uncertainty and improving choices for appropriate care. These approaches include: (1) factual statements and advice (i.e., “ask for a drug that…”) to choose treatments with direct evidence about benefit (e.g., benefit on ultimate clinical outcomes such as heart attacks, rather than on intermediate outcomes such as cholesterol); and (2) factual statements and advice (i.e., “ask for a drug that…”) to choose treatments with a higher likelihood of net benefit (e.g., interventions with longer safety records).

In addition, evidence also suggests that increasing the amount of information presented about the harms of testing affects the choices for testing patients might make. Conversely, increasing the amount of information about benefits has no effect on test choices.

### Findings in Relationship to What Is Already Known

Our report is the first systematic review about communicating uncertainty inherent in health-related and health care evidence. Although conceptual reviews on communicating uncertainty exist,52 they focus predominantly on communicating precision and stochastic uncertainty, rather than on concepts specifically related to uncertainty related to judging the quality of evidence. Thus, our review provides the most comprehensive examination of this issue to date.

Specifically, our findings constitute the only rigorous information available about communicating uncertainty related to the quality of scientific evidence to audiences other than those who are technically very sophisticated about the elements of assembling and synthesizing data. Although our goal was to examine uncertainty as it might be communicated in reports by evidence developers, several of our findings may be relevant to communication of information about scientific evidence as it happens in the clinical encounter. Additionally, these results are likely broadly applicable across a host of effective and preference sensitive conditions.

Other articles that did not meet our inclusion criteria162–168 may be of interest to some working in this area; however, results should be viewed cautiously due to their higher potential for bias and/or lower applicability to targeted end-users for this review.

### Limitations in the Evidence Base and Review Procedures

Limitations in the uncertainty literature are evident primarily from the lack of studies that directly test alternate ways to communicate the uncertainty concepts that are relevant to evidence about health and health care. Few studies addressed any type of uncertainty of interest and none examined ways to communicate risk of bias, consistency across studies, or applicability. Further, few alternate communication strategies were tested. Most studies focused on comparing various non-numeric or numeric presentations of uncertainty. Few tested visual presentations or framed presentations and none examined tailored, targeted, or narrative presentations of uncertainty. Additionally only one study (focused on strength of evidence) tested the effects of uncertainty presentations on providers; the vast majority of studies were conducted in patients or community dwelling adults.

To date, the literature has no well-accepted framework defining the important types of uncertainty related to medical evidence or defining the strategies most likely to be effective in communicating about these types of uncertainty. In this review, we have developed a preliminary framework, but this should be vetted by the field.

Further, it is likely that more conceptual work needs to be done to deepen the framework that we developed. For instance, although several studies in our review examined alternate presentations of precision, none examined how presenting precision for both benefits and harms might affect health and medical care. Deepening and centralizing conceptualizations how uncertainty affects use of medical evidence is likely to be quite important.

### Applicability

As noted, this evidence has nothing to say about effective ways to communicate uncertainty related to risk of bias assessments, consistency of evidence across studies, or the applicability of evidence itself. Further, evidence regarding communicating uncertainty related to overall strength of evidence and precision was graded as insufficient, making broad application of such evidence premature.

The applicability of evidence for communicating uncertainty about directness and net benefit, which have stronger evidence, is reviewed below. The applicability of evidence regarding using factual statements and advice (i.e., “ask for a drug that…”) to communicate uncertainty related to directness and overall net benefit is fairly broad given that evidence was derived from large population based studies and effects would not be expected to change across various clinical conditions for prevention and treatment. The applicability of evidence about communicating various numbers of harms and benefits and about presenting net benefit in the context of other more beneficial services should be applied with more caution. Although the evidence is from large population based studies, the specific harms and services communicated may affect outcomes and alter the results when the same interventions are applied in different clinical settings.

### Research Gaps

Future studies should address the full spectrum of types of uncertainty related to communicating evidence about health care options. For instance, studies should test a wider variety of possible presentations for strength of recommendations; the effects of many current strength of evidence grading schemes have not been tested. Studies should also target other components of uncertainty. Given the lack of any evidence on overall strength of evidence, risk of bias, consistency of evidence, and applicability of evidence, studies in these areas are greatly needed. Additional studies are also needed to test a wider spectrum of ways to communicate precision, directness, and net benefit. Studies of precision should pay particular attention to the effects of presentations of precision for both benefits and harms of interventions, preventive services, and treatment options. Studies of directness should explore how to communicate about indirect patient centered outcomes as well as the more traditional indirect risk factor outcomes. Further, studies of net benefit should pay particular attention to how the number and types of harms used to determine net benefit may affect decisions, to how clinical context affects decisions, and to whether evidence users are using rational or affective decisionmaking to decide about acceptance of therapy.

Future work should also strive to use a consistent taxonomy of uncertainty to provide the opportunity for meta-analysis of trials. Work should also strive to use large randomized comparisons of uncertainty presentations to minimize confounding and optimize the precision of findings and for testing of a variety of outcomes ranging from knowledge and accuracy of risk perception to guideline concordant decisions, end-user satisfaction, and trust in the evidence. Testing uncertainty presentations in nationally representative samples or, at the very least, diverse samples will also be critically important given prior work showing differential understanding of information in low- and high-literacy populations.169 More studies also need to be done in provider samples to examine whether effects or differential for patients and providers.

## Evidence in the Broader Context

Many aspects of this review cut across more than one KQ, and some across all three KQs. One aspect of this entire review involves the continuum of generating evidence, synthesizing it, communicating and disseminating findings, and implementing new or revamped practices predicated on those findings. This is a critical conceptual issue. We encountered similarities and differences in the types of comparisons and findings across KQs. Of particular concern are methods issues that reflect recurring gaps and deficiencies in the body of research. Finally, we see certain commonalities in implications for future research and ramifications for clinicians, patients, and other stakeholders and end users.

Below we set findings from our research into the broader context of evidence translation and highlight key cross-cutting issues that might advance the field. We also discuss limitations of our own review that should be considered in interpreting our results.

### Conceptual Issues

#### Communication, Dissemination, and Implementation of Evidence

The types of studies and their findings in this synthesis of the literature are best evaluated within a broader context of activities moving from creating interventions, testing them, translating results, and adopting appropriate practices. In health care, this process has been noted as imposing a 17-year period of uptake of proven interventions into routine practice.170 Experts in the dissemination and implementation science community aim to shorten that period drastically so that health care providers, patients, families, caregivers, communities and healthcare settings are equipped with empirically-supported strategies to integrate scientific knowledge and effective interventions into everyday use. Bernhardt and colleagues35 lay out the range of basic steps along a spectrum of knowledge creation and use, beginning with the completion of scientific studies to the implementation and maintenance of evidence in practice.35 Although they focus on Web 2.0 strategies, the key elements are relevant for our more narrow topics and help to illustrate some of the limitations we detected in our evidence base.

In the context of our review, we view the evidence as moving along a continuum beginning with its collection and systematic review followed by communicating and translating it for audiences as needed (see Figure 3). The communication and translation process is often comingled with the diffusion (passive spread) and dissemination (active spread) of the information. Our review included only the second and third phases in the evidence continuum. To be included in our review, studies had to use evidence that met certain criteria for reliability and validity. This requirement increased the quality of the evidence we studied, but it resulted in excluding some studies that may have used effective strategies. However, only a small number of studies were excluded because they did not meet our criteria for evidence. Given the scope of our review, we also excluded studies that examined the adoption and implementation phase of the continuum as well as the process of promoting sustainability.

Figure 3 Evidence continuum in implementation science

This figure is titled, The Evidence Continuum in Implementation Science and shows the evidence as moving along a continuum beginning with its collection and systematic review followed by communicating and translating it for audiences as needed. There are five boxes on the continuum, with the first box on the far left labeled as “Collect and Systematically Review the Evidence” with an arrow pointing to the next box to the right which is labeled as “Communicate and Translate”. An arrow points to the right from that box to the next box on the right which says “Diffuse and Disseminate,” and an arrow points from that box to the next box on the right which says “Adopt and Implement.” The arrow from that box points to the right and the final box which says “Sustain, Evaluate Impact and Adjust.”

Each phase in the evidence continuum is unique and essential for evidence to have an impact on public health and health care. Similarly, Lomas argues that “diffusion, dissemination, and implementation are not interchangeable terms: they are phases in a process of increasingly active and more focused intents, with each subsequent phase dependent on the success of its predecessor phase.”6 Researchers, funders, policy makers and the media should keep this full continuum in mind when designing, executing, reviewing, and publishing studies. We cannot be certain that interventions shown to efficacious in a single trial will be effective in real world settings. More emphasis should be placed on conducting comprehensive and longer-term studies that bear all of the phases in mind. Glasgow and colleagues171 argue that to close the gap between research findings and the application of findings, we also need to balance internal and external study design considerations. With respect to our review, for example, we found that multicomponent dissemination strategies were generally more effective than single strategies. But, investing in a multicomponent intervention can be resource intensive. Is it reasonable to assume that resources are available for disseminating and implementing multifaceted strategies?

Some trials seemed to conflate communication and dissemination, perhaps not surprisingly given how difficult cleanly defining these concepts can be. Several other trials also seemed to mix or merge dissemination with implementation. This conceptual overlap complicated our analysis in at least two stages: creating meaningful classifications of strategies reported in the literature and examining appropriate relevant outcomes for those strategies.

Better specifying the communication or dissemination process under examination and measuring the most relevant outcomes for that process, and at the relevant followup points, will more clearly illuminate the impact of different communication or dissemination strategies. Kreuter and Bernhardt make the same point about the need to reframe the concept of, and the research on, dissemination in particular.172 Studies that refine the type and intervention level and the target of the intervention would also advance this field.

Clearly, as argued also by Green et al.,154 dissemination is not an end in and of itself154 and we note that neither is communication. Even if research on these topics bears in mind the full evidence continuum, it needs to be informed by how recipients (or other stakeholders) might view, or use, such materials and knowledge.2 For example, we expect that interventions that communicate and disseminate evidence would be used as part of a dynamic decisionmaking process that occurs when patients and clinicians discuss and make decisions. The relationship between these individuals would undoubtedly influence the process.

Some studies indicated that the investigators had conducted formative work with their target audiences (e.g., patients and consumers, clinicians and other providers, or purchasers and payers); the primary goal was often to identify potential adoptee preferences, values, and needs for evidence. Many research teams did not do this, however. Instead, researchers relied on prior evidence of efficacy for a particular intervention component, especially when it had been “proven” in a similar setting. For example, investigators testing dissemination strategies often used reminders for clinicians about using evidence or following practice guidelines without taking into account whether the potential adoptees had expressed any need for a reminder to do so. Had investigators checked with members of such a target audience, they might have learned that potential adoptees had reasons for ignoring evidence or guidelines, such as perceptions of low credibility or clinical relevance.173 Armed with such insights, the investigators might have elected to design a different study.

End users of information need to be included in identifying data, findings, and implications to be communicated—i.e., to understand the relevance and usability of such information.174 Similarly, end users should be involved in developing and testing the evidence product(s) to be communicated, translated, disseminated. Such inclusive practices can help to make the product or information more usable, relevant, and meaningful. Incorporating such stakeholders, specifically including patients or consumers, into future research efforts will require pursuing more participatory research methodologies than has typically been done in the past. This includes involving clinicians in the research process as well given that the format and content of evidence may influence its acceptability and use, and specific content may support shared decisionmaking practices.158

#### Definitions of Concepts and Terms

An important conceptual concern in advancing the science of communicating and disseminating evidence involves definitions of key concepts and terms. As noted in the Introduction to our report, consensus is lacking regarding definitions of key terms pertinent to this review and the research efforts more generally. We saw this lack of consensus across studies especially for definitions of three key terms: dissemination, adoption, and implementation.

For our work, we adopted or adapted definitions used by the U.S. Department of Health and Human Services, particularly the National Institutes of Health, and the health communications literature more generally. Although these definitions differed from each other in minor respects, they were both authoritative and similar enough that we could apply them to frame our inclusion and exclusion criteria, organize our results, and summarize our findings. Greater unity in the field in terms of concepts and terms would be beneficial.

Increasingly, also, investigators in this field are adopting more advanced experimental designs and analytic methods found more commonly today in the health services research and other arenas. Moreover, reflecting this step, research on communication and dissemination is becoming more multidisciplinary. These are very recent advances, however, and our literature went back well beyond recent years.

#### Use of Theoretical Frameworks and Models

Another important issue for the field is the use of theoretical frameworks. Many studies (but not all) lacked any apparent theoretical or conceptual framework to inform or organize the research questions and focus interventions on essential processes of behavioral and systems change. Although theories and frameworks are distinct concepts, we refer to them collectively, here, as models.26

We found it difficult in most studies to determine how investigators used model(s) (if at all) to guide development of their intervention. For example, models did not seem to inform which constructs the researchers chose to frame the intervention, why they chose the constructs they chose, and how they defined those constructions; similarly researchers did not seem to apply models to make predictions about the results of future observations or to interpret study results. Among the trials that did use models, KQ 1 studies made greater use of them than did studies for KQ 2. KQ 1 most frequently used health behavior change models. KQ 3 studies were mostly atheoretical.

Existing models had not, of course, been developed to frame research of head-to-head comparisons of communication and dissemination strategies.173 As a result, investigators sometimes used multiple models, adapting and integrating various components of these models to their particular research questions, settings, intervention design, or intended audiences. These adaptations complicated our efforts to define intervention elements consistently, assure construct validity, and either estimate or accurately measure expected intervention accomplishments and impact, and ultimately to synthesize findings across studies. Adaptations of models can also be barriers to follow-on studies needed to replicate findings, and thus strengthen the body of evidence.

### Methodological Considerations Regarding Our Review

In helping readers interpret findings in this report, we must acknowledge the limitations of our own work. Although our review used a well-defined systematic review approach and inputs from key experts, several issues bear mention. Below we highlight issues of which we think readers should be aware.

First, we based our conclusions on findings from RCTs published in peer-reviewed journals for KQ 1 and KQ 2 and on RCTs plus quasi-experimental and nonrandomized trials for KQ 3. We did not consider other sources of information. For instance, the focus on mainly experimental studies necessarily eliminated information from case studies, reports of “exemplar” programs and projects, anecdotal evidence, practice-based (observational) evidence, and consensus expert opinion. Findings from practice-based initiatives and evaluations of various kinds of programs and projects are frequently of other study designs.

Second, we identified only 58 studies that directly (i.e., head-to-head) compared strategies to communicate and disseminate evidence about evidence. Although we searched multiple medical database using MESH headings and keywords cited by known relevant studies, it is possible that we missed relevant studies that were indexed differently in or in different databases. Given the limited number of direct comparisons, we elected to include studies as long as they had two or more active arms (i.e., study groups). We excluded studies that compared a specific strategy with usual practice alone. However, some studies had multiple arms including a usual practice arm and could have still been included. For example, one KQ 1 study had a usual practice arm that was an active comparator (targeting), and many KQ 2 studies had a usual practice arm that was an active comparator (e.g., dissemination by mail).

Third, we struggled with what investigators defined as “evidence” to communicate or disseminate. In this review, we excluded studies that disseminated evidence from unknown sources, single studies, or multiple sources of evidence not collected into guidelines, systematic reviews or meta-analyses because we felt they did not reliably represent our intent to study communication and dissemination of evidence-based information. We adopted a policy of including “research-based evidence,” which we defined as evidence that various types of authoritative groups (i.e., evidence developers) have assembled, reviewed, and presented and which has been used to make recommendations. Applying this definition allowed us to clearly circumscribe a body of evidence about which we could draw conclusions; however, it may have excluded articles that some fields believe could have been important in answering our Key Questions.

Fourth, we included a broad range of target populations, interventions (communication or dissemination strategies), outcomes and behaviors, and other variables such as clinical conditions in our work. In short, we cast a “wide net,” while attempting to focus clearly on comparative effectiveness. As is clear in the results chapters, this heterogeneity in populations, strategies (interventions and comparators), outcomes and methodologies proved to be especially challenging.

Within the RCTs included for KQ 1 and KQ 2, we found wide variation in the specification of sampling schema, dependent and independent variables, both intermediate and primary outcomes, measurement methods for those outcomes, statistical analyses, and reports of data and findings.

KQ 3 studies included more experimental manipulations of different ways of presenting information, especially to lay audiences. This approach is more common in risk communication, the field from which the some of the studies were drawn.

Finally, a mismatch between study design and necessary methodology may partly explain why many of our included studies showed little or no effect of specific intervention strategies. Many of the studies only employed descriptive statistics and did not capitalize on more recent methodological advances (e.g., multilevel modeling) that could have improved their analytic approach. Other studies did not factor in potentially important moderating variables such as self-efficacy and health literacy. As a result of these “negative” findings, we identified few generalizable, efficacious or effective, stand-alone strategies for any of the KQs.

Fifth, a key step in rigorous systematic reviews is assessing the risk of bias (or quality) of individual studies. We adapted our risk of bias assessment from two widely used grading schemes, although the assessment itself wasn’t independently validated. Nonetheless, it covers key domains of selection bias, measurement bias, confounding, power, and reporting issues.

Finally, there is the possibility of publication bias. We did not formally assess publication bias. There were too few studies in any category of strength of evidence to make such assessments meaningful.

### Future Research

We have addressed specific research needs for each KQ above. The overall conclusion is that, henceforth, research teams should try to address both the conceptual and the study limitations noted both in sections addressing each Key Question and here above. This includes: (a) relying more on accepted theoretical constructs and models when designing interventions and studies, (b) conducting some prior needs assessments with target audiences, focusing on audience subgroups with greatest needs, (c) designing robust trials or observational studies, (d) using an array of proven data collection methods that can include, but might go beyond, self-reported attitudes, levels of knowledge, and behaviors; (e) describing and defending choices of intermediate and ultimate outcomes; (f) applying modeling or other advanced statistical and analytic techniques to account for confounders, interactions, and similar complications in data, and addressing temporal aspects of outcomes, and (g) thoroughly describing all aspects of study design and conduct, especially for interventions.

### Implications for Patients, Clinicians, and Policymakers

Clinicians and policy makers are in unique positions to use effective communication and dissemination strategies to promote and accelerate the adoption of the evidence base for improving health and healthcare. In many studies, clinicians and policymakers are also members of the intended audience for communication and dissemination strategies designed to alert them to evidence necessitating change in clinical practice and policies guiding it. This review sought to identify effective strategies for communicating and disseminating evidence so that patients and caregivers, practicing clinicians, relevant professional and consumer organizations, purchasers of health care, and others can understand and choose whether to use available evidence as a guide for their clinical practice and policy choices.

Our findings offer some guidance for clinicians and policymakers as to the most effective strategies for communicating and disseminating evidence, but leave many questions unanswered. For example, we found, consistent with other reviews that multicomponent strategies addressing a combination of reach, ability, or motivation appear to be more effective than one strategy alone for affecting change in clinicians’ behaviors, and particularly clinician guideline adherence (KQ 2). Our findings offered us no or insufficient evidence, however to determine the comparative effectiveness of each dissemination strategy within a multicomponent strategy. We also found different combinations of strategies with intended audience(s) and setting(s), and few head-to-head comparisons of single strategies, further limiting our ability to recommend a specific strategy or policy for a specific target audience and/or setting.

While clinicians and policymakers may use our findings to guide choice of a specific communication and/or dissemination strategy, they should also carefully consider other factors shown to affect awareness, adoption and use of evidence in various settings and by individuals working in or receiving services in those settings. For example, evidence use by individual clinicians or an organization is dependent on factors such as the definition and source of evidence, the methods used to construct evidence, ways intended audience members use and retain information, characteristics and expressed needs of the intended audience(s), and organizational as well as individual constraints and enablers specific to various settings. Clinicians and policy makers should gather and use information on these and other factors relevant to their situation or setting as they consider adoption and use of specific communication and dissemination strategies to guide patient-centered care and/or develop and implement systems-level policy.

Patient-centered communication is essential to the provision of patient-centered care and especially so in the face of uncertain evidence about treatment options.39 We examined the impact of strategies to communicate uncertain evidence including approaches to communicating strength of evidence, precision and directness of risk estimates, and net benefit. Our findings show no consistent impact of these strategies on changing patient outcomes such as knowledge, perceived risk, accuracy of perceived risk, appropriate choices regarding care (e.g., selecting medications; obtaining screening), and decision satisfaction. As clinicians decide how to communicate evidence to their patients, they should consider multifaceted, multidirectional sharing of information between themselves and their patients that takes into account health literacy, cultural and other factors affecting an individual patient’s ability to process and retain information, and use it to make an informed decision. This interaction also hinges on individual clinician knowledge of evidence, organizational policies and standard protocols, and resources available to both the clinician and patient.

The lack of research evidence to inform communication and dissemination of evidence, including uncertain evidence impedes timely clinician, patient and policymaker awareness, uptake and use of evidence to improve the quality of care. Expanding investment in communication and dissemination research is critical to the identification of strategies to accelerate the translation of comparative effectiveness research into community and clinical practice and the direct benefit of patient care.

More research is needed to better understand the current barriers to translating the findings of comparative effectiveness research into community and clinical practice.175 Ongoing funding for interdisciplinary communication and dissemination sciences research is needed to promote the uptake and use of evidence and ensure quality of care.

### Conclusions

In closing, this was the first systematic review that attempted to compare the effectiveness of communication strategies and to look at communicating uncertainty. Finding the appropriate “comparative” studies was challenging. The number of eligible studies was more limited for KQ 1 and KQ 3, but more substantial for KQ 2. Nonetheless, the review provides a helpful foundation in setting the research agenda to address key gaps in the literature.