# Appendix G Evidence Tables for Key Question 3

Table G-1 Key Question 3 study design details

Table G-2 Key Question 3 sample characteristics, part 1

Table G-3 Key Question 3 sample characteristics, part 2

Table G-4 Key Question 3 intervention descriptions

Table G-5 Key Question 3, first outcome

Table G-6 Key Question 3, second outcome

Table G-7 Key Question 3, third outcome

Table G-8 Key Question 3, fourth outcome

Table G-9 Key Question 3, fifth outcome

## References

1 Akl EA, Guyatt GH, Irani J, et al. (2012). “Might” or “suggest”? No wording approach was clearly superior in conveying the strength of recommendation. J Clin Epidemiol.
2 Brewer NT, Richman AR, DeFrank JT, et al. (2012). Improving communication of breast cancer recurrence risk. Breast Cancer Res Treat.
3 Han PKJ, Klein WMP, Lehman T, et al. (2011). Communication of uncertainty regarding individualized cancer risk estimates: effects and influential factors. Med Decis Making.
4 Longman T, Turner RM, King M, et al. (2012). The effects of communicating uncertainty in quantitative health risk estimates. Patient Educ Couns.
5 McCormack L, Treiman K, Bann C, et al. (2011). Translating medical evidence to promote informed health care decisions. Health Serv Res.
6 Perneger TV, Cullati S, Schiesari L, et al. (2010). Impact of information about risks and benefits of cancer screening on intended participation. Eur J Cancer.
7 Perneger TV, Schiesari L, Cullati S, et al. (2011). Does information about risks and benefits improve the decision-making process in cancer screening - randomized study. Cancer Epidemiol.
8 Schwartz LM, Woloshin S. (2011). Communicating uncertainties about prescription drugs to the public: a national randomized trial. Arch Intern Med.
9 Sheridan SL, Golin C, Bunton A, et al. (2012). Shared decision making for prostate cancer screening: the results of a combined analysis of two practice-based randomized controlled trials. BMC Med Inform Decis Mak.