# Appendix F Evidence Tables for Key Question 2

Table F-1 Key Question 2 study design details

Table F-2 Key Question 2 sample characteristics, part 1

Table F-3 Key Question 2 sample characteristics, part 2

Table F-4 Key Question 2 intervention descriptions

Table F-5 Key Question 2 studies, first outcome

Table F-6 Key Question 2 studies with a second outcome

Table F-7 Key Question 2 studies with a third outcome

Table F-8 Key Question 2 studies with a fourth outcome

Table F-9 Key Question 2 studies with a fifth or sixth outcome

Table F-10 Key Question 2, other analysis information

## References

1 Bahrami M, Deery C, Clarkson JE, et al. (2004). Effectiveness of strategies to disseminate and implement clinical guidelines for the management of impacted and unerupted third molars in primary dental care, a cluster randomised controlled trial. Br Dent J.
2 Banait G, Sibbald B, Thompson D, et al. (2003). Modifying dyspepsia management in primary care: a cluster randomised controlled trial of educational outreach compared with passive guideline dissemination. Br J Gen Pract.
3 Beaulieu MD, Brophy J, Jacques A, et al. (2004). Drug treatment of stable angina pectoris and mass dissemination of therapeutic guidelines: a randomized controlled trial. QJM.
4 Becker A, Leonhardt C, Kochen MM, et al. (2008). Effects of two guideline implementation strategies on patient outcomes in primary care: a cluster randomized controlled trial. Spine (Phila Pa 1976).
5 Bekkering GE, Hendriks HJ, van Tulder MW, et al. (2005). Effect on the process of care of an active strategy to implement clinical guidelines on physiotherapy for low back pain: a cluster randomised controlled trial. Qual Saf Health Care.
6 Bekkering GE, van Tulder MW, Hendriks EJ, et al. (2005). Implementation of clinical guidelines on physical therapy for patients with low back pain: randomized trial comparing patient outcomes after a standard and active implementation strategy. Phys Ther.
7 Campbell MK, James A, Hudson MA, et al. (2004). Improving multiple behaviors for colorectal cancer prevention among African American church members. Health Psychol.
8 Carney PA, Harwood BG, Greene MA, et al. (2005). Impact of a telephone counseling intervention on transitions in stage of change and adherence to interval mammography screening (United States). Cancer Causes Control.
9 Christakis DA, Zimmerman FJ, Rivara FP, et al. (2006). Improving pediatric prevention via the internet: a randomized, controlled trial. Pediatrics.
10 Davis J, Roberts R, Davidson DL, et al. (2004). Implementation strategies for a Scottish national epilepsy guideline in primary care: results of the Tayside Implementation of Guidelines in Epilepsy Randomized (TIGER) trial. Epilepsia.
11 Eaton CB, Parker DR, Borkan J, et al. (2011). Translating cholesterol guidelines into primary care practice: a multimodal cluster randomized trial. Ann Fam Med.
12 Elder JP, Ayala GX, Campbell NR, et al. (2005). Interpersonal and print nutrition communication for a Spanish-dominant Latino population: Secretos de la Buena Vida. Health Psychol.
13 Feldstein A, Elmer PJ, Smith DH, et al. (2006). Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc.
14 Gattellari M, Ward JE. (2005). A community-based randomised controlled trial of three different educational resources for men about prostate cancer screening. Patient Educ Couns.
15 Hagmolen of ten Have W, van den Berg NJ, van der Palen J, et al. (2008). Implementation of an asthma guideline for the management of childhood asthma in general practice: a randomised controlled trial. Prim Care Respir J.
16 Jain MK, Heyland D, Dhaliwal R, et al. (2006). Dissemination of the Canadian clinical practice guidelines for nutrition support: results of a cluster randomized controlled trial. Crit Care Med.
17 Jousimaa J, Mäkelä M, Kunnamo I, et al. (2002). Primary care guidelines on consultation practices: the effectiveness of computerized versus paper-based versions. A cluster randomized controlled trial among newly qualified primary care physicians. Int J Technol Assess Health Care.
18 Junghans C, Feder G, Timmis AD, et al. (2007). Effect of patient-specific ratings vs. conventional guidelines on investigation decisions in angina: Appropriateness of Referral and Investigation in Angina (ARIA) Trial. Arch Intern Med.
19 Kennedy ADM, Sculpher MJ, Coulter A, et al. (2003). A multicentre randomised controlled trial assessing the costs and benefits of using structured information and analysis of women’s preferences in the management of menorrhagia. Health Technol Assess.
20 King AC, Friedman R, Marcus B, et al. (2007). Ongoing physical activity advice by humans versus computers: The Community Health Advice by Telephone (CHAT) trial. Health Psychol.
21 Laprise R, Thivierge R, Gosselin G, et al. (2009). Improved cardiovascular prevention using best CME practices: a randomized trial. J Contin Educ Health Prof.
22 Lien LF, Brown AJ, Ard JD, et al. (2007). Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension.
23 Svetkey LP, Harsha DW, Vollmer WM, et al. (2003). Premier: A clinical trial of comprehensive lifestyle modification for blood pressure control: rationale, design and baseline characteristics. Ann Epidemiol.
24 Young DR, Vollmer WM, King AC, et al. (2009). Can individuals meet multiple physical activity and dietary behavior goals?. Am J Health Behav.
25 Marcus BH, Napolitano MA, King AC, et al. (2007). Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychol.
26 Maxwell AE, Bastani R, Danao LL, et al. (2010). Results of a community-based randomized trial to increase colorectal cancer screening among Filipino Americans. Am J Public Health.
27 Murtaugh CM, Pezzin LE, McDonald MV, et al. (2005). Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res.
28 Paradis HA, Conn KM, Gewirtz JR, et al. (2011). Innovative delivery of newborn anticipatory guidance: a randomized, controlled trial incorporating media-based learning into primary care. Acad Pediatr.
29 Partin MR, Nelson D, Radosevich D, et al. (2004). Randomized trial examining the effect of two prostate cancer screening educational interventions on patient knowledge, preferences, and behaviors. J Gen Intern Med.
30 Rahme E, Choquette D, Beaulieu M, et al. (2005). Impact of a general practitioner educational intervention on osteoarthritis treatment in an elderly population. Am J Med.
31 Rebbeck T, Maher CG, Refshauge KM. (2006). Evaluating two implementation strategies for whiplash guidelines in physiotherapy: a cluster randomised trial. Aust J Physiother.
32 Rimer BK, Halabi S, Sugg Skinner C, et al. (2001). The short-term impact of tailored mammography decision-making interventions. Patient Educ Couns.
33 Rycroft-Malone J, Seers K, Crichton N, et al. (2012). A pragmatic cluster randomised trial evaluating three implementation interventions. Implement Sci.
34 Simon SR, Majumdar SR, Prosser LA, et al. (2005). Group versus individual academic detailing to improve the use of antihypertensive medications in primary care: a cluster-randomized controlled trial. Am J Med.
35 Soler N, Ballester E, Martin A, et al. (2010). Changes in management of chronic obstructive pulmonary disease (COPD) in primary care: EMMEPOC study. Respir Med.
36 Sullivan MD, Gaster B, Russo J, et al. (2010). Randomized trial of web-based training about opioid therapy for chronic pain. Clin J Pain.
37 Watson MC, Bond CM, Grimshaw JM, et al. (2002). Educational strategies to promote evidence-based community pharmacy practice: a cluster randomized controlled trial (RCT). Fam Pract.
38 Wetter DW, Mazas C, Daza P, et al. (2007). Reaching and treating Spanish-speaking smokers through the National Cancer Institute’s Cancer Information Service. A randomized controlled trial. Cancer.
39 Wolters R, Wensing M, Klomp M, et al. (2005). Effects of distance learning on clinical management of LUTS in primary care: a randomised trial. Patient Educ Couns.
40 Wright FC, Gagliardi AR, Law CH, et al. (2008). A randomized controlled trial to improve lymph node assessment in stage II colon cancer. Arch Surg.
41 Bishop PB, Wing PC. (2006). Knowledge transfer in family physicians managing patients with acute low back pain: a prospective randomized control trial. Spine J.
42 Elder JP, Ayala GX, Campbell NR, et al. (2006). Long-term effects of a communication intervention for Spanish-dominant Latinas. Am J Prev Med.