# Appendix E Evidence Tables for Key Question 1

Table E-1 Key Question 1 study design details

Table E-2 Key Question 1 sample characteristics, part 1

Table E-3 Key Question 1 sample characteristics, part 2

Table E-4 Key Question 1 intervention descriptions

Table E-5 Key Question 1, first outcome

Table E-6 Key Question 1, second outcome

## References

1 Cox D, Cox AD. (2001). Communicating the consequences of early detection: The role of evidence and framing. J Market.
2 Elder JP, Ayala GX, Campbell NR, et al. (2005). Interpersonal and print nutrition communication for a Spanish-dominant Latino population: Secretos de la Buena Vida. Health Psychol.
3 Elder JP, Ayala GX, Campbell NR, et al. (2006). Long-term effects of a communication intervention for Spanish-dominant Latinas. Am J Prev Med.
4 Jibaja-Weiss ML, Volk RJ, Kingery P, et al. (2003). Tailored messages for breast and cervical cancer screening of low-income and minority women using medical records data. Patient Educ Couns.
5 Myers RE, Sifri R, Hyslop T, et al. (2007). A randomized controlled trial of the impact of targeted and tailored interventions on colorectal cancer screening. Cancer.
6 Schneider TR, Salovey P, Apanovitch AM, et al. (2001). The effects of message framing and ethnic targeting on mammography use among low-income women. Health Psychol.
7 Vernon SW, del Junco DJ, Tiro JA, et al. (2008). Promoting regular mammography screening II. Results from a randomized controlled trial in US women veterans. J Natl Cancer Inst.
8 del Junco DJ, Vernon SW, Coan SP, et al. (2008). Promoting regular mammography screening I. A systematic assessment of validity in a randomized trial. J Natl Cancer Inst.
9 Yu N, Shen FY. (2013). Benefits for Me or Risks for Others: A Cross-Culture Investigation of the Effects of Message Frames and Cultural Appeals. Health Communication.