# Appendix D Risk of Bias Tables

Table D-1 Risk of bias for KQ 1

Table D-2 Risk of bias for KQ 2

Table D-3 Risk of bias for KQ 3

## References

1 Cox D, Cox AD. (2001). Communicating the consequences of early detection: The role of evidence and framing. J Market.
2 Elder JP, Ayala GX, Campbell NR, et al. (2005). Interpersonal and print nutrition communication for a Spanish-dominant Latino population: Secretos de la Buena Vida. Health Psychol.
3 Jibaja-Weiss ML, Volk RJ, Kingery P, et al. (2003). Tailored messages for breast and cervical cancer screening of low-income and minority women using medical records data. Patient Educ Couns.
4 Myers RE, Sifri R, Hyslop T, et al. (2007). A randomized controlled trial of the impact of targeted and tailored interventions on colorectal cancer screening. Cancer.
5 Schneider TR, Salovey P, Apanovitch AM, et al. (2001). The effects of message framing and ethnic targeting on mammography use among low-income women. Health Psychol.
6 Vernon SW, del Junco DJ, Tiro JA, et al. (2008). Promoting regular mammography screening II. Results from a randomized controlled trial in US women veterans. J Natl Cancer Inst.
7 Yu N, Shen FY. (2013). Benefits for Me or Risks for Others: A Cross-Culture Investigation of the Effects of Message Frames and Cultural Appeals. Health Communication.
8 Bahrami M, Deery C, Clarkson JE, et al. (2004). Effectiveness of strategies to disseminate and implement clinical guidelines for the management of impacted and unerupted third molars in primary dental care, a cluster randomised controlled trial. Br Dent J.
9 Banait G, Sibbald B, Thompson D, et al. (2003). Modifying dyspepsia management in primary care: a cluster randomised controlled trial of educational outreach compared with passive guideline dissemination. Br J Gen Pract.
10 Beaulieu MD, Brophy J, Jacques A, et al. (2004). Drug treatment of stable angina pectoris and mass dissemination of therapeutic guidelines: a randomized controlled trial. QJM.
11 Becker A, Leonhardt C, Kochen MM, et al. (2008). Effects of two guideline implementation strategies on patient outcomes in primary care: a cluster randomized controlled trial. Spine (Phila Pa 1976).
12 Bekkering GE, Hendriks HJ, van Tulder MW, et al. (2005). Effect on the process of care of an active strategy to implement clinical guidelines on physiotherapy for low back pain: a cluster randomised controlled trial. Qual Saf Health Care.
13 Bekkering GE, van Tulder MW, Hendriks EJ, et al. (2005). Implementation of clinical guidelines on physical therapy for patients with low back pain: randomized trial comparing patient outcomes after a standard and active implementation strategy. Phys Ther.
14 Bishop PB, Wing PC. (2006). Knowledge transfer in family physicians managing patients with acute low back pain: a prospective randomized control trial. Spine J.
15 Campbell MK, James A, Hudson MA, et al. (2004). Improving multiple behaviors for colorectal cancer prevention among African American church members. Health Psychol.
16 Carney PA, Harwood BG, Greene MA, et al. (2005). Impact of a telephone counseling intervention on transitions in stage of change and adherence to interval mammography screening (United States). Cancer Causes Control.
17 Christakis DA, Zimmerman FJ, Rivara FP, et al. (2006). Improving pediatric prevention via the internet: a randomized, controlled trial. Pediatrics.
18 Church TR, Yeazel MW, Jones RM, et al. (2004). A randomized trial of direct mailing of fecal occult blood tests to increase colorectal cancer screening. J Natl Cancer Inst.
19 Daniels EC, Bacon J, Denisio S, et al. (2005). Translation squared: improving asthma care for high-disparity populations through a safety net practice-based research network. J Asthma.
20 Davis J, Roberts R, Davidson DL, et al. (2004). Implementation strategies for a Scottish national epilepsy guideline in primary care: results of the Tayside Implementation of Guidelines in Epilepsy Randomized (TIGER) trial. Epilepsia.
21 Eaton CB, Parker DR, Borkan J, et al. (2011). Translating cholesterol guidelines into primary care practice: a multimodal cluster randomized trial. Ann Fam Med.
22 Feldstein A, Elmer PJ, Smith DH, et al. (2006). Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc.
23 Figueiras A, Sastre I, Tato F, et al. (2001). One-to-one versus group sessions to improve prescription in primary care: a pragmatic randomized controlled trial. Med Care.
24 Gattellari M, Ward JE. (2005). A community-based randomised controlled trial of three different educational resources for men about prostate cancer screening. Patient Educ Couns.
25 Hagmolen of ten Have W, van den Berg NJ, van der Palen J, et al. (2008). Implementation of an asthma guideline for the management of childhood asthma in general practice: a randomised controlled trial. Prim Care Respir J.
26 Jain MK, Heyland D, Dhaliwal R, et al. (2006). Dissemination of the Canadian clinical practice guidelines for nutrition support: results of a cluster randomized controlled trial. Crit Care Med.
27 Jousimaa J, Mäkelä M, Kunnamo I, et al. (2002). Primary care guidelines on consultation practices: the effectiveness of computerized versus paper-based versions. A cluster randomized controlled trial among newly qualified primary care physicians. Int J Technol Assess Health Care.
28 Junghans C, Feder G, Timmis AD, et al. (2007). Effect of patient-specific ratings vs conventional guidelines on investigation decisions in angina: Appropriateness of Referral and Investigation in Angina (ARIA) Trial. Arch Intern Med.
29 Kennedy ADM, Sculpher MJ, Coulter A, et al. (2003). A multicentre randomised controlled trial assessing the costs and benefits of using structured information and analysis of women’s preferences in the management of menorrhagia. Health Technol Assess.
30 King AC, Friedman R, Marcus B, et al. (2007). Ongoing physical activity advice by humans versus computers: The Community Health Advice by Telephone (CHAT) trial. Health Psychol.
31 Lenza M, Belloti Joao C, Gomes dos Santos Joao B, et al. (2009). Surgical interventions for treating acute fractures or non-union of the middle third of the clavicle. Cochrane Database of Systematic Reviews.
32 Lien LF, Brown AJ, Ard JD, et al. (2007). Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension.
33 Manfredi C, Cho YI, Warnecke R, et al. (2011). Dissemination strategies to improve implementation of the PHS smoking cessation guideline in MCH public health clinics: experimental evaluation results and contextual factors. Health Educ Res.
34 Marcus BH, Napolitano MA, King AC, et al. (2007). Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychol.
35 Maxwell AE, Bastani R, Danao LL, et al. (2010). Results of a community-based randomized trial to increase colorectal cancer screening among Filipino Americans. Am J Public Health.
36 Murtaugh CM, Pezzin LE, McDonald MV, et al. (2005). Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res.
37 Paradis HA, Conn KM, Gewirtz JR, et al. (2011). Innovative delivery of newborn anticipatory guidance: a randomized, controlled trial incorporating media-based learning into primary care. Acad Pediatr.
38 Partin MR, Nelson D, Radosevich D, et al. (2004). Randomized trial examining the effect of two prostate cancer screening educational interventions on patient knowledge, preferences, and behaviors. J Gen Intern Med.
39 Rahme E, Choquette D, Beaulieu M, et al. (2005). Impact of a general practitioner educational intervention on osteoarthritis treatment in an elderly population. Am J Med.
40 Rebbeck T, Maher CG, Refshauge KM. (2006). Evaluating two implementation strategies for whiplash guidelines in physiotherapy: a cluster randomised trial. Aust J Physiother.
41 Renzi PM, Ghezzo H, Goulet S, et al. (2006). Paper stamp checklist tool enhances asthma guidelines knowledge and implementation by primary care physicians. Can Respir J.
42 Han PK, Klein WM, Arora NK. (2011). Varieties of uncertainty in health care: a conceptual taxonomy. Med Decis Making.
43 Rycroft-Malone J, Seers K, Crichton N, et al. (2012). A pragmatic cluster randomised trial evaluating three implementation interventions. Implement Sci.
44 Simon SR, Majumdar SR, Prosser LA, et al. (2005). Group versus individual academic detailing to improve the use of antihypertensive medications in primary care: a cluster-randomized controlled trial. Am J Med.
45 Soler N, Ballester E, Martin A, et al. (2010). Changes in management of chronic obstructive pulmonary disease (COPD) in primary care: EMMEPOC study. Respir Med.
46 Sullivan MD, Gaster B, Russo J, et al. (2010). Randomized trial of web-based training about opioid therapy for chronic pain. Clin J Pain.
47 van Driel ML, Coenen S, Dirven K, et al. (2007). What is the role of quality circles in strategies to optimise antibiotic prescribing? A pragmatic cluster-randomised controlled trial in primary care. Qual Saf Health Care.
48 van Steenkiste B, van der Weijden T, Stoffers HE, et al. (2007). Improving cardiovascular risk management: a randomized, controlled trial on the effect of a decision support tool for patients and physicians. Eur J Cardiovasc Prev Rehabil.
49 Varonen H, Rautakorpi UM, Nyberg S, et al. (2007). Implementing guidelines on acute maxillary sinusitis in general practice--a randomized controlled trial. Fam Pract.
50 Wadland WC, Soffelmayr B, Ives K. (2001). Enhancing smoking cessation of low-income smokers in managed care. J Fam Pract.
51 Watson MC, Bond CM, Grimshaw JM, et al. (2002). Educational strategies to promote evidence-based community pharmacy practice: a cluster randomized controlled trial (RCT). Fam Pract.
52 Wetter DW, Mazas C, Daza P, et al. (2007). Reaching and treating Spanish-speaking smokers through the National Cancer Institute’s Cancer Information Service. A randomized controlled trial. Cancer.
53 Wolters R, Wensing M, Klomp M, et al. (2005). Effects of distance learning on clinical management of LUTS in primary care: a randomised trial. Patient Educ Couns.
54 Wright FC, Gagliardi AR, Law CH, et al. (2008). A randomized controlled trial to improve lymph node assessment in stage II colon cancer. Arch Surg.
55 Akl EA, Guyatt GH, Irani J, et al. (2012). “Might” or “suggest”? No wording approach was clearly superior in conveying the strength of recommendation. J Clin Epidemiol.
56 Brewer NT, Richman AR, DeFrank JT, et al. (2012). Improving communication of breast cancer recurrence risk. Breast Cancer Res Treat.
57 Han PKJ, Klein WMP, Lehman T, et al. (2011). Communication of uncertainty regarding individualized cancer risk estimates: effects and influential factors. Med Decis Making.
58 Johnson BB, Slovic P. (1995). Presenting uncertainty in health risk assessment: Initial studies of its effects on risk perception and trust. Risk Anal.
59 Longman T, Turner RM, King M, et al. (2012). The effects of communicating uncertainty in quantitative health risk estimates. Patient Educ Couns.
60 McCormack L, Treiman K, Bann C, et al. (2011). Translating medical evidence to promote informed health care decisions. Health Serv Res.
61 Perneger TV, Schiesari L, Cullati S, et al. (2011). Does information about risks and benefits improve the decision-making process in cancer screening - randomized study. Cancer Epidemiol.
62 Schwartz LM, Woloshin S. (2011). Communicating uncertainties about prescription drugs to the public: a national randomized trial. Arch Intern Med.
63 Sheridan SL, Golin C, Bunton A, et al. (2012). Shared decision making for prostate cancer screening: the results of a combined analysis of two practice-based randomized controlled trials. BMC Med Inform Decis Mak.
64 Elder JP, Ayala GX, Campbell NR, et al. (2006). Long-term effects of a communication intervention for Spanish-dominant Latinas. Am J Prev Med.