# Appendix C Excluded Studies

## Wrong Publication

(Protocols, studies published only as abstracts, studies with no original data)

1 Akl EA, Maroun N, Guyatt G, et al. (2007). Symbols were superior to numbers for presenting strength of recommendations to health care consumers: a randomized trial. J Clin Epidemiol.
2 Denton GD, Smith J, Faust J, et al. (2001). Comparing the efficacy of staff versus housestaff instruction in an intervention to improve hypertension management. Acad Med.
3 Dobbins M, Robeson P, Ciliska D, et al. (2009). A description of a knowledge broker role implemented as part of a randomized controlled trial evaluating three knowledge translation strategies. Implementation Science.
4 Frosch DL, Kaplan RM, Felitti V. (2001). The evaluation of two methods to facilitate shared decision making for men considering the prostate-specific antigen test. J Gen Intern Med.
5 Frosch DL, Kaplan RM, Felitti VJ. (2003). A randomized controlled trial comparing internet and video to facilitate patient education for men considering the prostate specific antigen test. J Gen Intern Med.
6 Ibrekk H, Morgan MG. (1987). Graphical communication of uncertain quantities to nontechnical people. Risk Anal.
7 Jaffe-Katz A, Budescu DV, Wallsten TS. (1989). Timed magnitude comparisons of numerical and nonnumerical expressions of uncertainty. Mem Cognit.
8 Kuhn KM. (1997). Communicating uncertainty: framing effects on response to vague probabilities. Organ Behav Hum Decis Process.
9 Larkey LK, Gonzalez J. (2007). Storytelling for promoting colorectal cancer prevention and early detection among Latinos. Patient Educ Couns.
10 Liaw ST, Sulaiman ND, Barton CA, et al. (2008). An interactive workshop plus locally adapted guidelines can improve general practitioners asthma management and knowledge: a cluster randomised trial in the Australian setting. BMC Fam Pract.
11 Ling BS, Schoen RE, Trauth JM, et al. (2009). Physicians encouraging colorectal screening: a randomized controlled trial of enhanced office and patient management on compliance with colorectal cancer screening. Arch Intern Med.
12 Lippke S, Kuhlmann T. (2013). Gesundheitsförderungsmaßnahmen für ältere Menschen mittels neuer Medien. Zeitschrift für Gesundheitspsychologie.
13 Rodriguez-Salvanes F, Novella B, Fernandez Luque MJ, et al. (2011). Efficacy of a strategy for implementing a guideline for the control of cardiovascular risk in a primary healthcare setting: the SIRVA2 study a controlled, blinded community intervention trial randomised by clusters. BMC Fam Pract.
14 Seers K, Cox K, Crichton NJ, et al. (2012). FIRE (Facilitating Implementation of Research Evidence): a study protocol. Implementation science: IS.
15 Stinesen B, Renes R, Meinetten J, et al. (2013). Interactieve media voor gedragsverandering. Tijdschrift voor gezondheidswetenschappen.
16 Teigen KH, Brun W. (1999). The directionality of verbal probability expressions: Effects on decisions, predictions, and probabilistic reasoning. Organ Behav Hum Decis Process.
17 White M, Michaud G, Pachev G, et al. (2004). Randomized trial of problem-based versus didactic seminars for disseminating evidence-based guidelines on asthma management to primary care physicians. J Contin Educ Health Professions.

## Not Health-Related Evidence

(Did not include research-based evidence that was health-related)

1 Clayton JM, Butow PN, Tattersall MH, et al. (2007). Randomized controlled trial of a prompt list to help advanced cancer patients and their caregivers to ask questions about prognosis and end-of-life care. J Clin Oncol.
2 Hong S, Park HS. (2012). Computer-mediated persuasion in online reviews: Statistical versus narrative evidence. Computers in Human Behavior.
3 Igou ER, Bless H. (2007). On undesirable consequences of thinking: Framing effects as a function of substantive processing. J Behav Decis Making.
4 Jain SP, Mathur P, Maheswaran D. (2009). The Influence of Consumers’ Lay Theories on Approach/Avoidance Motivation. J Market Res.
5 Katz SJ, Nissan N, Moyer CA. (2004). Crossing the digital divide: evaluating online communication between patients and their providers. Am J Manag Care.
6 Kuhberger A, Tanner C. (2010). Risky Choice Framing: Task Versions and a Comparison of Prospect Theory and Fuzzy-Trace Theory. J Behav Decis Making.
7 Langham J, Tucker H, Sloan D, et al. (2002). Secondary prevention of cardiovascular disease: a randomised trial of training in information management, evidence-based medicine, both or neither: the PIER trial. Br J Gen Pract.
8 Li C. (2013). “Cultumization?” The Impact of Cultural Priming on Customized Communication. Mass Communication and Society.
9 Marlenga B, Pickett W, Berg RL. (2002). Evaluation of an enhanced approach to the dissemination of the North American Guidelines for Children’s Agricultural Tasks: a randomized controlled trial. Prev Med.
10 Matthias MS. (2009). Problematic integration in pregnancy and childbirth: contrasting approaches to uncertainty and desire in obstetric and midwifery care. Health Commun.
11 McAuliff BD, Kovera MB, Nunez G. (2009). Can jurors recognize missing control groups, confounds, and experimenter bias in psychological science?. Law Hum Behav.
12 McCaffery KJ, Dixon A, Hayen A, et al. (2012). The influence of graphic display format on the interpretations of quantitative risk information among adults with lower education and literacy: a randomized experimental study. Med Decis Making.
13 Morss RE, Lazo JK, Demuth JL. (2010). Examining the use of weather forecasts in decision scenarios: results from a US survey with implications for uncertainty communication. Meteorological Applications.
14 Patt A. (2007). Assessing model-based and conflict-based uncertainty. Global Environmental Change-Human and Policy Dimensions.
15 Pelayo M, Cebrián D, Areosa A, et al. (2011). Effects of online palliative care training on knowledge, attitude and satisfaction of primary care physicians. BMC Fam Pract.
16 Pennington L, Roddam H, Burton C, et al. (2005). Promoting research use in speech and language therapy: a cluster randomized controlled trial to compare the clinical effectiveness and costs of two training strategies. Clin Rehabil.
17 Roggeveen AL, Grewal D, Gotlieb J. (2006). Does the frame of a comparative ad moderate the effectiveness of extrinsic information cues?. J Consum Res.

## Wrong Population

(Children < 19 years, non-English speaking, incarcerated, Federal and State policymakers)

1 Ali R, Alexander KP. (2007). Statins for the primary prevention of cardiovascular events in older adults: a review of the evidence (Structured abstract). Am J Geriatr Pharmacother.
2 Atkinson P. (1984). Training for certainty. Soc Sci Med.
3 Babrow AS. (1992). Communication and problematIc integration: Understanding diverging probability and value, ambiguity, ambivalence, and impossibility. Communication Theory.
4 Babrow AS. (1998). Colloquy - Developing multiple-process theories of communication. Human Commun Res.
5 Baishnab E, Karner C. (2012). Primary care based clinics for asthma. Cochrane Database of Systematic Reviews.
6 Barrett HC, Fiddick L. (2000). Evolution and risky decisions. Trends Cogn Sci.
7 Bauer MS, McBride L, Williford WO, et al. (2006). Collaborative care for bipolar disorder: Part II. Impact on clinical outcome, function, and costs. Psychiatr Serv.
8 Beck SJ. (2007). Risk, communication and health psychology. Health Commun.
9 Bekkers MJ, Simpson SA, Dunstan F, et al. (2010). Enhancing the quality of antibiotic prescribing in primary care: qualitative evaluation of a blended learning intervention. BMC Fam Pract.
10 Blaha MJ, Nasir K, Blumenthal RS. (2012). Statin therapy for healthy men identified as “increased risk”. JAMA.
11 Blair MM, Carson DS, Barrington R. (2000). Bisphosphonates in the prevention and treatment of glucocorticoid-induced osteoporosis (Structured abstract). J Fam Pract.
12 Brainerd CJ, Reyna VF. (2001). Fuzzy-trace theory: Dual processes in memory, reasoning, and cognitive neuroscience. Advances in Child Development and Behavior.
13 Chasan-Taber L, Marcus BH, Stanek E, et al. (2009). A randomized controlled trial of prenatal physical activity to prevent gestational diabetes: design and methods. J Womens Health (Larchmt).
14 Edwards A, Elwyn G, Mulley A. (2002). Explaining risks: turning numerical data into meaningful pictures. Br Med J.
15 Edwards A, Unigwe S, Elwyn G, et al. (2003). Personalised risk communication for informed decision making about entering screening programs. Cochrane Database Syst Rev.
16 Eisenberg EM. (2001). Building a mystery: Toward a new theory of communication and identity. J Commun.
17 Everett T, Bryant A, Griffin Michelle F, et al. (2011). Interventions targeted at women to encourage the uptake of cervical screening. Cochrane Database of Systematic Reviews.
18 Fallowfield L. (2008). Psychosocial aspects of risk appraisal. Breast Cancer Research.
19 Farmer Anna P, Légaré F, Turcot L, et al. (2008). Printed educational materials: effects on professional practice and health care outcomes. Cochrane Database of Systematic Reviews.
20 Fischhoff B. (2011). Applying the science of communication to the communication of science. Climatic Change.
21 Flodgren G, Parmelli E, Doumit G, et al. (2011). Local opinion leaders: effects on professional practice and health care outcomes. Cochrane Database of Systematic Reviews.
22 Forsetlund L, Bjørndal A, Rashidian A, et al. (2009). Continuing education meetings and workshops: effects on professional practice and health care outcomes. Cochrane Database of Systematic Reviews.
23 Fox RC. (1980). The evolution of medical uncertainty. Milbank Mem Fund Q.
24 Garau M, Towse A, Garrison L, et al. (2013). Can and should value-based pricing be applied to molecular diagnostics?. Personalized Medicine.
25 Gayet JL, Lithell H. (2003). The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. J Hypertens.
26 Gigerenzer G, Edwards A. (2003). Simple tools for understanding risks: from innumeracy to insight. Br Med J.
27 Guthrie C. (2003). Prospect theory, risk preference, and the law. Northwestern University Law Review.
28 HalvorTeigen K. (2008). More than X is a lot: Pragmatic implicatures of one-sided uncertainty intervals. Social Cognition.
29 Han PK. (2013). Conceptual, methodological, and ethical problems in communicating uncertainty in clinical evidence. Med Care Res Rev.
30 Han PK, Klein WM, Arora NK. (2011). Varieties of uncertainty in health care: a conceptual taxonomy. Med Decis Making.
31 Han PKJ, Klein WMP, Lehman TC, et al. (2009). Laypersons’ Responses to the Communication of Uncertainty Regarding Cancer Risk Estimates. Med Decis Making.
32 Hanson JL. (2009). Quandaries of Informed Consent. Arch Intern Med.
33 Harrington NG, Noar SM. (2011). Reporting standards for studies of tailored interventions (R2). Health Educ Res.
34 Haward MF, Lorenz JM. (2011). Communicating risk under conditions of uncertainty: not as simple as it may seem. Acta Paediatr.
35 Hill AM, Hill K, Brauer S, et al. (2009). Evaluation of the effect of patient education on rates of falls in older hospital patients: description of a randomised controlled trial. BMC Geriatr.
36 Hoffrage U, Lindsey S, Hertwig R, et al. (2000). Medicine. Communicating statistical information. Science.
37 Hofmeister M. (2012). How Do We Get Messages That Promote a Healthy Lifestyle Across?. Singapore Med J.
38 Honka A, Kaipainen K, Hietala H, et al. (2011). Rethinking health: ICT enabled services to empower people to manage their health. Biomedical Engineering, IEEE Reviews in.
39 Johnson SS. (2013). Maximizing Behavior Change by Matching Your Message to Clients’ Readiness to Exercise. Acsms Health & Fitness Journal.
40 Jusot F, Khlat M. Time preference and risk aversion in educational inequalities in smoking: a population-based study.
41 Kaipainen K, Honka A, Saranummi N. (2011). Personalized behavior change support for disease prevention.
42 Kistler CE, Goldstein AO. (2012). The risk of adverse cardiovascular events from varenicline balanced against the benefits in mortality from smoking cessation. Nicotine Tob Res.
43 Kulier R, Khan KS, Gulmezoglu AM, et al. (2010). A cluster randomized controlled trial to evaluate the effectiveness of the clinically integrated RHL evidence-based medicine course. Reproductive Health.
44 Latimer-Cheung AE, Fucito LM, Carlin-Menter S, et al. (2012). How Do Perceptions About Cessation Outcomes Moderate the Effectiveness of a Gain-Framed Smoking Cessation Telephone Counseling Intervention?. Journal of Health Communication.
45 Latimer-Cheung AE, Toll BA, Salovey P. (2013). Promoting increased physical activity and reduced inactivity. Lancet.
46 Light D. (1979). Uncertainty and control in professional training. J Health Soc Behav.
47 Loewenstein DA, Arguelles T, Arguelles S, et al. (1994). Potential cultural bias in the neuropsychological assessment of the older adult. J Clin Exp Neuropsychol.
48 Mamdani MM. (2008). Health advisories: when good intentions go bad. Can Med Assoc J.
49 Mass C, Joslyn S, Pyle J, et al. (2009). PROBCAST A Web-Based Portal to Mesoscale Probabilistic Forecasts. Bulletin of the American Meteorological Society.
50 Maule AJ, Hodgkinson GP. (2002). Heuristics, biases and strategic decision making. Psychologist.
51 McBride CM, Bryan AD, Bray MS, et al. (2012). Health behavior change: can genomics improve behavioral adherence?. Am J Public Health.
52 Naranbhai V, Abdool Karim Q, Meyer-Weitz A. (2011). Interventions to modify sexual risk behaviours for preventing HIV in homeless youth. Cochrane Database of Systematic Reviews.
53 Neuner-Jehle S, Senn O, Wegwarth O, et al. (2011). How do family physicians communicate about cardiovascular risk? Frequencies and determinants of different communication formats. BMC Fam Pract.
54 Pang AT, Wittenbrink CM, Lodha SK. (1997). Approaches to uncertainty visualization. Visual Computer.
55 Politi MC, Han PK, Col NF. (2007). Communicating the uncertainty of harms and benefits of medical interventions. Med Decis Making.
56 Quinn CC, Gruber-Baldini AL, Shardell M, et al. (2009). Mobile diabetes intervention study: testing a personalized treatment/behavioral communication intervention for blood glucose control. Contemp Clin Trials.
57 Reyna VF. (2008). A theory of medical decision making and health: fuzzy trace theory. Med Decis Making.
58 Reynolds WW, Nelson RM. (2008). Empirical data and the acceptability of research risk - A commentary on the charitable participation standard. Arch Pediatr Adolesc Med.
59 Schunemann HJ, Fretheim A, Oxman AD. (2006). Improving the use of research evidence in guideline development: 13. Applicability, transferability and adaptation. Health Res Pol Syst.
60 Spiegelhalter DJ. (2008). Understanding uncertainty. Ann Fam Med.
61 Stanovich KE, Toplak ME, West RF. (2008). The development of rational thought: A taxonomy of heuristics and biases. Kail RV, editor. Advances in Child Development and Behavior.
62 Strachan PH. (2010). What do you say about risk?. Heart.
63 Taskila T, Macaskill S, Coleman T, et al. (2012). A randomised trial of nicotine assisted reduction to stop in pharmacies - the RedPharm study. BMC public health.
64 Terre L. (2011). Optimizing Tailored Health Communications. Am J Lifestyle Med.
65 Thomson H, Thomas S, Sellstrom E, et al. (2010). Housing improvements for health and associated socio-economic outcomes. Cochrane Database of Systematic Reviews.
66 Verweij LM, Proper KI, Weel AN, et al. (2009). Design of the Balance@Work project: systematic development, evaluation and implementation of an occupational health guideline aimed at the prevention of weight gain among employees. BMC Public Health.
67 Wills CE. (1999). On the role of framing effects in assessment of health-related utilities. Med Decis Making.
68 Winkler RL. (1996). The costs and benefits of vague information. Reliability Engineering and System Safety.
69 Yin HQ, Prochaska JO, Rossi JS, et al. (2013). Treatment-enhanced paired action contributes substantially to change across multiple health behaviors: secondary analyses of five randomized trials. Transl Behav Med.
70 Yusuf S, Anand S. (2002). Hormone replacement therapy: a time for pause. CMAJ.

## Wrong Intervention

1 Brownson RC, Dodson EA, Stamatakis KA, et al. (2011). Communicating evidence-based information on cancer prevention to state-level policy makers. J Natl Cancer Inst.
2 Çölkesen B. (2013). Primary prevention of cardiovascular disease: evaluation of an individual-based strategy.
3 Donze JR, Tercyak KP. (2006). The Survivor Health and Resilience Education (SHARE) Program: Development and Evaluation of a Health Behavior Intervention for Adolescent Survivors of Childhood Cancer. J Clin Psychol Med Settings.
4 Sanchez-Calzon AB, Meneu T, Traver V. (2012). Semantic Technologies for the Modelling of Human Behaviour from a Psychosocial View. Semantic Interoperability: Issues, Solutions, Challenges.

## Wrong Comparator

(Comparisons with usual practice—except for KQ 3 when evidence is sparse)

1 Allard J, Hebert R, Rioux M, et al. (2001). Efficacy of a clinical medication review on the number of potentially inappropriate prescriptions prescribed for community-dwelling elderly people. CMAJ.
2 Aragones A, Schwartz MD, Shah NR, et al. (2010). A randomized controlled trial of a multilevel intervention to increase colorectal cancer screening among Latino immigrants in a primary care facility. J Gen Intern Med.
3 Baer JS, Wells EA, Rosengren DB, et al. (2009). Agency context and tailored training in technology transfer: a pilot evaluation of motivational interviewing training for community counselors. J Subst Abuse Treat.
4 Bemelmans WJ, Broer J, de Vries JH, et al. (2000). Impact of Mediterranean diet education versus posted leaflet on dietary habits and serum cholesterol in a high risk population for cardiovascular disease. Public Health Nutr.
5 Bernhard J, Butow P, Aldridge J, et al. (2012). Communication about standard treatment options and clinical trials: Can we teach doctors new skills to improve patient outcomes?. Psychooncology.
6 Bernstein LM, Chapman GB, Elstein AS. (1999). Framing effects in choices between multioutcome life-expectancy lotteries. Med Decis Making.
7 Bloom JR, Stewart SL, Hancock SL. (2006). Breast cancer screening in women surviving Hodgkin disease. Am J Clin Oncol.
8 Bochicchio GV, Smit PA, Moore R, et al. (2006). Pilot study of a web-based antibiotic decision management guide. J Am Coll Surg.
9 Bonds DE, Hogan PE, Bertoni AG, et al. (2009). A multifaceted intervention to improve blood pressure control: The Guideline Adherence for Heart Health (GLAD) study. Am Heart J.
10 Boter H, Mistiaen P, Groenewegen I. (2000). A randomized trial of a Telephone Reassurance Programme for patients recently discharged from an ophthalmic unit. J Clin Nurs.
11 Bourgeois FT, Simons WW, Olson K, et al. (2008). Evaluation of influenza prevention in the workplace using a personally controlled health record: randomized controlled trial. J Med Internet Res.
12 Buller DB, Burgoon M, Hall JR, et al. (2000). Using language intensity to increase the success of a family intervention to protect children from ultraviolet radiation: predictions from language expectancy theory. Prev Med.
13 Carling CLL, Kristoffersen DT, Oxman AD, et al. (2010). The Effect of How Outcomes Are Framed on Decisions about Whether to Take Antihypertensive Medication: A Randomized Trial. PLoS ONE.
14 Cherubini P, Rumiati R, Rossi D, et al. (2005). Improving attitudes toward prostate examinations by loss-framed appeals. J Appl Soc Psychol.
15 Chiauzzi E, Pujol LA, Wood M, et al. (2010). painACTION-back pain: a self-management website for people with chronic back pain. Pain Med.
16 Christensen H, Griffiths KM, Jorm AF. (2004). Delivering interventions for depression by using the internet: randomised controlled trial. BMJ.
17 Christensen H, Leach LS, Barney L, et al. (2006). The effect of web based depression interventions on self reported help seeking: randomised controlled trial. BMC Psychiatry.
18 Clarkson JE, Young L, Ramsay CR, et al. (2009). How to influence patient oral hygiene behavior effectively. J Dent Res.
19 Corson K, Doak MN, Denneson L, et al. (2011). Primary care clinician adherence to guidelines for the management of chronic musculoskeletal pain: results from the study of the effectiveness of a collaborative approach to pain. Pain Med.
20 Costanza ME, Luckmann R, Stoddard AM, et al. (2007). Using tailored telephone counseling to accelerate the adoption of colorectal cancer screening. Cancer Detect Prev.
21 Croudace T, Evans J, Harrison G, et al. (2003). Impact of the ICD-10 Primary Health Care (PHC) diagnostic and management guidelines for mental disorders on detection and outcome in primary care. Cluster randomised controlled trial. Br J Psychiatry.
22 Diefenbach MA, Mohamed NE, Butz BP, et al. (2012). Acceptability and preliminary feasibility of an Internet/CD-ROM-based education and decision program for early-stage prostate cancer patients: Randomized pilot study. J Med Internet Res.
23 Djurcilov S, Kim K, Lermusiaux P, et al. (2002). Visualizing scalar volumetric data with uncertainty. Comput Graph.
24 Druckman JN. (2001). Using credible advice to overcome framing effects. J L Econ & Org.
25 Emery J, Morris H, Goodchild R, et al. (2007). The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer.
26 Finkelstein JA, Davis RL, Dowell SF, et al. (2001). Reducing antibiotic use in children: a randomized trial in 12 practices. Pediatrics.
27 Finkelstein JA, Huang SS, Kleinman K, et al. (2008). Impact of a 16-community trial to promote judicious antibiotic use in Massachusetts. Pediatrics.
28 Fleisher L, Kandadai V, Keenan E, et al. (2012). Build it, and will they come? Unexpected findings from a study on a Web-based intervention to improve colorectal cancer screening. J Health Commun.
29 Freemantle N, Johnson R, Dennis J, et al. (2000). Sleeping with the enemy? A randomized controlled trial of a collaborative health authority/industry intervention to influence prescribing practice. Br J Clin Pharmacol.
30 Freemantle N, Nazareth I, Eccles M, et al. (2002). A randomised controlled trial of the effect of educational outreach by community pharmacists on prescribing in UK general practice. Br J Gen Pract.
31 Fretheim A, Oxman AD, Havelsrud K, et al. (2006). Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med.
32 Gadomski A, Ackerman S, Burdick P, et al. (2006). Efficacy of the North American guidelines for children’s agricultural tasks in reducing childhood agricultural injuries. Am J Public Health.
33 Garcia-Retamero R, Cokely ET. (2011). Effective Communication of Risks to Young Adults: Using Message Framing and Visual Aids to Increase Condom Use and STD Screening. JExP.
34 Garcia-Retamero R, Galesic M. (2010). How to Reduce the Effect of Framing on Messages About Health. J Gen Intern Med.
35 Gattellari M, Ward JE. (2003). Does evidence-based information about screening for prostate cancer enhance consumer decision-making? A randomised controlled trial. J Med Screen.
36 Genz J, Haastert B, Muller H, et al. (2012). Blood glucose testing and primary prevention of Type 2 diabetes-evaluation of the effect of evidence-based patient information: a randomized controlled trial. Diabet Med.
37 Giles JT, Kennedy DT, Dunn EC, et al. (2001). Results of a community pharmacy-based breast cancer risk-assessment and education program. Pharmacotherapy.
38 Gnjidic D, Le Couteur DG, Abernethy DR, et al. (2010). A pilot randomized clinical trial utilizing the drug burden index to reduce exposure to anticholinergic and sedative medications in older people. Ann Pharmacother.
39 Goldberg HI, Deyo RA, Taylor VM, et al. (2001). Can evidence change the rate of back surgery? A randomized trial of community-based education. Eff Clin Pract.
40 Goodwin MA, Zyzanski SJ, Zronek S, et al. (2001). A clinical trial of tailored office systems for preventive service delivery. The Study to Enhance Prevention by Understanding Practice (STEP-UP). Am J Prev Med.
41 Griffiths CE, Taylor H, Collins SI, et al. (2006). The impact of psoriasis guidelines on appropriateness of referral from primary to secondary care: a randomized controlled trial. Br J Dermatol.
42 Halberg AM, Teigen KH, Fostervold KI. (2009). Maximum vs. minimum values: preferences of speakers and listeners for upper and lower limit estimates. Acta Psychol (Amst).
43 Harris JL, Furberg R, Martin N, et al. (2013). Implementing an SMS-based intervention for persons living with human immunodeficiency virus. J Public Health Manag Pract.
44 Hatchell AC, Bassett-Gunter RL, Clarke M, et al. (2013). Messages for men: the efficacy of EPPM-based messages targeting men’s physical activity. Health Psychol.
45 Ireland DM, Clifton PM, Keogh JB. (2010). Achieving the salt intake target of 6 g/day in the current food supply in free-living adults using two dietary education strategies. J Am Diet Assoc.
46 Johnson W, Shaya FT, Khanna N, et al. (2011). The Baltimore Partnership to Educate and Achieve Control of Hypertension (The BPTEACH Trial): a randomized trial of the effect of education on improving blood pressure control in a largely African American population. J Clin Hypertens (Greenwich).
47 Katz DA, Muehlenbruch DR, Brown RL, et al. (2004). Effectiveness of implementing the agency for healthcare research and quality smoking cessation clinical practice guideline: a randomized, controlled trial. J Natl Cancer Inst.
48 Kerns JW, Krist AH, Woolf SH, et al. (2008). Patient perceptions of how physicians communicate during prostate cancer screening discussions: a comparison of residents and faculty. Fam Med.
49 Kreuter MW, Sugg-Skinner C, Holt CL, et al. (2005). Cultural tailoring for mammography and fruit and vegetable intake among low-income African-American women in urban public health centers. Prev Med.
50 Krist AH, Peele E, Woolf SH, et al. (2011). Designing a patient-centered personal health record to promote preventive care. BMC Med Inform Decis Mak.
51 Lane DS, Messina CR, Cavanagh MF, et al. (2008). A provider intervention to improve colorectal cancer screening in county health centers. Med Care.
52 Lauver DR, Settersten L, Kane JH, et al. (2003). Tailored messages, external barriers, and women’s utilization of professional breast cancer screening over time. Cancer.
53 Levine DA, Funkhouser EM, Houston TK, et al. (2011). Improving care after myocardial infarction using a 2-year internet-delivered intervention: the Department of Veterans Affairs myocardial infarction-plus cluster-randomized trial. Arch Intern Med.
54 Lozano P, Finkelstein JA, Carey VJ, et al. (2004). A multisite randomized trial of the effects of physician education and organizational change in chronic-asthma care: Health outcomes of the Pediatric Asthma Care Patient Outcomes Research Team II Study. Arch Pediatr Adolesc Med.
55 Markey P, Schattner P. (2001). Promoting evidence-based medicine in general practice-the impact of academic detailing. Fam Pract.
56 Martens JD, Winkens RA, van der Weijden T, et al. (2006). Does a joint development and dissemination of multidisciplinary guidelines improve prescribing behaviour: a pre/post study with concurrent control group and a randomised trial. BMC Health Serv Res.
57 Mayoux-Benhamou A, Giraudet-Le Quintrec JS, Ravaud P, et al. (2008). Influence of patient education on exercise compliance in rheumatoid arthritis: a prospective 12-month randomized controlled trial. J Rheumatol.
58 Mazor KM, Baril J, Dugan E, et al. (2007). Patient education about anticoagulant medication: is narrative evidence or statistical evidence more effective?. Patient Educ Couns.
59 Mettes TG, van der Sanden WJ, Bronkhorst E, et al. (2010). Impact of guideline implementation on patient care: a cluster RCT. J Dent Res.
60 Migneault JP, Dedier JJ, Wright JA, et al. (2012). A Culturally Adapted Telecommunication System to Improve Physical Activity, Diet Quality, and Medication Adherence Among Hypertensive African-Americans: A Randomized Controlled Trial. Ann Behav Med.
61 Mishra S, Fiddick L. (2012). Beyond gains and losses: the effect of need on risky choice in framed decisions. J Pers Soc Psychol.
62 Murgaff V, Abraham C, McDermott M. (2007). Reducing friday alcohol comsumption among moderate, women drinkers: Evaluation of a brief evidence-based intervention. Alcohol Alcohol.
63 Murphy ST, Frank LB, Chatterjee JS, et al. (2013). Narrative versus Nonnarrative: The Role of Identification, Transportation, and Emotion in Reducing Health Disparities. J Commun.
64 Myers RE, Daskalakis C, Cocroft J, et al. (2005). Preparing African-American men in community primary care practices to decide whether or not to have prostate cancer screening. J Natl Med Assoc.
65 O’Brien K, Wright J, Conboy F, et al. (2000). The effect of orthodontic referral guidelines: a randomised controlled trial. Br Dent J.
66 Ornstein S, Nemeth LS, Jenkins RG, et al. (2010). Colorectal cancer screening in primary care: translating research into practice. Med Care.
67 Perria C, Mandolini D, Guerrera C, et al. (2007). Implementing a guideline for the treatment of type 2 diabetics: results of a cluster-randomized controlled trial (C-RCT). BMC Health Serv Res.
68 Poddar KH, Hosig KW, Anderson-Bill ES, et al. (2012). Dairy intake and related self-regulation improved in college students using online nutrition education. J Acad Nutr Diet.
69 Powers BJ, Danus S, Grubber JM, et al. (2011). The effectiveness of personalized coronary heart disease and stroke risk communication. Am Heart J.
70 Raynes-Greenow CH, Roberts CL, Nassar N, et al. (2009). Do audio-guided decision aids improve outcomes? A randomized controlled trial of an audio-guided decision aid compared with a booklet decision aid for Australian women considering labour analgesia. Health Expect.
71 Roumie CL, Grogan EL, Falbe W, et al. (2004). A three-part intervention to change the use of hormone replacement therapy in response to new evidence. Ann Intern Med.
72 Scales DC, Dainty K, Hales B, et al. (2011). A multifaceted intervention for quality improvement in a network of intensive care units: a cluster randomized trial. JAMA.
73 Schneeweiss S, Ratnapalan S. (2007). Impact of a multifaceted pediatric sedation course: self-directed learning versus a formal continuing medical education course to improve knowledge of sedation guidelines. CJEM.
74 Schnoor M, Meyer T, Suttorp N, et al. (2010). Development and evaluation of an implementation strategy for the German guideline on community-acquired pneumonia. Qual Saf Health Care.
75 Schwalm JD, Stacey D, Pericak D, et al. (2012). Radial artery versus femoral artery access options in coronary angiogram procedures: randomized controlled trial of a patient-decision aid. Circ Cardiovasc Qual Outcomes.
76 Searle J, Grover S, Santin A, et al. (2002). Randomised trial of an integrated educational strategy to reduce investigation rates in young women with dysfunctional uterine bleeding. Aust N Z J Obstet Gynaecol.
77 Shekelle PG, Kravitz RL, Beart J, et al. (2000). Are nonspecific practice guidelines potentially harmful? A randomized comparison of the effect of nonspecific versus specific guidelines on physician decision making. Health Serv Res.
78 Smith DH, Christensen DB, Stergachis A, et al. (1998). A randomized controlled trial of a drug use review intervention for sedative hypnotic medications. Med Care.
79 Søndergaard J, Andersen M, Støvring H, et al. (2003). Mailed prescriber feedback in addition to a clinical guideline has no impact: a randomised, controlled trial. Scand J Prim Health Care.
80 Thompson A, Sullivan SA, Barley M, et al. (2008). The DEBIT trial: an intervention to reduce antipsychotic polypharmacy prescribing in adult psychiatry wards - a cluster randomized controlled trial. Psychol Med.
81 Thompson DA, Joshi A, Hernandez RG, et al. (2012). Nutrition education via a touchscreen: a randomized controlled trial in Latino immigrant parents of infants and toddlers. Acad Pediatr.
82 Vallance J, Plotnikoff RC, Karvinen KH, et al. (2010). Understanding physical activity maintenance in breast cancer survivors. Am J Health Behav.
83 Vallance JK, Courneya KS, Plotnikoff RC, et al. (2008). Analyzing theoretical mechanisms of physical activity behavior change in breast cancer survivors: results from the activity promotion (ACTION) trial. Ann Behav Med.
84 van der Sanden WJ, Mettes DG, Plasschaert AJ, et al. (2005). Effectiveness of clinical practice guideline implementation on lower third molar management in improving clinical decision-making: a randomized controlled trial. Eur J Oral Sci.
85 van Genugten L, van Empelen P, Boon B, et al. (2012). Results from an online computer-tailored weight management intervention for overweight adults: randomized controlled trial. J Med Internet Res.
86 Welkenhuysen M, Evers-Kiebooms G, d’Ydewalle G. (2001). The language of uncertainty in genetic risk communication: framing and verbal versus numerical information. Patient Educ Couns.
87 Welkenhuysen M, Evers-Kiebooms G, d’Ydewalle G. (2001). The language of uncertainty in genetic risk communication: framing and verbal versus numerical information. Patient Educ Couns.
88 Williams-Piehota P, Pizarro J, Navarro Silvera SA, et al. (2006). Need for cognition and message complexity in motivating fruit and vegetable intake among callers to the cancer information service. Health Commun.
89 Windsor R, Woodby L, Miller T, et al. (2011). Effectiveness of smoking cessation and reduction in pregnancy treatment (SCRIPT) methods in Medicaid-supported prenatal care: Trial III. Health Educ Behav.
90 Wong SS, Thornton JG, Gbolade B, et al. (2006). A randomised controlled trial of a decision-aid leaflet to facilitate women’s choice between pregnancy termination methods. BJOG.
91 Yates K, Pena A. (2006). Comprehension of discharge information for minor head injury: a randomised controlled trial in New Zealand. N Z Med J.

## Wrong Outcome

(Outcomes for target audience did not include awareness of, knowledge about, discussions about, self-efficacy to use, or behavioral intentions to use or apply the evidence; outcomes for patients did not include health-related decisions or behaviors or clinical outcomes; ultimate outcomes for clinicians did not include behavior)

1 Baker R, Fraser RC, Stone M, et al. (2003). Randomised controlled trial of the impact of guidelines, prioritized review criteria and feedback on implementation of recommendations for angina and asthma. Br J Gen Pract.
2 Belia S, Fidler F, Williams J, et al. (2005). Researchers misunderstand confidence intervals and standard error bars. Psychol Methods.
3 Buller DB, Andersen PA, Walkosz BJ, et al. (2012). Enhancing industry-based dissemination of an occupational sun protection program with theory-based strategies employing personal contact. Am J Health Promot.
4 Riggs NR, Nakawatase M, Pentz MA. (2008). Promoting community coalition functioning: effects of Project STEP. Prev Sci.
5 Ryan GL, Skinner CS, Farrell D, et al. (2001). Examining the boundaries of tailoring: The utility of tailoring versus targeting mammography interventions for two distinct populations. Health Educ Res.
6 Steginga SK, Occhipinti S. (2004). The application of the heuristic-systematic processing model to treatment decision making about prostate cancer. Med Decis Making.
7 Yuksel N, Majumdar SR, Biggs C, et al. (2010). Community pharmacist-initiated screening program for osteoporosis: randomized controlled trial. Osteoporos Int.

## Wrong Evidence Source

(Did not provide evidence that was assembled, reviewed, and presented by a professional organization that was then used to make recommendations)

1 Amsallem E, Kasparian C, Cucherat M, et al. (2007). Evaluation of two evidence-based knowledge transfer interventions for physicians. A cluster randomized controlled factorial design trial: the CardioDAS Study. Fundam Clin Pharmacol.
2 Andersen MR, Yasui Y, Meischke H, et al. (2000). The effectiveness of mammography promotion by volunteers in rural communities. Am J Prev Med.
3 Azocar F, Cuffel B, Goldman W, et al. (2003). The impact of evidence-based guideline dissemination for the assessment and treatment of major depression in a managed behavioral health care organization. J Behav Health Ser Res.
4 Champion V, Maraj M, Hui S, et al. (2003). Comparison of tailored interventions to increase mammography screening in nonadherent older women. Prev Med.
5 Cousineau TM, Green TC, Corsini E, et al. (2008). Online psychoeducational support for infertile women: a randomized controlled trial. Hum Reprod.
6 Di Noia J, Schwinn TM, Dastur ZA, et al. (2003). The relative efficacy of pamphlets, CD-ROM, and the Internet for disseminating adolescent drug abuse prevention programs: an exploratory study. Prev Med.
7 Funk M, Wutzke S, Kaner E, et al. (2005). A multicountry controlled trial of strategies to promote dissemination and implementation of brief alcohol intervention in primary health care: findings of a World Health Organization collaborative study. J Stud Alcohol.
8 Gordon JS, Andrews JA, Lichtenstein E, et al. (2005). Disseminating a smokeless tobacco cessation intervention model to dental hygienists: a randomized comparison of personalized instruction and self-study methods. Health Psychol.
9 Hall L, Eccles M, Barton R, et al. (2001). Is untargeted outreach visiting in primary care effective? A pragmatic randomized controlled trial. J Public Health Med.
10 Lipkus IM, Rimer BK, Halabi S, et al. (2000). Can tailored interventions increase mammography use among HMO women?. Am J Prev Med.
11 Man-Son-Hing M, O’Connor AM, Drake E, et al. (2002). The effect of qualitative vs. quantitative presentation of probability estimates on patient decision-making: a randomized trial. Health Expect.
12 McDonald MV, Pezzin LE, Feldman PH, et al. (2005). Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage.
13 Mishel MH, Germino BB, Lin L, et al. (2009). Managing uncertainty about treatment decision making in early stage prostate cancer: a randomized clinical trial. Patient Educ Couns.
14 Nolan RP, Upshur RE, Lynn H, et al. (2011). Therapeutic benefit of preventive telehealth counseling in the Community Outreach Heart Health and Risk Reduction Trial. Am J Cardiol.
15 Oyeku SO, Feldman HA, Ryan K, et al. (2010). Primary care clinicians’ knowledge and confidence about newborn screening for sickle cell disease: Randomized assessment of educational strategies. J Natl Med Assoc.
16 Prins RG, Brug J, van Empelen P, et al. (2012). Effectiveness of YouRAction, an Intervention to Promote Adolescent Physical Activity Using Personal and Environmental Feedback: A Cluster RCT. Plos One.
17 Romero A, Alonso C, Marín I, et al. (2005). Rev Esp Cardiol.
18 Ruf D, Berner M, Kriston L, et al. (2010). Cluster-randomized controlled trial of dissemination strategies of an online quality improvement programme for alcohol-related disorders. Alcohol Alcohol.
19 Schectman JM, Schroth WS, Verme D, et al. (2003). Randomized controlled trial of education and feedback for implementation of guidelines for acute low back pain. J Gen Intern Med.
20 Schroter S, Jenkins RD, Playle RA, et al. (2011). Evaluation of an online interactive Diabetes Needs Assessment Tool (DNAT) versus online self-directed learning: a randomised controlled trial. BMC Med Educ.
21 Seager JM, Howell-Jones RS, Dunstan FD, et al. (2006). A randomised controlled trial of clinical outreach education to rationalise antibiotic prescribing for acute dental pain in the primary care setting. Br Dent J.
22 Taplin SH, Barlow WE, Ludman E, et al. (2000). Testing reminder and motivational telephone calls to increase screening mammography: A randomized study. J Natl Cancer Inst.
23 Valanis BG, Glasgow RE, Mullooly J, et al. (2002). Screening HMO women overdue for both mammograms and Pap tests. Prev Med.
24 van Eijk ME, Avorn J, Porsius AJ, et al. (2001). Reducing prescribing of highly anticholinergic antidepressants for elderly people: randomised trial of group versus individual academic detailing. BMJ.
25 Winterbottom AE, Bekker HL, Conner M, et al. (2012). Patient stories about their dialysis experience biases others’ choices regardless of doctor’s advice: an experimental study. Nephrology Dialysis Transplantation.
26 Witt K, Knudsen E, Ditlevsen S, et al. (2004). Academic detailing has no effect on prescribing of asthma medication in Danish general practice: a 3-year randomized controlled trial with 12-monthly followups. Fam Pract.

## Wrong Country

(Any country not specified for inclusion)

1 Cuello Garcia CA, Pacheco Alvarado KP, Perez Gaxiola G. (2011). Grading recommendations in clinical practice guidelines: randomised experimental evaluation of four different systems. Arch Dis Child.
2 Kulier R, Gulmezoglu AM, Zamora J, et al. (2012). Effectiveness of a clinically integrated e-learning course in evidence-based medicine for reproductive health training: a randomized trial. JAMA.
3 Lewis E, Mayer JA, Slymen D, et al. (2005). Disseminating a sun safety program to zoological parks: the effects of tailoring. Health Psychol.
4 Shakespeare TP, Gebski V, Tang J, et al. (2008). Influence of the way results are presented on research interpretation and medical decision making: the PRIMER collaboration randomized studies. Med Decis Making.

## Wrong Study Design

(Nonrandomized trials, nonexperimental studies, single pre/post designs, qualitative research)

1 Denton GD, Smith J, Faust J, et al. (2001). Comparing the efficacy of staff versus housestaff instruction in an intervention to improve hypertension management. Acad Med.
2 Dobbins M, Robeson P, Ciliska D, et al. (2009). A description of a knowledge broker role implemented as part of a randomized controlled trial evaluating three knowledge translation strategies. Implementation Science.
3 Frosch DL, Kaplan RM, Felitti V. (2001). The evaluation of two methods to facilitate shared decision making for men considering the prostate-specific antigen test. J Gen Intern Med.
4 Frosch DL, Kaplan RM, Felitti VJ. (2003). A randomized controlled trial comparing internet and video to facilitate patient education for men considering the prostate specific antigen test. J Gen Intern Med.
5 Ling BS, Schoen RE, Trauth JM, et al. (2009). Physicians encouraging colorectal screening: a randomized controlled trial of enhanced office and patient management on compliance with colorectal cancer screening. Arch Intern Med.
6 Rodriguez-Salvanes F, Novella B, Fernandez Luque MJ, et al. (2011). Efficacy of a strategy for implementing a guideline for the control of cardiovascular risk in a primary healthcare setting: the SIRVA2 study a controlled, blinded community intervention trial randomised by clusters. BMC Fam Pract.
7 Seers K, Cox K, Crichton NJ, et al. (2012). FIRE (Facilitating Implementation of Research Evidence): a study protocol. Implementation science : IS.
8 Teigen KH, Brun W. (1999). The directionality of verbal probability expressions: Effects on decisions, predictions, and probabilistic reasoning. Organ Behav Hum Decis Process.

## Wrong Sample Size

(N < 100 total individuals in the study)

1 Akl EA, Maroun N, Guyatt G, et al. (2007). Symbols were superior to numbers for presenting strength of recommendations to health care consumers: a randomized trial. J Clin Epidemiol.
2 Ibrekk H, Morgan MG. (1987). Graphical communication of uncertain quantities to nontechnical people. Risk Anal.
3 Jaffe-Katz A, Budescu DV, Wallsten TS. (1989). Timed magnitude comparisons of numerical and nonnumerical expressions of uncertainty. Mem Cognit.
4 Kuhn KM. (1997). Communicating uncertainty: framing effects on response to vague probabilities. Organ Behav Hum Decis Process.
5 Larkey LK, Gonzalez J. (2007). Storytelling for promoting colorectal cancer prevention and early detection among Latinos. Patient Educ Couns.
6 Liaw ST, Sulaiman ND, Barton CA, et al. (2008). An interactive workshop plus locally adapted guidelines can improve general practitioners asthma management and knowledge: a cluster randomised trial in the Australian setting. BMC Fam Pract.
7 White M, Michaud G, Pachev G, et al. (2004). Randomized trial of problem-based versus didactic seminars for disseminating evidence-based guidelines on asthma management to primary care physicians. J Contin Educ Health Professions.

## High Risk of Bias

1 Church TR, Yeazel MW, Jones RM, et al. (2004). A randomized trial of direct mailing of fecal occult blood tests to increase colorectal cancer screening. J Natl Cancer Inst.
2 Daniels EC, Bacon J, Denisio S, et al. (2005). Translation squared: improving asthma care for high-disparity populations through a safety net practice-based research network. J Asthma.
3 Figueiras A, Sastre I, Tato F, et al. (2001). One-to-one versus group sessions to improve prescription in primary care: a pragmatic randomized controlled trial. Med Care.
4 Johnson BB, Slovic P. (1995). Presenting uncertainty in health risk assessment: Initial studies of its effects on risk perception and trust. Risk Anal.
5 Manfredi C, Cho YI, Warnecke R, et al. (2011). Dissemination strategies to improve implementation of the PHS smoking cessation guideline in MCH public health clinics: experimental evaluation results and contextual factors. Health Educ Res.
6 Renzi PM, Ghezzo H, Goulet S, et al. (2006). Paper stamp checklist tool enhances asthma guidelines knowledge and implementation by primary care physicians. Can Respir J.
7 van Driel ML, Coenen S, Dirven K, et al. (2007). What is the role of quality circles in strategies to optimise antibiotic prescribing? A pragmatic cluster-randomised controlled trial in primary care. Qual Saf Health Care.
8 van Steenkiste B, van der Weijden T, Stoffers HE, et al. (2007). Improving cardiovascular risk management: a randomized, controlled trial on the effect of a decision support tool for patients and physicians. Eur J Cardiovasc Prev Rehabil.
9 Varonen H, Rautakorpi UM, Nyberg S, et al. (2007). Implementing guidelines on acute maxillary sinusitis in general practice--a randomized controlled trial. Fam Pract.
10 Wadland WC, Soffelmayr B, Ives K. (2001). Enhancing smoking cessation of low-income smokers in managed care. J Fam Pract.