# Appendix B Search Strategies

## May 18 2012 PsycInfo Communication (KQ 1) and Uncertainty (KQ 3) Final Searches

RCTs+Experimental study types: Uncertainty line #47 (2 results)

RCTs for Communication Line #16 (338 results)

SRs/MAs: Communication = 33 (line 41) [used for background only, not as a potential include]

SR/MAs: Uncertainty = 0 [used for background only, not as a potential include]

Search ID# | Search Terms | Search Options | Actions
S47 | S35 or S46 | Search modes - Boolean/Phrase | (2)
S46 | S34 and S45 | Search modes - Boolean/Phrase | (1)
S45 | S42 or S43 or S44 | Search modes - Boolean/Phrase | (12778)
S44 | “controlled clinical trial” OR “controlled clinical trials” | Search modes - Boolean/Phrase | (1816)
S43 | “cross-over study” OR “cross-over studies” | Search modes - Boolean/Phrase | (418)
S42 | “comparative study” OR “comparative studies” | Search modes - Boolean/Phrase | (10556)
S41 | S37 or S40 | Search modes - Boolean/Phrase | (33)
S40 | S11 | Limiters - Methodology: -Systematic Review, -Meta Analysis Search modes - Boolean/Phrase | (24)
S39 | S34 | Limiters - Methodology: -Systematic Review, -Meta Analysis Search modes - Boolean/Phrase | (0)
S38 | S34 AND S36 | Limiters - Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | (0)
S37 | S36 and S11 | Search modes - Boolean/Phrase | (28)
S36 | (DE “Literature Review” and systematic) OR “systematic review” OR (review AND systematic) OR “meta-analysis” | Search modes - Boolean/Phrase | (24095)
S35 | S34 AND S15 | Limiters - Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | (2)
S34 | S33 | Limiters - Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | (249)
S33 | S31 and S32 | Search modes - Boolean/Phrase | (754)
S32 | DE “Communication” | Search modes - Boolean/Phrase | (14325)
S31 | S17 or S18 or S19 or S20 or S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30 | Search modes - Boolean/Phrase | (93893)
S30 | “low evidence” | Search modes - Boolean/Phrase | (18)
S29 | “conflicting evidence” | Search modes - Boolean/Phrase | (387)
S28 | “missing evidence” | Search modes - Boolean/Phrase | (14)
S27 | “strength of evidence” | Search modes - Boolean/Phrase | (241)
S26 | equipoise | Search modes - Boolean/Phrase | (83)
S25 | uncertainty | Search modes - Boolean/Phrase | (17611)
S24 | ambigu* | Search modes - Boolean/Phrase | (19891)
S23 | complexity | Search modes - Boolean/Phrase | (47888)
S22 | vagueness | Search modes - Boolean/Phrase | (627)
S21 | precision | Search modes - Boolean/Phrase | (7110)
S20 | “net benefit” | Search modes - Boolean/Phrase | (168)
S19 | “risk of bias” | Search modes - Boolean/Phrase | (92)
S18 | DE “Statistical Reliability” | Search modes - Boolean/Phrase | (3124)
S17 | DE “Uncertainty” | Search modes - Boolean/Phrase | (3918)
S16 | S15 AND S10 | Search modes - Boolean/Phrase | (338)
S15 | S12 OR S14 | Search modes - Boolean/Phrase | (20758)
S14 | control* AND (random* AND trial*) | Search modes - Boolean/Phrase | (20133)
S13 | S10 and S12 | Search modes - Boolean/Phrase | (192)
S12 | “randomized controlled trial” OR RCT* | Search modes - Boolean/Phrase | (7665)
S11 | S9 and S10 | Search modes - Boolean/Phrase | (3711)
S10 | S8 | Limiters - Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | (15971)
S9 | Intervention OR control OR (random* AND trial*) | Limiters - Publication Year from: 2000–2012 Search modes - Boolean/Phrase | (322632)
S8 | S1 or S2 or S3 or S4 or S5 or S6 | Limiters - Publication Year from: 2000–2012 Search modes - Boolean/Phrase | (34132)
S7 | S1 or S2 or S3 or S4 or S5 or S6 | Search modes - Boolean/Phrase | (54096)
S6 | MM “Health Education” | Search modes - Boolean/Phrase | (7077)
S5 | DE “Persuasive Communication” | Search modes - Boolean/Phrase | (4204)
S4 | MM “Narratives” | Search modes - Boolean/Phrase | (8157)
S3 | DE “Client Education” | Search modes - Boolean/Phrase | (2730)
S2 | MM “Decision Making” | Search modes - Boolean/Phrase | (31861)
S1 | MM “Information Dissemination” | Search modes - Boolean/Phrase | (617)

## May 19–20 2012 PubMed Final CEDT Searches: KQ 1, KQ 2 and KQ 3

Summary:

KQ 1: RCTs = 3981

SRs+MAs(non-RCTs) = 165 [used for background only, not as a potential include]

KQ 2: RCTs = 1555, after duplicates with KQ 1 removed = 401; 1154 imported to duplicates library

SRs+MAs (non-RCTs) = 91, after duplicates with KQ 1 removed = 61; 30 imported to duplicates library [used for background only, not as a potential include]

KQ 3 done 5–20 to expand to all experimental study types per Stacey:

Experimental Study Types including RCTs = 577, after duplicates with KQ 1 and/or KQ 2 removed= 551; 26 imported to duplicates library

SRs+MAs (Non-RCTs)= 17, after duplicates with KQ 1 and/or KQ 2 removed = 14; 3 imported to duplicates library [used for background only, not as a potential include]

Total from PubMed RCTs (& exp studies of KQ 3) = 4933 + 1180 in Duplicates library = 6113

Total from PubMed SR+MA = 240 + 33 in Duplicates library = 275 [used for background only, not as a potential include]

### KQ 1 (Communication) Search

Search | Query | Items found
#1 | Search “Information Dissemination/methods”[Majr] | 1437
#2 | Search “Decision Making”[Majr] | 44117
#3 | Search “Patient Education as Topic”[Mesh] | 63946
#4 | Search “Narration”[Majr] | 1402
#5 | Search “Persuasive Communication”[Mesh] | 2596
#6 | Search “Health Education/methods”[Majr] | 14580
#7 | Search #1 or #2 or #3 or #4 or #5 or #6 | 118367
#8 | Search #1 or #2 or #3 or #4 or #5 or #6 Filters: Humans | 109909
#9 | Search #1 or #2 or #3 or #4 or #5 or #6 Filters: Humans; English | 98287
#10 | Search #1 or #2 or #3 or #4 or #5 or #6 Filters: Humans; English; Adult: 19+ years | 37365
#11 | Search #1 or #2 or #3 or #4 or #5 or #6 Filters: Publication date from 2000/01/01; Humans; English; Adult: 19+ years | 25606
#12 | Search #1 or #2 or #3 or #4 or #5 or #6 Filters: Publication date from 2000/01/01; Humans; Comment; English; Adult: 19+ years | 335
#13 | Search #1 or #2 or #3 or #4 or #5 or #6 Filters: Publication date from 2000/01/01; Humans; Comment; Editorial; English; Adult: 19+ years | 448
#14 | Search #1 or #2 or #3 or #4 or #5 or #6 Filters: Publication date from 2000/01/01; Humans; Comment; Editorial; Letter; English; Adult: 19+ years | 687
#15 | Search #1 or #2 or #3 or #4 or #5 or #6 Filters: Publication date from 2000/01/01; Humans; Comment; Editorial; Letter; News; English; Adult: 19+ years | 767
#16 | Search #11 NOT #15 | 24839
#17 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 476184
#18 | Search #16 and #17 | 3981
#19 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 91360
#20 | Search #16 and #19 | 243
#21 | Search #20 NOT #18 | 165

### May 19, 2012 PubMed KQ 2 (Dissemination) Search

Search | Query | Items found
#1 | Search “Information Dissemination”[Mesh] | 7921
#2 | Search “Diffusion of Innovation”[Mesh] | 13481
#3 | Search “Evidence-Based Medicine/education”[Mesh] | 1104
#4 | Search “Information Services/utilization”[Mesh] | 1279
#5 | Search “Practice Guidelines as Topic/standards”[Mesh] | 4292
#6 | Search “Guideline Adherence/statistics and numerical data”[Mesh] | 2311
#7 | Search “Patient Education as Topic/methods”[Mesh] | 11427
#8 | Search “Physician’s Practice Patterns/standards”[Mesh] | 3308
#9 | Search “Physician’s Practice Patterns/statistics and numerical data”[Mesh] | 8826
#10 | Search “Physician’s Practice Patterns/trends”[Mesh] | 2846
#11 | Search “Social Marketing”[Mesh] | 1756
#12 | Search “social marketing”[tiab] | 1106
#13 | Search “academic detailing”[tiab] | 274
#14 | Search “dissemination strategy”[tiab] | 72
#15 | Search “dissemination strategies”[tiab] | 125
#16 | Search disseminat*[ti] AND guideline*[ti] | 119
#17 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 | 56082
#18 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 Filters: Humans | 48743
#19 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 Filters: Humans; English | 44665
#20 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 Filters: Humans; English; Adult: 19+ years | 13841
#21 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 Filters: Publication date from 2000/01/01; Humans; English; Adult: 19+ years | 11150
#22 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 Filters: Publication date from 2000/01/01; Humans; Comment; English; Adult: 19+ years | 151
#23 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 Filters: Publication date from 2000/01/01; Humans; Comment; Editorial; English; Adult: 19+ years | 204
#24 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 Filters: Publication date from 2000/01/01; Humans; Comment; Editorial; Letter; English; Adult: 19+ years | 324
#25 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 Filters: Publication date from 2000/01/01; Humans; Comment; Editorial; Letter; News; English; Adult: 19+ years | 362
#26 | Search #21 NOT #25 | 10788
#27 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 476184
#28 | Search #26 and #27 | 1555
#29 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 91360
#30 | Search #26 and #29 | 121
#31 | Search #30 NOT #28 | 91

### May 20, 2012 PubMed KQ 3 (Uncertainty) Search To Expand to Experimental Study Types

Search | Query | Items found
#1 | Search “Uncertainty”[Mesh] | 4566
#2 | Search “Research Design/statistics and numerical data”[Mesh] | 1286
#3 | Search “Therapeutic Equipoise”[Mesh] | 58
#4 | Search “Bias (Epidemiology)”[Mesh] | 44913
#5 | Search “low evidence” | 66
#6 | Search “conflicting evidence” | 1594
#7 | Search “missing evidence” | 52
#8 | Search “strength of evidence” | 866
#9 | Search uncertainty | 35336
#10 | Search ambigu* | 20766
#11 | Search complexity | 66735
#12 | Search vagueness | 302
#13 | Search precision | 64453
#14 | Search “risk of bias” | 1551
#15 | Search “net benefit” | 803
#16 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 | 232698
#17 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 Filters: Humans | 151010
#18 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 Filters: Humans; English | 139800
#19 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 Filters: Humans; English; Adult: 19+ years | 48967
#20 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 Filters: Humans; Comment; English; Adult: 19+ years | 502
#21 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 Filters: Humans; Comment; Editorial; English; Adult: 19+ years | 558
#22 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 Filters: Humans; Comment; Editorial; Letter; English; Adult: 19+ years | 688
#23 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 Filters: Humans; Comment; Editorial; Letter; News; English; Adult: 19+ years | 701
#24 | Search #19 NOT #23 | 48266
#25 | Search “Communication”[Mesh] | 332362
#26 | Search #24 and #25 | 3172
#27 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 476184
#28 | Search #26 and #27 | 194
#29 | Search “Comparative Study” [Publication Type] OR “Controlled Clinical Trial” [Publication Type] OR “Cross-Over Studies”[Mesh] | 1641835
#30 | Search #26 and #29 | 423
#31 | Search #28 or #30 | 577
#32 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 91379
#33 | Search #26 and #32 | 33
#34 | Search #33 NOT #31 | 17

## May 20, 2012 Cochrane Library and Cochrane Trials Registry Searches

### Cochrane Library KQ 1 Search

ID | Search | Hits
#1 | “Information Dissemination/methods”[Majr] | 34
#2 | “Decision Making”[Majr] | 4713
#3 | “Patient Education as Topic”[Mesh] | 5620
#4 | “Narration”[Majr] | 93
#5 | “Persuasive Communication”[Mesh] | 212
#6 | “Health Education/methods”[Majr] | 957
#7 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6) | 11230
#8 | (#7), from 2000 to 2012 | 8489
#9 | “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 363212
#10 | (#8 AND #9) | 6161
#11 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 34619
#12 | (#8 AND #11) | 1707
#13 | (#12 AND NOT #10) | 828

### Cochrane Library KQ 2 Search

ID | Search | Hits
#1 | “Information Dissemination”[Mesh] | 218
#2 | “Diffusion of Innovation”[Mesh] | 124
#3 | “Evidence-Based Medicine/education”[Mesh] | 51
#4 | “Information Services/utilization”[Mesh] | 9
#5 | “Practice Guidelines as Topic/standards”[Mesh] | 81
#6 | “Guideline Adherence/statistics and numerical data”[Mesh] | 0
#7 | “Patient Education as Topic/methods”[Mesh] | 1855
#8 | “Physician’s Practice Patterns/standards”[Mesh] | 93
#9 | “Physician’s Practice Patterns/statistics and numerical data”[Mesh] | 0
#10 | “Physician’s Practice Patterns/trends”[Mesh] | 16
#11 | “Social Marketing”[Mesh] | 193
#12 | “social marketing”[tiab] | 193
#13 | “academic detailing”[tiab] | 164
#14 | “dissemination strategy”[tiab] | 22
#15 | “dissemination strategies”[tiab] | 31
#16 | disseminat*[ti] AND guideline*[ti] | 3685
#17 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16) | 6233
#18 | (#17), from 2000 to 2012 | 5264
#19 | “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 363212
#20 | (#18 AND #19) | 2786
#21 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 34619
#22 | (#18 AND #21) | 2523
#23 | (#22 AND NOT #20) | 1501

### Cochrane Library KQ 3 Search

ID | Search | Hits
#1 | “Uncertainty”[Mesh] | 6758
#2 | “Research Design/statistics and numerical data”[Mesh] | 0
#3 | “Therapeutic Equipoise”[Mesh] | 1
#4 | “Bias (Epidemiology)”[Mesh] | 543
#5 | “low evidence” | 24
#6 | “conflicting evidence” | 344
#7 | “missing evidence” | 5
#8 | “strength of evidence” | 476
#9 | uncertainty | 7662
#10 | ambigu* | 737
#11 | complexity | 1542
#12 | vagueness | 13
#13 | precision | 2621
#14 | “risk of bias” | 7335
#15 | “net benefit” | 352
#16 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15) | 17326
#17 | “Communication”[Mesh] | 7106
#18 | (#16 AND #17) | 2144
#19 | “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 363212
#20 | (#18 AND #19) | 1776
#21 | “Comparative Study” OR “Controlled Clinical Trial” OR “Cross-Over Studies”[Mesh] | 224908
#22 | (#18 AND #21) | 1273
#23 | (#20 OR #22) | 1837
#24 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 34619
#25 | (#18 AND #24) | 1980
#26 | (#25 AND NOT #23) | 231

## Web of Science Searches Forward-Tracing (Citations Counts) for Key Reviews, KQ 1 and KQ 3, May 21–22, 2012

### KQ 1 Web of Science Searches

- Kühberger A. The Influence of Framing on Risky Decisions: A Meta-analysis.
  Organ Behav Hum Decis Process. 1998 Jul;75(1):23–55. PMID: 9719656.
  Cited by = 219, 218 imported to SR+MA database, 1 dup [used for background only, not as a potential include]
- Noar, S. M., Harrington, N. G., Van Stee, S. K., & Aldrich, R. S. (2011). Tailored health communication to change lifestyle behaviors. American Journal of Lifestyle Medicine, 5(2), 112–122.
  Cited by = not in WoS. Cited by 8 in Google Scholar. All imported
- Allen, M., & Preiss, R. W. (1997). Comparing the persuasiveness of narrative and statistical evidence using meta-analysis. Communication Research Reports, 14, 125–133.
  Cited by = not in WoS, Searched Google Scholar and downloaded 81 references. All imported
- Title: A meta-analysis of computer-tailored interventions for health behavior change
  Author(s): Krebs Paul; Prochaska James O.; Rossi Joseph S.
  Source: PREVENTIVE MEDICINE Volume: 51 Issue: 3–4 Pages: 214–221 DOI: 10.1016/j.ypmed.2010.06.004 Published: SEP–OCT 2010
  Cited by= 15, all imported.
- Title: A systematic review of three approaches for constructing physical activity messages: What messages work and what improvements are needed?
  Author(s): Latimer Amy E.; Brawley Lawrence R.; Bassett Rebecca L.
  Source: INTERNATIONAL JOURNAL OF BEHAVIORAL NUTRITION AND PHYSICAL ACTIVITY Volume: 7 Article Number: 36 DOI: 10.1186/1479-5868-7-36 Published: MAY 11 2010
  Cited by = 12, 8 imported, 4 dups discarded
- Title: Does tailoring matter? Meta-analytic review of tailored print health Behavior change interventions
  Author(s): Noar Seth M.; Benac Christina N.; Harris Melissa S.
  Source: PSYCHOLOGICAL BULLETIN Volume: 133 Issue: 4 Pages: 673–693 DOI: 10.1037/0033-2909.133.4.673 Published: JUL 2007
  Cited by = 191, 186 imported, 5 discarded
- Title: Does narrative information bias individual’s decision making? A systematic review
  Author(s): Winterbottom Anna; Bekker Hilary L.; Conner Mark; et al.
  Source: SOCIAL SCIENCE & MEDICINE Volume: 67 Issue: 12 Pages: 2079–2088 DOI: 10.1016/j.socscimed.2008.09.037 Published: DEC 2008
  Cited by= 20, 18 imported, 2 deleted
- O’Keefe, DJ & Jensen, JD ( 2006 ). The advantages of compliance or the disadvantages of noncompliance? A meta-analytic review of the relative persuasive effectiveness of gain-framed and loss-framed messages. Communication Yearbook, 30, 1 – 43
  Cited by = Not in WoS not PubMed. Cited by 72 in Google Scholar. 68 imported. 4 dups discarded
- Title: The relative persuasiveness of gain-framed and loss-framed messages for encouraging disease prevention behaviors: A meta-analytic review
  Author(s): O’Keefe Daniel J.; Jensen Jakob D.
  Source: JOURNAL OF HEALTH COMMUNICATION Volume: 12 Issue: 7 Pages: 623–644 DOI: 10.1080/10810730701615198 Published: OCT–NOV 2007
  Cited by = 46, 32 imported, and 14 dups discarded
- Title: The Relative Persuasiveness of Gain-Framed and Loss-Framed Messages for Encouraging Disease Detection Behaviors: A Meta-Analytic Review
  Author(s): O’Keefe Daniel J.; Jensen Jakob D.
  Source: JOURNAL OF COMMUNICATION Volume: 59 Issue: 2 Pages: 296–316 DOI: 10.1111/j.1460-2466.2009.01417.x Published: JUN 2009
  Cited by = 14, 3 imported and 11 dups discarded
- Title: What works with men? A systematic review of health promoting interventions targeting men
  Author(s): Robertson Lynn M.; Douglas Flora; Ludbrook Anne; et al.
  Source: BMC HEALTH SERVICES RESEARCH Volume: 8 Article Number: 141 DOI: 10.1186/1472-6963-8-141 Published: JUL 3 2008
  Cited by = 16, 15 imported and 1 dup discarded

### KQ 3 Web of Science Searches

- Politi MC, Han PK, Col NF. Communicating the uncertainty of harms and benefits of medical interventions. Med Decis Making. 2007 Sep–Oct;27(5):681–95. PMID: 17873256.
  Cited by = 50, 48 imported to SR+MA database, 2 duplicates [used for background only, not as a potential include]
- Babrow AS. The many meanings of uncertainty in illness: toward a systematic accounting. Health communication. 10(1): 1–23.
  Cited by = 46, 45 imported to SR+MA database, 1 duplicate [used for background only, not as a potential include]
- Han PK. Varieties of uncertainty in healthcare: a conceptual taxonomy. Medical Decision Making Epub ahead for print Jan 18 2011.
  Cited by = not in WoS. Cited by 2 in Google Scholar.

## March 15, 2013 PsycINFO Communication (KQ 1) and Uncertainty (KQ 3) Final Searches

KQ 1: RCTs for communication—line #S45: 0 results for 2013

KQ 3: RCTs and other experimental study types, line #S44: 0 results for 2013

PsycInfo KQ 1 and KQ 3 search:

Last Run Via Interface: EBSCOhost, Search Screen – Advance Search Database—PsycINFO

Search ID# | Search Terms | Search Options | Actions
S45 | S18 | Limiters - Published Date from: 20130101–20131231 Search modes - Boolean/Phrase | 0
S44 | S37 OR S42 | Limiters - Published Date from: 20130101–20131231 Search modes - Boolean/Phrase | 0
S43 | S37 OR S42 | Search modes - Boolean/Phrase | 2
S42 | S36 AND S41 | Search modes - Boolean/Phrase | 1
S41 | S38 OR S39 OR S40 | Search modes - Boolean/Phrase | 13,402
S40 | “controlled clinical trial” OR “controlled clinical trials” | Search modes - Boolean/Phrase | 1,948
S39 | “cross-over study” OR “cross-over studies” | Search modes - Boolean/Phrase | 441
S38 | “comparative study” OR “comparative studies” | Search modes - Boolean/Phrase | 11,027
S37 | S15 AND S36 | Search modes - Boolean/Phrase | 2
S36 | S33 AND S34 | Limiters - English; Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | 281
S35 | S33 AND S34 | Search modes - Boolean/Phrase | 818
S34 | DE “Communication” | Search modes - Boolean/Phrase | 15,292
S33 | S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 | Search modes - Boolean/Phrase | 100,215
S32 | “low evidence” | Search modes - Boolean/Phrase | 19
S31 | “conflicting evidence” | Search modes - Boolean/Phrase | 413
S30 | “missing evidence” | Search modes - Boolean/Phrase | 18
S29 | “strength of evidence” | Search modes - Boolean/Phrase | 267
S28 | equipoise | Search modes - Boolean/Phrase | 98
S27 | uncertainty | Search modes - Boolean/Phrase | 19,152
S26 | ambigu* | Search modes - Boolean/Phrase | 20,998
S25 | complexity | Search modes - Boolean/Phrase | 51,060
S24 | vagueness | Search modes - Boolean/Phrase | 662
S23 | precision | Search modes - Boolean/Phrase | 7,685
S22 | “net benefit” | Search modes - Boolean/Phrase | 187
S21 | “risk of bias” | Search modes - Boolean/Phrase | 133
S20 | DE “Statistical Reliability” | Search modes - Boolean/Phrase | 3,164
S19 | DE “Uncertainty” | Search modes - Boolean/Phrase | 4,342
S18 | S16 AND S17 | Search modes - Boolean/Phrase | 4
S17 | “Comparative effectiveness” OR “Evidence-based” OR “Evidence based” OR Recommendations OR Recommendation | Search modes - Boolean/Phrase | 78,747
S16 | S9 AND S15 | Search modes - Boolean/Phrase | 29
S15 | S12 OR S14 | Search modes - Boolean/Phrase | 22,708
S14 | control* AND (random* AND trial*) | Search modes - Boolean/Phrase | 22,638
S13 | S9 AND S12 | Limiters - Published Date from: 20120401–20131231 Search modes - Boolean/Phrase | 17
S12 | “randomized controlled trial” OR RCT* | Limiters - Published Date from: 20120401–20131231 Search modes - Boolean/Phrase | 929
S11 | S9 and S10 | Limiters - Published Date from: 20120401–20131231 Search modes - Boolean/Phrase | 325
S10 | Intervention OR control OR (random* AND trial*) | Limiters - Published Date from: 20120401–20131231 Search modes - Boolean/Phrase | 25,145
S9 | S8 | Limiters - English; Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | 1,446
S8 | S1 or S2 or S3 or S4 or S5 or S6 | Limiters - Published Date from: 20120401–20131231 Search modes - Boolean/Phrase | 2,479
S7 | S1 or S2 or S3 or S4 or S5 or S6 | Search modes - Boolean/Phrase | 58,462
S6 | MM “Health Education” | Search modes - Boolean/Phrase | 7,491
S5 | DE “Persuasive Communication” | Search modes - Boolean/Phrase | 0
S4 | MM “Narratives” | Search modes - Boolean/Phrase | 8,861
S3 | DE “Client Education” | Search modes - Boolean/Phrase | 2,834
S2 | MM “Decision Making” | Search modes - Boolean/Phrase | 34,846
S1 | MM “Information Dissemination” | Search modes - Boolean/Phrase | 697

## March 15, 2013 Pub Med Final CEDT Searches: KQ 1, KQ 2 and KQ 3

Only RCTS searches, limited in the KQ 1 and KQ 2 strategies to the following CER terms this time as part of the search instead of as a search within the EndNote files:

“Comparative effectiveness” OR “Evidence-based” OR “Evidence based” OR Recommendations OR Recommendation

### PubMed KQ 1

Search | Query | Items found
#1 | Search “Information Dissemination/methods”[Majr] | 1647
#2 | Search “Decision Making”[Majr] | 47231
#3 | Search “Patient Education as Topic”[Mesh] | 66206
#4 | Search “Narration”[Majr] | 1559
#5 | Search “Persuasive Communication”[Mesh] | 2718
#6 | Search “Health Education/methods”[Majr] | 15326
#7 | Search (#1 or #2 or #3 or #4 or #5 or #6) | 124440
#8 | Search (#1 or #2 or #3 or #4 or #5 or #6) Filters: Humans | 115539
#9 | Search (#1 or #2 or #3 or #4 or #5 or #6) Filters: Humans; English | 103456
#10 | Search (#1 or #2 or #3 or #4 or #5 or #6) Filters: Humans; English; Adult: 19+ years | 39722
#11 | Search (#10) AND (“2013/01/05”[Date - Entrez]: “3000”[Date - Entrez]) | 30
#12 | Search (comment[pt] OR editorial[pt] OR letter[pt] or news[pt]) | 1362908
#13 | Search (#11 not #12) | 29
#14 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh]) | 500670
#15 | Search (#13 and #14) | 6
#16 | Search (“Comparative effectiveness” OR “Evidence-based” OR “Evidence based” OR Recommendations OR Recommendation) | 211691
#17 | Search (#15 and #16) | 0

### PubMed KQ 2

Search | Query | Items found
#1 | Search “Information Dissemination”[Mesh] | 8710
#2 | Search “Diffusion of Innovation”[Mesh] | 14220
#3 | Search “Evidence-Based Medicine/education”[Mesh] | 1145
#4 | Search “Information Services/utilization”[Mesh] | 1203
#5 | Search “Practice Guidelines as Topic/standards”[Mesh] | 4680
#6 | Search (“Guideline Adherence/statistics and numerical data”[Mesh]) | 2716
#7 | Search “Patient Education as Topic/methods”[Mesh] | 12019
#8 | Search “Physician’s Practice Patterns/standards”[Mesh] | 3571
#9 | Search (“Physician’s Practice Patterns/statistics and numerical data”[Mesh]) | 9663
#10 | Search “Physician’s Practice Patterns/trends”[Mesh] | 3045
#11 | Search “Social Marketing”[Mesh] | 1913
#12 | Search “social marketing”[tiab] | 1178
#13 | Search “academic detailing”[tiab] | 290
#14 | Search “dissemination strategy”[tiab] | 80
#15 | Search “dissemination strategies”[tiab] | 145
#16 | Search (disseminat*[ti] AND guideline*[ti]) | 122
#17 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16) | 60167
#18 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16) Filters: Humans | 52434
#19 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16) Filters: Humans; English | 48133
#20 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16) Filters: Humans; English; Adult: 19+ years | 15129
#21 | Search (#20) AND (“2013”[Date - Entrez]: “3000”[Date - Entrez]) | 10
#22 | Search (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt]) | 1362908
#23 | Search (#21 not #22) | 10
#24 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh]) | 500670
#25 | Search (#23 and #24) | 1
#26 | Search (“Comparative effectiveness” OR “Evidence-based” OR “Evidence based” OR Recommendations OR Recommendation) | 211691
#27 | Search (#25 and #26) | 0

### PubMed KQ 3

Search | Query | Items found
#1 | Search “Uncertainty”[Mesh] | 5187
#2 | Search (“Research Design/statistics and numerical data”[Mesh]) | 1454
#3 | Search “Therapeutic Equipoise”[Mesh] | 73
#4 | Search “Bias (Epidemiology)”[Mesh] | 47073
#5 | Search “low evidence” | 89
#6 | Search “conflicting evidence” | 1724
#7 | Search “missing evidence” | 59
#8 | Search “strength of evidence” | 1018
#9 | Search uncertainty | 38398
#10 | Search ambigu* | 22090
#11 | Search complexity | 72660
#12 | Search vagueness | 324
#13 | Search precision | 68972
#14 | Search “risk of bias” | 2290
#15 | Search “net benefit” | 899
#16 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15) | 250417
#17 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15) Filters: Humans | 160969
#18 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15) Filters: Humans; English | 149354
#19 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15) Filters: Humans; English; Adult: 19+ years | 52400
#20 | Search (#19) AND (“2013/”[Date - Entrez]: “3000”[Date - Entrez]) | 35
#21 | Search (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt]) | 1362908
#22 | Search (#20 not #21) | 35
#23 | Search “Communication”[Mesh] | 335663
#24 | Search (#22 and #23) | 2
#25 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh]) | 500670
#26 | Search (#24 and #25) | 0
#27 | Search (“Comparative Study” [Publication Type] OR “Controlled Clinical Trial” [Publication Type] OR “Cross-Over Studies”[Mesh]) | 1683952
#28 | Search (#24 and #27) | 0

## March 15, 2013 Cochrane Library Searches

Summary of results:

KQ 1—0 results

KQ 2—0 results

KQ 3—1 result (a Cochrane review); imported to EndNote

### Cochrane Library KQ 1 Search

(Zero results when limited to 2013 only)

ID | Search | Hits
#1 | [mh “information dissemination” [mj]/MT] | 1
#2 | [mh “decision making” [mj]] | 789
#3 | [mh “patient education as topic”] | 5686
#4 | [mh narration [mj]] | 44
#5 | [mh “persuasive communication”] | 181
#6 | [mh “health education” [mj]/MT] | 103
#7 | #1 or #2 or #3 or #4 or #5 or #6 from 2012 to 2013 | 112
#8 | “randomized controlled trial”:pt or “randomized controlled trial as topic”:pt or” single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 315900
#9 | #7 and #8 | 59
#10 | “Comparative effectiveness” or “Evidence-based” or “Evidence based” or Recommendations or Recommendation | 17955
#11 | #9 and #10 from 2013 to 2013 | 0

### Cochrane Library KQ 2 Search

(Zero results)

ID | Search | Hits
#1 | [mh “information dissemination”] | 140
#2 | [mh “diffusion of innovation”] | 122
#3 | [mh “evidence-based medicine”/ED] | 50
#4 | [mh “information services”/UT] | 17
#5 | [mh “practice guidelines as topic”/ST] | 81
#6 | [mh “guideline adherence”/SN] | 86
#7 | [mh “patient education as topic”/MT] | 1944
#8 | [mh “physician’s practice patterns”/ST] | 94
#9 | [mh “physician’s practice patterns”/SN] | 218
#10 | [mh “physician’s practice patterns”/TD] | 37
#11 | [mh “social marketing”] | 108
#12 | “social marketing”:ti or “social marketing”:ab | 61
#13 | “academic detailing”:ti or “academic detailing”:ab | 118
#14 | “dissemination strategy”:ti or “dissemination strategy”:ab | 18
#15 | “dissemination strategies”:ti or “dissemination strategies”:ab | 26
#16 | disseminat*:ti and guideline*:ti | 33
#17 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 from 2012 to 2013 | 57
#18 | “randomized controlled trial”:pt or
“randomized controlled trial as topic”:pt or
“single-blind method”:pt or “double-blind
method”:pt or “random allocation”:pt | | 315900
#19 | #17 and #18
29
#20 | “Comparative effectiveness” or
“Evidence-based” or “Evidence based” or
Recommendations or Recommendation | 17955
#21 | #19 and #20 from 2013 to 2013 | 0

### Cochrane Library KQ 3 Search

1 new result, a Feb 2013 Cochrane review.

ID | Search | Hits
#1 | [mh uncertainty] | 66
#2 | [mh “research design”/SN] | 34
#3 | [mh “therapeutic equipoise”]
#4 | [mh “bias (epidemiology)”] | 2181
#5 | “low evidence” | 29
#6 | “conflicting evidence” | 363
#7 | “missing evidence” | 6
#8 | “strength of evidence” | 538
#9 | uncertainty | 8376
#10 | ambigu* | 789
#11 | complexity
1564
#12 | vagueness
13
#13 | precision
2851
#14 | “risk of bias”
8418
#15 | “net benefit”
360
#16 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 | 20554
#17 | [mh communication]
| | 8192
#18 | #16 and #17
403
#19 | “randomized controlled trial”: pt or
“randomized controlled trial as topic”:pt or
“single-blind method”:pt or “double-blind
method”:pt or “random allocation”:pt | | 315900
#20 | #18 and #19
221
#21 | “comparative study” or “controlled clinical
trial” or “cross-over studies”
225896
#22 | #18 and #21
168
#23 | #20 or #22 from 2013 to 2013
| 1

## March 15, 2013 Update to Web of Science Searches Forward-Tracing

Citations counts; includes the yield from May 21–22, 2012 search

- Kühberger A. The Influence of Framing on Risky Decisions: A Meta-analysis.
  Organ Behav Hum Decis Process. 1998 Jul;75(1):23–55. PubMed PMID: 9719656.
  Cited by = 239
- Noar, S. M., Harrington, N. G., Van Stee, S. K., & Aldrich, R. S. (2011). Tailored health communication to change lifestyle behaviors. American Journal of Lifestyle Medicine, 5(2), 112–122.
  Not in WoS. Google scholar – cited by 15 All imported.
- Allen, M., & Preiss, R. W. (1997). Comparing the persuasiveness of narrative and statistical evidence using meta-analysis. Communication Research Reports, 14, 125–133.
  Cited by = 36 All imported
- Title: A meta-analysis of computer-tailored interventions for health behavior change
  Author(s): Krebs Paul; Prochaska James O.; Rossi Joseph S.
  Source: PREVENTIVE MEDICINE Volume: 51 Issue: 3–4 Pages: 214–221 DOI: 10.1016/j.ypmed.2010.06.004 Published: SEP–OCT 2010
  Cited by= 43, 1 dupl discarded, 42 imported.
- Title: A systematic review of three approaches for constructing physical activity messages: What messages work and what improvements are needed?
  Author(s): Latimer Amy E.; Brawley Lawrence R.; Bassett Rebecca L.
  Source: INTERNATIONAL JOURNAL OF BEHAVIORAL NUTRITION AND PHYSICAL ACTIVITY Volume: 7 Article Number: 36 DOI: 10.1186/1479-5868-7-36 Published: MAY 11 2010
  Cited by = 18, all imported
- Title: Does tailoring matter? Meta-analytic review of tailored print health Behavior change interventions
  Author(s): Noar Seth M.; Benac Christina N.; Harris Melissa S.
  Source: PSYCHOLOGICAL BULLETIN Volume: 133 Issue: 4 Pages: 673–693 DOI: 10.1037/0033-2909.133.4.673 Published: JUL 2007
  Not cited in WoS. Cited by 18 in Google Scholar, 3 dups, 15 imported
- Title: Does narrative information bias individual’s decision making? A systematic review
  Author(s): Winterbottom Anna; Bekker Hilary L.; Conner Mark; et al.
  Source: SOCIAL SCIENCE & MEDICINE Volume: 67 Issue: 12 Pages: 2079–2088 DOI: 10.1016/j.socscimed.2008.09.037 Published: DEC 2008
  Cited by= 20, 18 imported, 2 deleted
- O’Keefe, DJ & Jensen, JD ( 2006 ). The advantages of compliance or the disadvantages of noncompliance? A meta-analytic review of the relative persuasive effectiveness of gain-framed and loss-framed messages. Communication Yearbook, 30, 1 – 43
  Cited by = 30 1 dup, 29 imported
- Title: The relative persuasiveness of gain-framed and loss-framed messages for encouraging disease prevention behaviors: A meta-analytic review
  Author(s): O’Keefe Daniel J.; Jensen Jakob D.
  Source: JOURNAL OF HEALTH COMMUNICATION Volume: 12 Issue: 7 Pages: 623–644 DOI: 10.1080/10810730701615198 Published: OCT–NOV 2007
  Cited by = 67, 51 imported, and 12 dups discarded
- Title: The Relative Persuasiveness of Gain-Framed and Loss-Framed Messages for Encouraging Disease Detection Behaviors: A Meta-Analytic Review
  Author(s): O’Keefe Daniel J.; Jensen Jakob D.
  Source: JOURNAL OF COMMUNICATION Volume: 59 Issue: 2 Pages: 296–316 DOI: 10.1111/j.1460-2466.2009.01417.x Published: JUN 2009
  Cited by = 24, 5 imported and 17 dups discarded
- Title: What works with men? A systematic review of health promoting interventions targeting men
  Author(s): Robertson Lynn M.; Douglas Flora; Ludbrook Anne; et al.
  Source: BMC HEALTH SERVICES RESEARCH Volume: 8 Article Number: 141 DOI: 10.1186/1472-6963-8-141 Published: JUL 3 2008
  Cited by = 18, 17 imported and 1 dup discarded

### KQ 3 Web of Science Searches

- Politi MC, Han PK, Col NF. Communicating the uncertainty of harms and benefits of medical interventions. Med Decis Making. 2007 Sep–Oct;27(5):681–95. PMID: 17873256.
  Cited by = 59, 58 imported, 1 dup
- Babrow AS. The many meanings of uncertainty in illness: toward a systematic accounting. Health communication. 10(1): 1–23. (1998)
  Cited by = 49, 2 dups, 47 imported
- Han PK. Varieties of uncertainty in healthcare: a conceptual taxonomy. Medical Decision Making Epub ahead for print Jan 18 2011.
  Cited by = not in WoS. Cited by 14 in Google Scholar. 13 imported. 1 was in Chinese, not downloaded.