# Appendix A Sources of Uncertainty Mentioned in Existing Taxonomies of Uncertainty

Table A-1 Sources of uncertainty mentioned in existing taxonomies of uncertainty

| Inadequate Conceptualization of Evidence | Lack of Evidence | Bias | Inconsistency of Information Across Evidence Sources | Imprecision | Probability | Multicausality | Balance of Benefits and Harms | Applicability | Other
Tannert, 2007 | | Epistemological Uncertainty= lack of knowledge | | | | Ontological Uncertainty: stochastic | | | | Moral/Rule Uncertainty—lack of moral rules or applicable moral rules to apply
Lipschitz, 1997 | Inadequate understanding/Conceptualization | Incomplete information | Unreliable information | Unstable information (rapidly changing) | | | | Equivocality of options | | Undifferentiated alternatives Poor understanding of role
Morgan, 1990 | | Lack of Knowledge | Systematic Error | | Random Error/Statistical Variation | Probability Inherent Randomness | Modeling uncertainty (errors due to inability of model to predict real world) | | Variability | Linguistic imprecision Disagreements in interpretation/subjective judgment
Walker, 1991 | Conceptual organization of information; Epistemic (error in how we think about information) | | Measurement Uncertainty (validity, reliability), Sampling Uncertainty (selection bias); Causal Uncertainty (confounding) | | Sampling Uncertainty (CIs) | | Causal Uncertainty (lack of clarity about causes); Modeling Uncertainty (predictive errors due to wrong combination of variables)
Smithson, 1989/1993 | | Ignorance: Incomplete knowledge | Ignorance: Bias | | Ignorance: Vagueness | Ignorance: Probability | | | Ignorance: Irrelevance
Babrow, 1998 | Structure of Information (order/integration); lay epistemology | Information quality: completeness | Information Quality: Accuracy | Information Quality: Consistency | | Probability, Complexity (unpredictability/randomness) | Complexity= Multicausality, unpredictability, contingency (moderators) | | Information Quality: Applicability | Information Quality: Other (clarity, volume, source confidence) Information Quality: Ambiguity (=many meanings in interpretation)
Djulgebovic, 2007 | | Ignorance: Lack of Knowledge | | | Intervals | Frequency | | Net Benefit: Benefit vs. Equipoise
Politi, 2007 | | Ambiguity/Vagueness: Lack of evidence | Ambiguity/Vagueness: Strength of evidence (study design, bias) | Ambiguity/Vagueness= Conflicting evidence | Risk/CIs | Risk | Complexity= Multicausality or stability of risks | | Personal relevance
Han, 2011 | | Ambiguity= Lack of evidence | | Ambiguity= conflicting evidence | Ambiguity: Precision | Probability | Complexity= Multiplicity of causes

* Note: did not include Mishel, Kaspar cited by Han because focus is on patient understanding of uncertainty

Uncertainty definition: the quality or state of being in doubt.