# Overall Benefits and Harms of Oral Contraceptives for Prevention of Ovarian Cancer

## Background

Our systematic review and evidence synthesis found significant protective effects of oral contraceptives (OCs) against ovarian cancer, in both the general population and in high-risk groups such as BRCA1 and BRCA2 carriers, with risk decreasing as the duration of use increases. We also found significant decreases in the risk of colorectal and endometrial cancers. Increased risks were significant for breast cancer (with risk declining with time since last use), deep venous thrombosis (DVT), pulmonary embolism (PE), and ischemic stroke. The incidences of myocardial infarction (MI) and cervical cancer were also increased, although the confidence interval for these two associations included 1.0.

There has long been recognition that OC use has important noncontraceptive implications for health.349 Previous studies using formal methods to synthesize the available data in order to estimate net effects have generally shown either no overall effect, or a small positive effect, particularly for younger women.66,350,351

## Relevant Key Questions

The seven KQs developed for the entire systematic review are listed in Section 1 (refer to Figure 7 for a roadmap of this report). For Section 5, we have developed a new simulation model to generate estimates of the net harms and benefits of OC use in order to examine the following KQs:

KQ 4: Aside from pregnancy prevention, are there other benefits of OC use in reducing the risks of endometrial cancer or colorectal cancer?

KQ 5: What are the harms of OC use, including breast cancer incidence, cervical cancer incidence, venous thromboembolic disease, stroke, or myocardial infarction? How do these harms vary by dose or formulation, duration of use, or specific population?

KQ 6: Based on the comprehensive literature review, what are the benefits and harms from the use of OCs to reduce the incidence of ovarian cancer for specific populations? Based on the decision model, what is the estimated effect of these benefits and harms on life expectancy and quality-adjusted life expectancy?

KQ 7: Based on the systematic review and decision model, what research gaps need to be filled to better understand whether OCs are effective for the primary prevention of ovarian cancer?

### Analytic Framework

Figure 40 shows the analytic framework that guided this section of the review.

Figure 40 Analytic framework for overall benefits and harms of OCs

KQ = Key Question; OC = oral contraceptive

Note: KQ 7 is not shown in the analytic framework.

Figure 40 depicts KQs 4-7 within the context of the PICO (population, interventions, comparators, and outcomes) that will be the focus of Section 5, Overall Benefits and Harms of Oral Contraceptives for Prevention of Ovarian Cancer.

## Methods

A detailed description of the simulation model structure, data sources, and parameters is provided in Appendix F. Section 5 summarizes those aspects most relevant to the presented results. Unless otherwise noted, we used national estimates from 2007—the most recently available at the start of the model-construction process.

### Age-Specific Incidence of Relevant Outcomes With and Without OC Use

We obtained estimates of the age-specific (in 5-year age groups) incidence of ovarian, breast, cervical, colorectal, and endometrial cancers from two sources: (1) the Surveillance, Epidemiology, and End Results (SEER) database maintained by the National Cancer Institute (http://seer.cancer.gov/canques/index.html) and (2) the Centers for Disease Control and Prevention (CDC) National Program of Cancer Registries (http://wonder.cdc.gov/wonder/help/cancernpcr-v2009.html). Estimates were derived for all women as well as for four mutually exclusive race/ethnicity classifications: non-Hispanic white, non-Hispanic black, non-Hispanic other, and Hispanic. For the simulation model, we used age-specific and race/ethnicity-specific estimates of the number of cases and the total number of women in each strata from U.S. Census estimates (www.census.gov/popest/data/intercensal/national/nat2010.html) to generate beta distributions for incidence.

Estimates for the age-specific and race/ethnicity-specific incidence of DVT, PE, stroke, and acute MI were derived from the 2007 Nationwide Inpatient Sample (NIS), using specific International Classification of Disease-9 (ICD-9) codes as detailed in Appendix F. Again, distributions for stochastic modeling were derived by generating gamma distributions based on point estimates and standard errors and dividing by the estimated number of females in each strata based on Census estimates.

Estimates for the usage history of OCs were obtained from the National Survey of Family Growth (NSFG) data for 2002^352^ and 2006 (www.cdc.gov/nchs/nsfg/nsfg_2006_2010_puf.htm).

For current exposure to OCs, we estimated age-specific and race/ethnicity-specific prevalence of current use of OCs as reported by survey respondents; for ever OC use, we used the cumulative estimate of race/ethnicity-specific self-reported ever use by age 44 in the 2006 NSFG. We derived estimates of the age-specific probability of beginning OC use for the first time from the age-specific prevalence of ever use within each racial/ethnic group.

We then estimated the impact of current OC use and ever OC use on the five cancers and four vascular events from the age-specific incidence estimates, the age-specific exposure estimates for OCs, and the derived odds ratios from the meta-analyses reported earlier. For any outcome,

Overall Incidence = (Incidence in OC users) * (Prevalence OC use) + (Incidence in nonusers) * (Prevalence nonuse).

since

Incidence in OC users = (Incidence in nonusers) * (Relative risk in OC users),

and

Prevalence nonuse = 1 – (Prevalence OC use),

separate estimates for age-specific incidence in users and nonusers can be derived from the overall incidence (converted to probabilities as described in Appendix F), the prevalence of OC use, and the relative risks (estimated here from the odds ratios from the respective meta-analyses).

Table 60 shows the relative risk estimates for the association between OC use and incidence of outcomes of interest (relative risks estimated based on odds ratios). All estimates except for the joint effect of duration of OC use and time since last use are derived from the meta-analyses described in Sections 2–4 of this report. These estimates reflect the results of our initial analyses completed for the initial version of the report; as described in the methods, these analyses were updated during peer review. Because the estimates and confidence intervals are essentially unchanged, we present the results of the more extensive analyses completed with the original estimates. The one substantive change was that time since last use was found to have a significant effect on the protective association between OC use and ovarian cancer risk, with protection decreasing with increasing time since last use. Because the study-level meta-analyses did not allow for estimating the distribution of duration of OC use and time since last use, we used stratified data from a single published pooled analysis.21 Because the pooled analysis had insufficient observations to generate estimates for risks for durations of use greater than 5 years with last use 30 or more years previously, we used the estimates for 20 to 29 years. We assumed that OC use had no effect on survival after diagnosis of cancer or a vascular event since the literature review did not identify a significant effect of OCs on postdiagnosis survival. Therefore, any effects of OC use on cancer-specific or vascular event-specific mortality generated by the model are due only to effects on incidence.

Table 60 Relative risk estimates for association between OC use and incidence of outcomes of interest

Parameter | Base Case Estimate | Range (95% CI Unless Otherwise Specified) | Distribution Type
Cancers (Ever vs. Never OC Use)
Ovarian
General population | 0.71 | 0.64 to 0.79 | Lognormal
BRCA1 carrier | 0.54 | 0.45 to 0.65 | Lognormal
BRCA2 carrier | 0.60 | 0.29 to 1.54 | Lognormal
Breast
General population | 1.08 | 1.01 to 1.15 | Lognormal
BRCA1 carrier | 1.18 | 0.92 to 1.50 | Lognormal
BRCA2 carrier | 1.18 | 0.92 to 1.50 | Lognormal
Cervical | 1.28 | 0.89 to 1.86 | Lognormal
Colorectal | 0.86 | 0.79 to 0.95 | Lognormal
Endometrial | 0.55 | 0.42 to 0.70 | Lognormal
Cancers (Other Exposure Types)
Duration of OC use and ovarian cancer risk | 1 - 1 / (1 + 7.43 / duration (years))^*,*^1.239 | | Function
Time since last OC use and breast cancer risk | 1 + (0.2711 * EXP(-0.06551 * years) | | Function
Joint Effect of Duration of OC Use and Time Since Last Use and Ovarian Cancer Risk
Current or <10 Years Since Last Use
Duration of use <5 years | 0.88 | 0.75 to 1.04^*^ | Lognormal
Duration of use 5–9 years | 0.52 | 0.43 to 0.64^*^ | Lognormal
Duration of use ≥10 years | 0.39 | 0.33 to 0.47^*^ | Lognormal
Last use 10–19 Years Previously
Duration of use <5 years | 0.85 | 0.62 to 0.73^*^ | Lognormal
Duration of use 5–9 years | 0.62 | 0.53 to 0.73^*^ | Lognormal
Duration of use ≥10 years | 0.51 | 0.44 to 0.59^*^ | Lognormal
Last Use 20–29 Years Previously
Duration of use <5 years | 0.81 | 0.74 to 0.89^*^ | Lognormal
Duration of use 5–9 years | 0.69 | 0.60 to 0.78^*^ | Lognormal
Duration of use ≥10 years | 0.60 | 0.51 to 0.72^*^ | Lognormal
Last Use ≥30 Years Previously
Duration of use <5 years | 0.83 | 0.73 to 0.95^*^ | Lognormal
Duration of use 5–9 years | 0.69 | 0.60 to 0.78^*^ | Lognormal
Duration of use ≥10 years | 0.60 | 0.51 to 0.72^*^ | Lognormal
Vascular Events (Noncurrent vs. Current OC Use)
Deep vein thrombosis | 3.01 | 2.47 to 3.68 | Lognormal
Pulmonary embolism | 1.61 | 1.26 to 2.05 | Lognormal
Stroke | 2.02 | 1.11 to 3.65 | Lognormal
Myocardial infarction | 1.24 | 0.75 to 2.04 | Lognormal

BRCA = breast cancer genetic mutation; CI = confidence interval; OC = oral contraceptive

* 99% confidence interval.

### Impact of Current Use Patterns of OCs on Overall Life Expectancy and Disease-Specific Incidence and Mortality

We developed a semi-Markov state-transition model using TreeAge Pro (Williamstown, MA: TreeAge, Inc.) to simulate the effects of use and nonuse of OCs on incidence and mortality from ovarian cancer and the other outcomes of interest (Appendix F). The model is run as a microsimulation, starting at age 10. During each iteration of the simulation, individual “subject” characteristics, including race/ethnicity and BRCA status are drawn from distributions (second-order Monte Carlo simulation). Depending on the simulation, the values of other parameters are either the base case estimate or a value drawn from the appropriate distributions described in Tables 60 and 61 (first-order Monte Carlo simulation). Cycle lengths are 1 month.

Table 61 Key parameter values, ranges, and distributions

Parameter | Base Case Estimate | Range (95% CI Unless Otherwise Indicated) | Distribution Type | Reference
Demographics/Natural History
Race/ethnicity at age 10 | Non-Hispanic: White: 56.9% Black: 14.9% Other: 7.9% Hispanic: 20.3% | Census data—assumed to have negligible uncertainty | Fixed | Census
BRCA1
Prevalence | 0.22% | 0.15-0.33% | Beta | John, 2007^353^ Anonymous 2000^354^
RR Ovarian cancer | 41.7 | 30.1-53.3 | Lognormal | Anonymous 2000^354^
RR Breast cancer | Age-dependent 20–39: 58.6 40–49: 14.4 50–99: 1.0 | Age-dependent 20–39: 49.9-67.2 40–49: 0.9-28.0) 50–99: 1.0 | Lognormal | Anonymous 2000^354^
BRCA2
Prevalence | 0.15% | 0.08-0.23% | Beta | John, 2007^353^ Anonymous 2000^354^
RR Ovarian cancer | 9.9 | 2.3-17.4 | Lognormal | Anonymous 2000^354^
RR Breast cancer | Age-dependent 20–39: 17.1 40–49: 11.2 50–99: 22.4 | Age-dependent 20–39: 17.1 (9.7-24.5) 40–49: 7.5-15.0 50–99: 18.1-26.8 | Lognormal | Anonymous 2000^354^
Age-Specific Incidence
Hysterectomy | Age- and race/ethnicity-dependent | See Appendix F | Gamma (numerator) | NIS
Oophorectomy | Age- and race/ethnicity-dependent | See Appendix F | Gamma (numerator) | NIS
Bilateral tubal ligation | Age- and race/ethnicity-dependent | See Appendix F | Beta | Chan, 2010^355^ Whiteman, 2012^356^
Cancers | Age- and race/ethnicity-dependent | See Appendix F | Gamma (numerator) | NIS
Vascular events | Age- and race/ethnicity-dependent | See Appendix F | Gamma (numerator) | NIS
Mortality
All-cause mortality | Age- and race/ethnicity-dependent | See Appendix F | Gamma (numerator) | NCHS^a^
Cancers | Age- and race-dependent (white/black only) | See Appendix F | Beta | SEER
Vascular events | Age- and race/ethnicity-dependent | See Appendix F | Beta | NIS
Oral Contraceptive Use
Age At First Use
Natural history | Age- and race/ethnicity-dependent | See Appendix F | Dirichlet | NSFG
Prescription | Randomly assigned | 15–45 | Uniform
Duration of Use
Natural history | Mean 54.8 months | Standard deviation 41 months, range 1–240 | Gamma | Chasan-Taber, 1996^357^
Prescription | Randomly assigned | 1–240 months, partly dependent on age of starting (not continued past age 45) | Uniform
Reduction in ovarian cancer incidence after tubal ligation | 0.69 for 15 years, then 1.0 | 0.64 to 0.75 | Lognormal | Cibula, 2011^17^

NCHS = National Center for Health Statistics; NIS = Nationwide Inpatient Sample; NSFG = National Survey of Family Growth; RR = risk ratio; SEER = Surveillance, Epidemiology, and End Results

a http://wonder.cdc.gov/wonder/help/cmf.html#Compressed%20Mortality%20File:%20ICD%20Revision

The use of probabilistic analysis and microsimulation offer two main advantages over a deterministic approach. First, probabilistic analysis allows the model to incorporate both the range of uncertainty in parameter estimates (e.g., the width of a 95% confidence interval) as well as the distribution of that uncertainty. For example, for a given mean parameter value with a normal distribution around that mean, the model can be run multiple times, drawing from the distribution with most of the values lying close to the mean value, but 2.5 percent would be drawn from below the lower 95-percent confidence bound and 2.5 percent from above the upper 95-percent confidence bound). Using distributions can be particularly helpful for parameters that are not “statistically significant” using conventional criteria, but where the weight of the existing evidence suggests a trend. For example, if a point estimate for a relative risk is 1.6 with a 95-percent confidence interval of 0.99 to 2.3, the traditional interpretation is that the observed increased risk is not statistically significant. However, because it is only the lower tail of the distribution that is below 1.0, the probability that the risk is greater than 1.0 is more than 95 percent. From a decisionmaking perspective, quantifying these effects can be quite helpful—in some situations, a patient, clinician, or policymaker might want to consider the potential effects of an increased risk of harm if the probability of the harm truly being increased was more than 80 or 90 percent (depending on the absolute risk of harm and the consequences of that harm), even though a threshold based on “not statistically significant” would preclude consideration of that harm.

The main advantage of microsimulation for this specific application is that it allows the model to have “memory” so that the probability of the outcomes of interests can be conditioned not only on the current state but also on past events, such as past use of OCs or duration of OCs.

### OC Use Scenarios

We modeled OC use under five scenarios; all scenarios began at age 10 and continued until death or age 100. Table 62 illustrates the main differences in the four OC-use scenarios. The initial scenario included the full range of available contraceptive options as well as varying contraceptive effectiveness, pregnancy outcomes (including duration of pregnancy), and lactation. However, because of the paucity of data on the dynamics of contraceptive choice over a woman's lifetime, particularly in the United States, and because pregnancy is a potential competing risk for some outcomes, we elected to model “No OC use” by fixing the risk of the outcomes of interest to that of nonusers, based on the equations above. This allowed us to focus only on the potential tradeoffs between harms and benefits of OC use as a potential preventive agent.

Table 62 Five OC use scenarios used in model

Parameter/Assumption | OC Use Scenario
Parameter/Assumption | Ever/Never | Duration | No OC | Prescribed Duration and Age at First Use and Duration | Joint Effects of Duration and Time Since Last Use
Age at first use | Age- and race-specific probability | Age- and race-specific probability | Age- and race-specific probability | Uniform distribution, assigned in sensitivity analysis | Age- and race-specific probability
Duration of OC use | Population distribution, constrained to stop by age 50 | Population distribution, constrained to stop by age 50 | Population distribution, constrained to stop by age 50 | Uniform distribution, assigned in sensitivity analysis, constrained to stop by age 50 | Population distribution, constrained to stop by age 50
Association between OC use and cancers | Relative risk based on ever vs. never use for all | Relative risk based on duration of use for ovarian cancer, time since last use for breast cancer, ever vs. never for others | No reduction or increase in risk associated with OCs; incidence assumed to be that of nonusers in general population | Relative risk based on duration of use for ovarian cancer, time since last use for breast cancer, ever vs. never for others | Relative risk based on duration of use and time since last use for ovarian cancer, time since last use for breast cancer, ever vs. never for others
Association between OC use and vascular events | Relative risk based on current vs. noncurrent use for all | Relative risk based on current vs. noncurrent use for all | No reduction or increase in risk associated with OCs; incidence assumed to be that of noncurrent users in general population | Relative risk based on current vs. noncurrent use for all | Relative risk based on current vs. noncurrent use for all

OC = oral contraceptive

### Model Assumptions

We made a number of simplifying assumptions as described below. If an assumption could possibly bias the analysis for or against the potential benefits of OC use, we chose the more conservative assumptions that biased against potential benefits of OC use whenever feasible.

#### Excluded Other Potential Benefits and Harms

We did not include other potential benefits (e.g., prevention of pregnancy, effects on menstrual flow and discomfort, effects on other reproductive outcomes such as endometriosis or benign ovarian cysts, effects on acne or premenstrual syndrome) or harms (e.g., neoplasms of the liver, gallbladder disease). Although including the full range of potential benefits and harms is ultimately of great interest, the scope of this analysis was specifically restricted to the potential noncontraceptive preventive benefits of OCs. Therefore, we restricted our analysis to relatively common, potentially fatal cancers or vascular events for which a preliminary literature review suggested consistent evidence of an association with OC use.

#### Excluded Quality-of-Life Measures

We did not include quality-of-life measures. Although we originally intended to include quality-adjusted life expectancy, expressed as quality-adjusted life years (QALYs) as one of the outcomes, we were limited by a lack of available data on preferences for OC use. Although we identified several economic analyses of OC use for contraception—some of which included other outcomes,350,358,359 or prophylaxis against ovarian cancer in BRCA1 and BRCA2 mutation carriers360,361 which included utility values for outcomes relevant to our analysis—none included any values for OC use itself. There is a relatively high discontinuation rate of OC use within the first 12 months after starting, some of which is attributable to side effects.362-366 Conversely, there are other potentially positive effects on quality-of-life, including effects on menstruation, reassurance against unwanted pregnancy, or reduced acne. Including only the effect of cancers and vascular events on QALYs could substantially bias overall estimates of the impact of OCs on quality-adjusted life expectancy. Therefore, we focused primarily on the specific balance between benefits (in terms of reduced cancers) and harms (in terms of increased cancers or acute vascular events); further work to integrate the effect of OCs, either as contraceptives or as prevention against other diseases, is a major research need.

#### Continuous OC Use for Duration

We assumed that, once “assigned” an age at first use and duration of use by the model, OC use would be continuous for that duration, then stopped. This is clearly not the case for most women, but because the available literature on duration of use does not distinguish between continuous and intermittent use, and data to inform patterns of use were not available, we used this simplifying assumption.

This assumption creates the potential for bias in both directions. In the case of breast cancer and vascular events, where incidence increases with age, an assumption of continuous use may underestimate the upper tail of the age distribution of current OC users, and therefore underestimate the potential increased risk associated with OC use. On the other hand, to the extent that time since last use potentially decreases protection for ovarian, colorectal, and endometrial cancers, underestimating the upper tail may lead to underestimating the protective effect, since the continuous use assumption results in longer average duration between last use and the time of highest cancer risk.

#### Point Estimates in Base-Case Analysis

For the purposes of the base-case analysis, we used the point estimates from the meta-analyses; since two of these (MI and cervical cancer) were not statistically significant using conventional criteria, this is a potential bias against OC use.

#### Analysis of Temporal Relationships

We included an analysis of temporal relationships such as age at first or last use, duration of use, or time since last use only for those found to be significant in the meta-analyses (duration of use and time since last use for ovarian cancer, and time since last use for breast cancer). Because the data available for meta-analysis did not allow for estimation of the joint effect of duration of use and time since last use, we used estimates for ovarian cancer risk stratified by both duration and time since last use from the pooled analysis of the Collaborative Group on Epidemiological Studies of Ovarian Cancer.21 As discussed in Section 2, these estimates are quite similar to the results of the study-level meta-analyses. This was done primarily for tractability of modeling, and because estimates of relative risk were most commonly reported as ever vs never use. This assumption of lifetime effects for any duration exposure could result in overestimation of both benefits and harms.

#### Constant Risk of Vascular Events

We assumed that the risk of vascular events among current users was constant across time; i.e., that the degree of risk associated with OCs was the same during a woman's first and last month of use no matter how long. As discussed in Section 4, there is some evidence that the risk is highest early during use for some outcomes, particularly DVT,281 presumably because women with an increased underlying risk such as inherited thrombophilias develop the outcome quickly. If this is the case, the assumption of constant risk may overestimate the likelihood of these events among all OC users.

We also assumed that there was no increased risk in vascular events after discontinuation of OCs. This was consistent with the findings for venous thromboembolism and stroke discussed in Section 4. Although we did not explicitly consider ever vs never use for myocardial infarction, another meta-analysis found no difference in risk between past users and never users.47

#### Survival After Cancer Diagnosis

We modeled survival after diagnosis for each cancer up to 5 years; after 5 years, we assumed cure (women with breast cancer were at risk for a second primary, although this was not conditioned on previous history). We limited followup for five years primarily because there is variability in reported length of followup between the different cancers. Particularly for breast cancer, where late recurrences are not uncommon, this may result in an underestimate of cause-specific mortality.

As described in Appendix F, survival after diagnosis was conditional on age at diagnosis and race (black vs. white only, with the assumption that survival for Hispanic and other-race women was identical to white women). Also as described in Appendix F, the model predictions for overall lifetime incidence when incorporating patterns of OC use and the derived estimates for the association between OC use and cancers showed good agreement with estimates of lifetime incidence derived from the SEER DevCan software. (http://surveillance.cancer.gov/devcan/).

#### Patterns of OC Use Over Lifetime

We found surprisingly few data on patterns of use of OCs over a woman's lifetime. Although we were able to generate an estimate of the distribution based on one study that reported a mean and standard deviation for duration,357 the available literature does not provide any data to correlate duration of use with age of starting, and so we modeled these as independent probabilities for those analyses where the values for these parameters were drawn from distributions.

We assumed no one would start OCs after age 45, (i.e., age at first use ranged from 12 to 44) age of first use to 44, based on data from the NSFG that showed almost no increase in the proportion of “ever users” after age 35, and the lack of available data for women over age 45 (since the NSFG only includes women aged 15 to 44 years). We also constrained duration of use so that all women stopped OC use at age 50, regardless of assigned age at first use and duration. Assuming that there is, in fact, a correlation between age at first use and duration of use, this assumption of independence may underestimate duration of use in younger women and overestimate it in older women. Particularly for vascular events, where overall risk increases with age and there is an assumption of constant risk with time among current users, this may result in an overestimate of the number of events in OC users.

#### Tubal Ligation

Because there is a consistent association between tubal ligation and reduced ovarian cancer risk, even after controlling for contraceptive use,17,19,123,367 we included tubal ligation (based on age-specific and race/ethnicity-specific incidence and prevalence) in the model, and used the estimate for reduction in risk from a recent meta-analysis.17 Because most studies of the association between ovarian cancer and OCs controlled for tubal ligation (and vice versa), we assumed that the risks were independent such that the risk of ovarian cancer in a woman with a history of OC use was further reduced if she subsequently underwent tubal ligation. We also assumed that the probability of tubal ligation was not conditioned on prior OC use.

#### Effect of Other Contraceptive Methods

Because the overwhelming majority of the literature classified OC use as some variant of ever versus never, we assumed that contraceptive methods other than tubal ligation that were used whenever OCs were not being used did not affect ovarian cancer risk, although one recent study suggests this may not be the case.123

#### Effect of Hysterectomy or Oophorectomy

Because removal of the potentially cancerous organ obviously affects the likelihood of developing cancer, we included age-specific and race/ethnicity-specific probabilities of hysterectomy and oophorectomy (in various combinations) in the model. We assumed that the risk of cervical and endometrial cancer was zero after hysterectomy and that the risk of ovarian cancer was zero after bilateral oophorectomy. Although there are fairly consistent data showing that women who undergo hysterectomy alone, without removal of the ovaries, have a reduced risk for ovarian cancer,19,368 we assumed hysterectomy alone did not affect ovarian cancer risk, primarily because of uncertainty about potential interactions with OC use. Because OCs may reduce the incidence of both benign and malignant indications for hysterectomy, they could potentially decrease hysterectomy rates.

Conversely, because OCs may be prescribed for many conditions that can lead to hysterectomy, use of OCs may be associated with increased hysterectomy rates. This is consistent with data from two observational studies; in Denmark, a country with high overall use of OCs, long-term OC use was associated with decreased hysterectomy rates, while short-term use was associated with increased rates,369 and in Ireland, where OC use for contraception was historically quite low, a history of OC use was associated with an increased hysterectomy rate.370

### Three Types of Simulations

With the above assumptions and base-case estimates, we ran three types of simulations:

1. Simple simulations, where the mean value of the relative risks associated with OC use was used for all iterations. These included:
  a. A series of 60,000 simulations for the general population (all women including BRCA1 and BRCA 2 carriers) and 20,000 each for BRCA1 and BRCA2 carriers where the effect of OC use based on current use patterns was compared with no use.
  b. A series of 50,000 simulations for the general population and 20,000 each for BRCA1 and BRCA2 carriers where OC use was based on current use patterns. After the simulations, the “population” dataset was divided into ever and never users. Differences in outcomes were compared and 50,000 simulations were run for the general population and for BRCA1 and BRCA2 carriers.
2. Age and duration analyses, where sets of 20,000 simulations were run varying both age at first OC use (15, 20, 25, 30, 35, and 40 years) and duration of use (1, 2, 5, and 10 years). A total of 24 combinations were simulated (we did not model 10 years' duration starting at age 40). These simulations also indirectly captured the effect of recency of use on breast cancer since “recency” relative to age-specific breast cancer risk is a direct function of age at first use and duration of use.
3. Two-dimensional simulations, where individual values of the OC-associated relative risks were drawn from the distribution (n=200), followed by 10,000 simulations for each relative risk value, for a total of 2,000,000 simulations.

#### Modeled Outcomes

We used the model to estimate overall life expectancy and lifetime incidence and mortality from the five cancers and four acute vascular events; for the “direct” comparison of ever vs never users, we also estimated the absolute number of harms and benefits attributable to OC use per 100,000, and the number needed to harm or prevent (defined as 1 divided by the risk difference)

#### Sensitivity Analyses

We assessed the effect of uncertainty in the model structure and parameter values in several ways. First, for each set of simulations, we modeled the association between OC use and outcomes based on current use in two different ways: (1) where all cancer relative risks were based solely on ever versus never use and (2) where the risks for ovarian cancer were modeled on the basis of duration of use and the risks for breast cancer were modeled on ever vs never use and time since last use.

Second, we focused on age of starting use and duration of use by fixing the value of these across a wide range and then comparing the results. Third, we conducted a series of two-dimensional simulations, where the values for the relative risks of events were first drawn from the distributions described in Table 60, followed by a series of microsimulations, drawing “individual” values for BRCA status, race/ethnicity, and disease incidence and mortality from their appropriate distributions described in Table 61. For each outcome, we then generated the equivalent of “acceptability curves,”371 where the proportion of sets of simulations where one strategy was “optimal” compared with another are illustrated at different thresholds for “optimality.”

For outcome incidence and mortality, we used a net benefits approach.371 In health economics, net monetary benefits (NMB) are defined as a function of willingness-to-pay (WTP) as follows:

NMB = (WTP * Effectiveness) – Costs

If WTP is measured in dollars per QALY, then NMB reduces to a single dollar figure. At any given WTP, the strategy with the highest NMB is preferred. Alternatively, the same approach can be applied using net health benefits (NHB):

NHB = (Costs/WTP) – Effectiveness

In a growing number of economic analyses, probabilistic analysis is used to estimate the effect of uncertainty in parameter values on the likelihood of making an optimal decision.372 However, for those settings where costs are not explicitly being considered, this approach still has value. Harms can be considered “costs”—especially in the setting of preventive interventions.

For this analysis, we estimated separate harm/benefit ratios for incidence and mortality, with harms defined as the difference in incidence or mortality for breast and cervical cancer, and DVT, PE, MI, and stroke, and benefits as the difference in incidence or mortality for ovarian, colorectal, and endometrial cancers. For the incidence ratio, we varied the WTP from 0 net (no harms with some benefit) to 5.0 (5 extra incident cases for each case prevented) and benefits equivalent). For the mortality ratio, we varied the WTP from 0 (no excess mortality relative to deaths prevented) to 1.0 (excess mortality attributable to OC use exactly equivalent to prevented deaths attributable to OC use) We assumed that the harms and benefits compared here—all of which are associated with potential long-term morbidity and mortality—were roughly equivalent; obviously, this may not be the case, and appropriate weighting using validated preference measures is needed. Although this approach has been described,373 it has not gained wide acceptance in the health economics literature. However, the simple comparison of net harms and benefits is frequently used in guidelines development,374,375 and this approach may be particularly helpful in illustrating the effects of uncertainty on specific harms and benefits when developing practice or policy recommendations.

## Results

### Age-Specific Incidence of Relevant Outcomes With and Without OC Use

Estimated age-specific incidences of cancers among ever and never users of OCs are shown in Figures 41 to 45. At the ages of peak incidence, ever use is associated with an absolute reduction in ovarian cancer incidence of approximately 20 per 100,000 (Figure 41). For other cancers, peak incidence was increased by approximately 20 per 100,000 for breast cancer (Figure 42) and 4 per 100,000 for cervical cancer (Figure 43), and peak incidence decreased by approximately 50 per 100,000 for colorectal cancer (Figure 44) and 55 per 100,000 for endometrial cancer (Figure 45).

Figure 41 Estimated age-specific incidence of ovarian cancer among ever versus never OC users

Description: Figure 41 shows that at the ages of peak incidence, ever use is associated with an absolute reduction in ovarian cancer incidence of approximately 20 per 100,000.

Figure 42 Estimated age-specific incidence of breast cancer among ever versus never OC users

Description: Figure 42 shows that peak incidence was increased by approximately 20 per 100,000 for breast cancer.

Figure 43 Estimated age-specific incidence of cervical cancer among ever versus never OC users

Description: Figure 43 shows that peak incidence was increased by approximately 4 per 100,000 for cervical cancer.

Figure 44 Estimated age-specific incidence of colorectal cancer among ever versus never OC users

Description: Figure 44 shows that peak incidence was increased by approximately 50 per 100,000 for colorectal cancer.

Figure 45 Estimated age-specific incidence of endometrial cancer among ever versus never OC users

Description: Figure 45 shows that peak incidence was increased by approximately 55 per 100,000 for endometrial cancer.

Estimates for vascular events among current versus noncurrent users of OCs are shown in Figures 46 to 49. Peak increases in incidence were approximately 150 per 100,000 for DVT (Figure 46), 30 per 100,000 for PE (Figure 47), 30 per 100,000 for stroke (Figure 48), and 12 per 100,000 for acute MI (Figure 49); all of these were in women between the ages of 35 and 44. Note that the rates for all events merge at age 45. This is due to the lack of data on the prevalence of OC use in women over 45 years of age, since the best available data source, the NSFG, is limited to women aged 15 to 44. Because the formula for estimating incidence of an outcome based on exposure status subjects is derived from relative risk, overall incidence, and prevalence of exposure, there is no way to estimate the incidence in OC users over age 45, but it is certainly likely to be greater than for nonusers.

Figure 46 Estimated age-specific incidence of hospitalizations for deep vein thrombosis among current versus noncurrent OC users aged 15 to 44

Description: Figure 46 shows that peak increases in incidence were approximately 150 per 100,000 for DVT.

Figure 47 Estimated age-specific incidence of hospitalizations for pulmonary embolism among current versus noncurrent OC users aged 15 to 44

Description: Figure 47. Estimated age-specific incidence of hospitalizations for pulmonary embolism among current versus noncurrent OC users aged 15 to 44 Figure 47 shows that peak increases in incidence were approximately 30 per 100,000 for PE.

Figure 48 Estimated age-specific incidence of hospitalizations for stroke among current versus noncurrent OC users aged 15 to 44

Description: Figure 48. Estimated age-specific incidence of hospitalizations for stroke among current versus noncurrent OC users aged 15 to 44 figure 48 shows that peak increases in incidence were approximately 30 per 100,000 for stroke.

Figure 49 Estimated age-specific incidence of hospitalizations for acute myocardial infarction among current versus noncurrent OC users aged 15 to 44

Description: Figure 49 shows that peak increases in incidence were approximately 12 per 100,000 for acute MI.

Figure 50 (for cancers) and Figure 51 (for vascular events) summarize the effects of OC use on age-specific incidence on a common scale. Each graph represents the estimated net difference in cases or hospitalizations per 100,000 in OC users compared with nonusers at each age. It is important to note that these estimates are for each individual outcome only and are not adjusted for competing risks such as hysterectomy or oophorectomy, or the occurrence of other outcomes, and effects of duration of use or time since last use are not incorporated.

Figure 50 Increase or decrease in age-specific incidence of cancers in ever OC users versus never users

Description: Figure 50 shows the absolute difference in age-specific incidence for users of OC compared to nonusers. Increase in breast cancer incidence is much greater than increase in cervical cancer incidence. Reductions in incidence are greatest for endometrial cancer, followed by colorectal cancer, then ovarian cancer.

Figure 51 Increase in age-specific incidence of vascular events in current OC users versus noncurrent users

DVT = deep vein thrombosis; MI = myocardial infarction; PE = pulmonary embolism

Description: Figure 51 shows the absolute difference in age-specific incidence in vascular events for current users of OC compared to nonusers. The increased risk is greatest for DVT, with all others being 30 per 100,000 or less.

### Effect of OC Use on Lifetime Incidence and Mortality

Table 63 shows the results of 60,000 simulations for the general population, along with 20,000 simulations each for BRCA1 and BRCA2 carriers; results were not qualitatively different by race or ethnicity. In this analysis, we estimate the overall effects of OC use based on current population patterns of use (including some women who never use OCs), and compare it to a simulated population that has the same patterns of pill us, but without any harms or benefits attributable to the pill (i.e., the risk of events in pill users is assumed to be identical to nonusers estimated base on relative risk estimates). Current patterns of OC use resulted in an increase in life expectancy of 1 to 2 months in the general population (with larger gains when modeled on the basis of duration), 10.5 months in BRCA1 carriers, and 1 month in BRCA2 carriers. Estimated ovarian cancer incidence and mortality, and overall mortality, in the model incorporating the joint effects of duration of use and time since last use was intermediate between estimates resulting from the ever/never and duration-only models. For clarity, we present only ever/never and duration only. Because there were no data on effects of duration of use or time since last use on outcomes in BRCA1 or BRCA2 carriers, effects of OCs were based on ever versus never use. Again, for the purposes of clarity, we omit confidence intervals but note that, even with this large number of simulations, the confidence intervals between different models overlapped.

Table 63 Estimated life expectancy and lifetime number of cases and deaths from cancers and vascular events

Outcome | All Women (n=60,000) | | | BRCA1 Only (n=20,000) | | BRCA2 Only (n=20,000)
Outcome | No Effect of OCs | OC- Attributable Effects | | No Effect of OCs | OC- Attributable Effects | No Effect of OCs | OC- Attributable Effects
Outcome | No Effect of OCs | Ever/Never^a^ | Time-Dependent^b^ | No Effect of OCs | Ever/Never^a^ | No Effect of OCs | Ever/Never^a^
Life expectancy | 71.26 | 71.37 | 71.42 | 63.81 | 64.76 | 65.31 | 65.41
Lifetime Risks of Cancers
Ovarian
Developing | 1.76% | 1.42% | 1.00% | 48.92% | 36.21% | 14.15% | 9.97%
Dying | 0.99% | 0.78% | 0.55% | 25.55% | 19.33% | 7.80% | 5.63%
Breast
Developing | 10.52% | 11.04% | 11.14% | 48.45% | 54.09% | 82.92% | 85.89%
Dying | 0.92% | 0.98% | 0.97% | 5.11% | 5.58% | 8.14% | 8.45%
Cervical
Developing | 0.54% | 0.63% | 0.60% | 0.39% | 0.61% | 0.28% | 0.47%
Dying | 0.01% | 0.01% | 0.01% | 0.00% | 0.01% | 0.00% | 0.01%
Colorectal
Developing | 5.16% | 4.70% | 4.78% | 3.42% | 3.33% | 3.44% | 3.22%
Dying | 1.72% | 1.57% | 1.64% | 1.09% | 1.05% | 1.00% | 1.03%
Endometrial
Developing | 3.21% | 2.13% | 2.15% | 2.19% | 1.63% | 2.71% | 1.50%
Dying | 0.60% | 0.41% | 0.38% | 0.42% | 0.26% | 0.52% | 0.27%
Lifetime Risks of Other Outcomes
DVT
Cases | 8.54% | 8.74% | 8.77% | 5.77% | 6.30% | 5.79% | 5.47%
Deaths | 0.45% | 0.50% | 0.50% | 0.34% | 0.38% | 0.40% | 0.34%
PE
Cases | 4.89% | 4.89% | 4.89% | 3.46% | 3.19% | 3.13% | 3.14%
Deaths | 0.43% | 0.40% | 0.39% | 0.27% | 0.29% | 0.27% | 0.23%
Stroke
Cases | 10.53% | 10.38% | 10.36% | 7.31% | 7.44% | 6.26% | 6.45%
Deaths | 0.87% | 0.79% | 0.79% | 0.48% | 0.58% | 0.53% | 0.48%
MI
Cases | 15.62% | 15.66% | 15.68% | 11.10% | 11.27% | 9.02% | 9.42%
Deaths | 1.99% | 1.98% | 2.01% | 1.48% | 1.51% | 1.07% | 1.04%

BRCA = breast cancer genetic mutation; DVT = deep venous thrombosis; MI = acute myocardial infarction; OC = oral contraceptive; PE = pulmonary embolism

a Association between OC use and ovarian and breast cancers modeled as ever versus never users.

b Association between OC use and ovarian cancer dependent on duration of use, and between OC use and breast cancer on time since last use.

This gain was largely attributable to decreases in ovarian cancer (which, while uncommon, has a high mortality rate), and colorectal cancer, which is common and has an intermediate mortality rate. While OC use did increase breast cancer cases, the relative increase in mortality from breast cancer was lower than the decrease from ovarian and colorectal cancer. This outcome is likely due to two factors. First, the overall case mortality rate for breast cancer is lower than for ovarian or colorectal cancer, even without adjusting for any effect of OCs on mortality through screening and/or biological changes. Second, by increasing age-specific incidence, cases are diagnosed at an earlier age—because we used age-specific survival in the model, this will lead to lower expected mortality. Finally, we assumed that 5-year survivors were no longer at risk for cancer death (although breast cancer survivors were at risk for a contralateral new cancer), which may also be contributing to lower overall mortality (other than BRCA carriers, who were at increased risk for both breast and ovarian cancers, we assumed the risk of different cancers was independent—women with a history of breast cancer were as likely to develop ovarian or other cancers as women who did not). The effect on mortality of cases occurring at younger ages is also seen for vascular events; in some iterations of the model, mortality was even reduced among users compared with nonusers, although some of this is also because of the large variance around the probability estimates due to the small number of cases. The prevalence of ever use in the models averaged approximately 75 percent across all iterations, which is somewhat lower than the 84 percent reported in the NSFG. However, given the relative magnitudes of the different effects, this likely leads to underestimation of overall net benefit.

The relative effects of incidence and disease-specific mortality are particularly clear in the results for BRCA1 and BRCA2 carriers. For BRCA1 carriers—where the relative increases in risk of breast and ovarian cancer are similar and result in similar lifetime risks of close to 50 percent in this model—the absolute reduction in ovarian cancer mortality is approximately 6 percent, while the absolute increase in breast cancer mortality is less than 1 percent, resulting in a gain in life expectancy of over 10 months. Conversely, for BRCA2 carriers—where the increased risk of breast cancer is much larger than for ovarian cancer (83% vs. 14%)—resulted in a smaller absolute reduction in mortality. The estimated number of other cancers and vascular events is also smaller for the BRCA carriers, largely due to the large competing risks associated with breast and ovarian cancers. As with the general population, the combination of small probabilities and earlier diagnosis lead to some paradoxical results in terms of the effect of OC use on incidence and mortality.

These results reflect estimates of the population-level impact of associations between OC use and these outcomes based on current patterns of OC use—in other words, the weighted average based on estimates of the population distribution of ever use, age at first use, and duration of use. Because the “OC use” model includes “subjects” who never use OCs, the absolute difference in outcomes at the population level will be lower than it will be when directly comparing ever users to never users.

### Effect of OC Use on Lifetime Incidence and Mortality in Ever Versus Never Users

To estimate absolute differences in outcomes between ever users and never users, we generated a “population” of women who had used OCs based on reported patterns, then calculated life expectancy and incidence and mortality from cancers and vascular events for “subjects” who had “taken” OCs during the simulation versus those who had not. We performed 50,000 iterations for the general population and 20,000 each for BRCA1 and BRCA2 carriers.

In Table 64, the estimated life expectancy and lifetime number of cases and deaths from cancers and vascular events is compared between ever versus never users. The results are qualitatively similar but somewhat larger in scale than seen when modeled as a general population effect, where the effect is the weighted average of incidence in users and nonusers. Estimated gains in life expectancy ranged from 5 months for BRCA2 carriers to 11.5 to 12.5 months for the general population, to 16 months for BRCA1 carriers. The incidence estimates for never users are also somewhat higher than in the population model, which is likely due to differences resulting from the effect of actually modeling no use, which may slightly modify the effects of differences in possible state transition compared with the general population model, which assumes similar patterns of pill use but no pill effects on cancers or vascular events.

Table 64 Estimated lifetime excess cases and deaths (harms) and prevented cases (benefits) per 100,000 women

Outcome | General Population | | | | BRCA1 | | BRCA2
Outcome | Ever/Never^a^ | | Duration^b^ | | BRCA1 | | BRCA2
Outcome | Excess (Prevented) per 100,000 | Number Needed To Harm (Prevent) | Excess (Prevented) per 100,000 | Number Needed To Harm (Prevent) | Excess (Prevented) per 100,000 | Number Needed To Harm (Prevent) | Excess (Prevented) per 100,000 | Number Needed To Harm (Prevent)
Harms
Breast Cancer
Cases | 1021 | 98 | (345) | (290) | 2080 | 48 | 2268 | 44
Deaths | (170) | (588) | (263) | (380) | (48) | (2078) | 318 | 315
Cervical Cancer
Cases | 7 | 14154 | 74 | 1356 | 149 | 671 | 217 | 461
Deaths | 0 | 4513455 | 11 | 9369 | 7 | 14899 | 7 | 15029
DVT
Cases | 1226 | 82 | 1277 | 78 | 1059 | 94 | 45 | 2215
Deaths | 4 | 24208 | 20 | 4959 | 46 | 2184 | (77) | (1297)
PE
Cases | 524 | 191 | 530 | 189 | 575 | 174 | 451 | 222
Deaths | 484 | 207 | 468 | 214 | 432 | 232 | 317 | 315
Stroke
Cases | 1329 | 75 | 1177 | 85 | 1819 | 55 | 1461 | 68
Deaths | 77 | 1300 | 37 | 2706 | 138 | 726 | (105) | (949)
MI
Cases | 1253 | 80 | 1645 | 61 | 1823 | 55 | 1396 | 72
Deaths | 378 | 264 | 448 | 223 | (33) | (3009) | 149 | 671
Total harms
Cases | 5361 | 19 | 4357 | 23 | 7505 | 13 | 5840 | 17
Deaths | 773 | 129 | 720 | 139 | 541 | 185 | 608 | 164
Benefits
Ovarian cancer
Cases | (806) | (124) | (1076) | (93) | (9701) | (10) | (4300) | (23)
Deaths | (389) | (257) | (566) | (177) | (4478) | (22) | (1845) | (54)
Colorectal Cancer
Cases | (802) | (125) | (717) | (139) | (810) | (123) | (682) | (147)
Deaths | (374) | (267) | (321) | (312) | 50 | 2017 | 49 | 2021
Endometrial Cancer
Cases | (1344) | (74) | (1421) | (70) | (1553) | (64) | (1996) | (50)
Deaths | (145) | (690) | (160) | (625) | (71) | (1402) | (85) | (1181)
Total Benefits
Cases | (2952) | (34) | (3215) | (31) | (12064) | (8) | (6978) | (14)
Deaths | (908) | (110) | (1046) | (96) | (4500) | (22) | (1880) | (53)

BRCA = breast cancer genetic mutation; DVT = deep venous thrombosis; MI = acute myocardial infarction; OC = oral contraceptive; PE = pulmonary embolism

a Association between OC use and ovarian and breast cancers modeled as ever versus never users.

b Association between OC use and ovarian cancer dependent on duration of use, and between OC use and breast cancer on time since last use.

Table 64 presents these results as the absolute number of case or deaths caused or prevented by OC use per 100,000 women over a lifetime starting at age 10. We also present the number needed to harm (NNH) or number need to prevent (NNP), which is the reciprocal of the absolute risk associated with OC use. For the general population, modeling the effects of exposure as time-dependent compared with ever vs never has an impact on the magnitude of the effect of OC use on both harms and benefits, increasing the number of breast cancer cases but decreasing the number of ovarian cancer. Although the qualitative effects are similar, and the absolute difference between the two different modeling approaches is quite small, the fact that they are different illustrates the potential importance of better data about the relationship between duration of use, time since last use, and the risk of developing specific cancers. There are also some paradoxical results for BRCA carriers (for example, decreased incidence but increased mortality for colorectal cancer among both BRCA1 and BRCA2 carriers), but it is unclear whether this represents the instability of relatively small numbers, or perhaps a competing risk effect because of the high background risk of mortality from ovarian cancer which is reduced by OC use. This series of simulations also resulted in lower estimated mortality, despite increased incidence, from breast cancer when OC effects are modeled based on time or in BRCA1 carriers. As noted in the meta-analysis, breast cancer incidence is increased by OC use, but mortality was not significantly increased. These model results, which are based only on modeling an increased incidence, suggest that some of the effect observed in the studies may be the result of shifts in age-specific incidence resulting in better overall survival. As noted below, we observed similar effects for stroke, which are almost entirely explained by differences in age distribution of cases. Some of this may also be related to a relatively small number of “subjects” with no history of OC use in the simulated data set. Finally, there are structural differences in competing risks depending on how the effects of OC use on the outcomes considered here are modeled, which may also contribute to this effect.

### Effect of Age at First Use and Duration of OC Use

Figures 52 to 76 present the results of simulations at varying ages of starting OCs (15, 20, 25, 30, 35, and 40 years) and duration of use (1, 2, 5, and 10 years) for cancer incidence and mortality, vascular event incidence and mortality, overall life expectancy and combined benefits and harms, and harm to benefit ratio. For all except life expectancy and the harm/benefit ratios, results are presented as changes in absolute incidence or mortality relative to no OC use—values above 0 reflect an increase relative to no OC use, while values below 0 reflect a decrease relative to OC use. Life expectancy is presented as absolute difference in fractions of years. For the harm/benefit ratio, values less than 0 indicate that total harms are reduced relative to no use; values between 0 and 1 indicate that harms are increased but that benefits exceed harms; and values greater than 1 indicate that harms exceed benefits.

Figure 52 Age at first use and duration of use: ovarian cancer incidence

OC = oral contraceptive

Description: Figure 52 shows that ovarian cancer incidence decreases with increasing duration of use at all ages.

Figure 53 Age at first use and duration of use: ovarian cancer mortality

OC = oral contraceptive

Description: Figure 53 shows that ovarian cancer mortality decreases with increasing duration of use at all ages.

Figure 54 Age at first use and duration of use: breast cancer incidence

OC = oral contraceptive

Description: Figure 54 shows that there is no obvious relationship between age at first use or duration of use and breast cancer incidence.

Figure 55 Age at first use and duration of use: breast cancer mortality

OC = oral contraceptive

Description: Figure 55 shows that there is no obvious relationship between age at first use or duration of use and breast cancer mortality.

Figure 56 Age at first use and duration of use: cervical cancer incidence

OC = oral contraceptive

Description: Figure 56 shows that there is no obvious relationship between age at first use or duration of use and cervical cancer incidence.

Figure 57 Age at first use and duration of use: cervical cancer mortality

OC = oral contraceptive

Description: Figure 57 shows that there is no obvious relationship between age at first use or duration of use and cervical cancer mortality.

Figure 58 Age at first use and duration of use: colorectal cancer incidence

OC = oral contraceptive

Description: Figure 58 shows that there is no obvious relationship between age at first use or duration of use and colorectal cancer incidence.

Figure 59 Age at first use and duration of use: colorectal cancer mortality

OC = oral contraceptive

Description: Figure 59 shows that there is no obvious relationship between age at first use or duration of use and colorectal cancer mortality.

Figure 60 Age at first use and duration of use: endometrial cancer incidence

OC = oral contraceptive

Description: Figure 60 shows that there is no obvious relationship between age at first use or duration of use and endometrial cancer incidence.

Figure 61 Age at first use and duration of use: endometrial cancer mortality

OC = oral contraceptive

Description: Figure 61 shows that there is no obvious relationship between age at first use or duration of use and endometrial cancer mortality.

Figure 62 Age at first use and duration of use: deep vein thrombosis incidence

DVT = deep vein thrombosis; OC = oral contraceptive

Description: Figure 62 shows that there is an apparent trend toward increasing deep vein thrombosis incidence with increasing duration of use.

Figure 63 Age at first use and duration of use: deep vein thrombosis mortality

DVT = deep vein thrombosis; OC = oral contraceptive

Description: Figure 63 shows that there is no apparent relationship between deep vein thrombosis mortality with age at first use or duration of use.

Figure 64 Age at first use and duration of use: pulmonary embolism incidence

OC = oral contraceptive; PE = pulmonary embolism

Description: Figure 64 shows that there is an apparent trend toward increasing pulmonary embolism incidence with increasing duration of use.

Figure 65 Age at first use and duration of use: pulmonary embolism mortality

OC = oral contraceptive; PE = pulmonary embolism

Description: Figure 65 shows that there is no apparent relationship between pulmonary embolism mortality with age at first use or duration of use.

Figure 66 Age at first use and duration of use: stroke incidence

OC = oral contraceptive

Description: Figure 66 shows that there is an apparent trend toward increasing stroke incidence with increasing duration of use.

Figure 67 Age at first use and duration of use: stroke mortality

OC = oral contraceptive

Description: Figure 67 shows that there is no apparent relationship between stroke mortality with age at first use or duration of use.

Figure 68 Age at first use and duration of use: myocardial infarction incidence

MI = myocardial infarction; OC = oral contraceptive

Description: Figure 68 shows that there is an apparent trend toward increasing myocardial infarction incidence with increasing duration of use.

Figure 69 Age at first use and duration of use: myocardial infarction mortality

MI = myocardial infarction; OC = oral contraceptive

Description: Figure 69 shows that there is no apparent relationship between myocardial infarction mortality with age at first use or duration of use.

Figure 70 Age at first use and duration of use: life expectancy

OC = oral contraceptive

Description: Figure 70 shows that there is an increase in life expectancy between 1 and 5 years duration of use, but a decrease with 10 years of use.

Figure 71 Age at first use and duration of use: total harms incidence

OC = oral contraceptive

Description: Figure 71 shows that there is an apparent increase in total harms with increasing duration of use with the possible exception of women who start at age 15.

Figure 72 Age at first use and duration of use: total harms mortality

OC = oral contraceptive

Description: Figure 72 shows that there is an apparent trend toward increased mortality from combined harms with time.

Figure 73 Age at first use and duration of use: total benefits incidence

OC = oral contraceptive

Description: Figure 73 shows that the number of prevented ovarian, colorectal, and endometrial cancers decreases with increasing duration of use.

Figure 74 Age at first use and duration of use: total benefits mortality

OC = oral contraceptive

Description: Figure 74 shows that the number of deaths from ovarian, colorectal, and endometrial cancer decreases with increasing duration of time, particularly for women who start before age 35.

Figure 75 Age at first use and duration of use: harm/benefit ratio of OC use on incidence

OC = oral contraceptive

Description: Figure 75 shows that there is no apparent relationship between the ratio of harms to benefits (defined as cases) and age at first use or duration of use.

Figure 76 Age at first use and duration of use: harm/benefit ratio of OC use on mortality

OC = oral contraceptive

Description: Figure 76 shows an apparent trend toward an increasing harm/benefit ratio with increasing duration of use.

Not surprisingly, the relationship between duration of use and outcome is strongest for ovarian cancer, since the effect of OC use on ovarian cancer incidence is directly modeled as a function of duration. There may be an interaction between age at first use and duration for breast cancer. The effect of OC use on breast cancer is modeled as a constant risk until stopping, with a subsequent decline over time. Therefore, women who start at later ages for longer periods of time may be at greater risk because breast cancer incidence increases with age. However, the results of the simulations do not show a clear relationship between age at first use and duration, which may be a function of the relatively small number of simulations for each age/duration combination. There do not appear to be any age/duration effects for the remaining cancers (again, likely due to exposure being modeled simply as ever vs. never use).

For vascular events, there was no clear relationship between age at first use and risk, but estimates for incidence and mortality tended to converge at 10 years of use for all ages of first use. This likely due to the assumption of constant risk—at longer durations of use, there is more opportunity for any effect of OC use on the event to occur, and the estimates are more stable.

For several of the outcomes, particularly breast cancer and stroke, overall lifetime incidence is decreased but overall lifetime cause-specific mortality is decreased for some groups, even though we do not model a separate effect of OC use on cause-specific mortality. There are several possible explanations for this, including random “noise” for rare events, the effects of competing risks, and structural factors in the model (for example, although “women” remain at risk for subsequent events such as a second VTE, this probability is not conditioned on experiencing a previous VTE while on OCs). However, some of the reductions in cause specific mortality may also be related to changes in age-specific mortality from specific conditions—increasing age-specific incidence while on OCs will by definition lead to a shift in the overall incidence to younger ages. Because survival after diagnosis for these conditions is better for younger women (because of lower prevalence of comorbid diseases and, in the case of cancers, potential shifts in stage distribution because of screening), it is possible to have increased incidence along with decreased mortality. We tested this hypothesis for stroke by fixing in-hospital stroke mortality in the model to the national average (9.8%) rather than to age-specific values, which vary from 7.8% in women under 45 years of age to 12.8% in women 85 years and older. Lifetime stroke mortality was 0.9 percent for no OC use, 0.83 percent when modeled as age-specific mortality, and 1.1 percent when modeled at the fixed overall rate, demonstrating the effect of changes in age-specific incidence on overall mortality if mortality is variable across age.

Similar convergences with longer duration of use were observed for combined harms and benefits, with an overall greater reduction in mortality from ovarian, colorectal, and endometrial cancer compared with the increased mortality from other causes (note that the trend was not perfect, which may be due to unstable estimates resulting from too few simulations).

Use of OCs for 5 years or less was associated with net increase in life expectancy except for women 35 years and older. Longer durations were associated with gains in life expectancy in younger women but not women 30 years and older. This is largely explained by the impact of deaths occurring at younger age on overall life expectancy—more potential years lost has a greater impact. These results are consistent with the results showing net gains in life expectancy in Tables 63 and 64: if, as the age of first use versus duration effects suggest, net benefit is optimized by 5 years of use, then one would expect net increases in life expectancy in a population that has a mean duration of use of 5 years, which is the value used in the model.

Note that for each figure, the different shapes 15, 20, 25, 30, 35, and 40 represent the age of starting OC use, while the y-axis represents the absolute change in lifetime incidence or mortality due to the estimated association between OC use and the outcome.

### Harm/Benefit Acceptability

To assess the impact of uncertainty of the estimates of the relative risks associated with OC use on the tradeoffs between benefits and harms, we ran a series of simulations where the value for each relative risk was drawn from the distributions described in Table 60 (200 draws from these distributions, with 10,000 “subjects” per draw, for a total of 2 million simulations).This method allows us to generate estimates of the effect of uncertainty in the parameter estimates on the uncertainty in the output. For example, Figure 77 compares the distribution of the difference in life expectancy in the general population model between modeling OC effects as ever versus never, versus dependent on duration of exposure for ovarian cancer and time since last use for breast cancer. Consistent with the results presented earlier, modeling OC effects based on time results in a greater mean gain in life expectancy. The probabilistic analysis shows this clearly, and also shows the distribution of outcomes, including the small proportion of simulations using ever versus never use which results in net loss of life expectancy.

Figure 77 Distribution of net life expectancy difference due to OC effects^a^ a Based on OC use in the general population for 100 simulations, where OC effects are either time-dependent for breast and ovarian cancer, or modeled simply as ever versus never.

OC = oral contraceptive

Description: Figure 77 compares the distribution of the difference in life expectancy in the general population model between modeling OC effects as ever versus never, versus dependent on duration of exposure for ovarian cancer and time since last use for breast cancer.

For the analysis of net benefits, we present the results as acceptability curves—the y-axis represents the proportion of simulations where a given scenario was optimal at a given “willingness-to-pay” (WTP) in terms of harms incurred versus benefits gained; in other words, the sum of all adverse outcomes divided by the sum of all desired outcomes. The point where the lines cross represents the point where half of the simulations favor OC use and half favor nonuse. At a WTP threshold below the point on the x-axis where the lines cross, the majority of simulations favor not using OCs, and, above that point, OC use is favored. The ratio of harms to benefits ranges from 0 (no excess harms) to 1 (harms equal to benefits).

Figures 78 and 79 show the curves for incidence cases and mortality, respectively. The acceptability threshold where OC use is favored is lower for mortality then for incidence, but for both it is below 0.5. For mortality, the model is based on duration of use results in a slightly, more favorable threshold for OC use: the proportion of simulations where a given acceptability threshold was reached was consistently higher because of the higher estimate of ovarian cancers prevented and the lower number of excess breast cancers.

Figure 78 Harm/benefit acceptability for incidence, modeled as ever/never use or duration of use

OC = oral contraceptive

Description: Figure 78 shows that, if the acceptable ratio of harm to benefit in terms of cases is less than 0.15, OC use is not favored, while at values above this threshold, OC use is favored.

Figure 79 Harm/benefit acceptability for mortality, modeled as ever/never use or duration of use

OC = oral contraceptive

Description: Figure 79 shows that, if the acceptable ratio of harm to benefit in terms of deaths is less than 0.05, OC use is not favored, while at values above this threshold, OC use is favored. The model based on duration of use is slightly more favorable than the model based on ever vs. never use.

We then explored the relative impact of different components of harm and benefit on acceptability by systematically removing different conditions from the numerator or denominator of the harm/benefit ratio and comparing the proportion of simulations where OC use was favored at a given WTP threshold. For ease of visualization, we present only the proportion of simulations where OC use was acceptable for each combination of harms and benefits at a given WTP threshold; implicitly, the proportion of simulations where OC use was not acceptable at that threshold is 100 percent minus the value for OC use.

In these figures, we sequentially remove groups of harms from the numerator, leaving all benefits, then sequentially remove benefits, leaving all harms. The lines represent the following outcomes:

- Harms (incident cases and mortality)
  ○ “All combined”: breast and cervical cancer, DVT, PE, stroke, MI
  ○ “No vascular events”: breast and cervical cancer only
  ○ “No cancers”: DVT, PE, stroke, MI only
- Benefits (prevented incident cases and deaths)
  ○ “All combined”: ovarian, colorectal, and endometrial cancers
  ○ “Ovarian and colorectal”: ovarian and colorectal cancers only
  ○ “Ovarian only”: ovarian cancer only

Removing vascular events from the harms results in a shift to the left of the acceptability curve for incidence. An even greater shift is seen with removal of breast cancer and cervical cancer (Figure 80). Given the very low absolute increase in cervical cancer incidence associated with OCs, this effect is almost entirely due to breast cancer. This is due to several factors. First, although the relative risk of breast cancer attributable to OC use is relatively small, the absolute number of cases is larger than for vascular events. Second, the degree of uncertainty around the risk estimate for breast cancer is larger than it is for vascular events, with a lower bound very close to 1, so that removing the effect of this uncertainty leads to a greater number of simulations favoring OCs at a given threshold. Conversely, removing colorectal and endometrial cancer resulted in a marked shift of the curve to the right—40 percent of the simulations resulted in a harm/benefit ratio (number of harms incurred per case of ovarian cancer prevented) of 1.0 (Figure 81). This suggests that it is more likely that, for OC use solely for ovarian cancer prevention, the number of harms in terms of incident cases is likely to exceed the benefit (of course, the case might be different if patient preferences for the specific harms and benefits were included). Adding colorectal cancer improved the threshold somewhat, but the major effect was seen by replacing endometrial cancer into the equation. These results are consistent with the tables presented above, where the number needed to prevent one endometrial cancer case is substantially lower than for colorectal or ovarian cancer.

Figure 80 Effect of specific harms on harm/benefit acceptability for incidence (duration model only)

Description: Figure 80 shows that the increased incidence of breast cancer is the greatest contributor to an increased harm/benefit ratio with OC use.

Figure 81 Effect of specific benefits on harm/benefit acceptability for incidence (duration model only)

Description: Figure 81 shows that the probability that incident harms will be greater than the number of ovarian cancer cases prevented is approximately 40%.

Results for harms related to mortality were qualitatively similar, but showed an interesting pattern (Figure 82). Removing vascular events actually resulted in decrease in the acceptability threshold at WTO values below 0.1. This is due to the consistent model prediction of increased incidence but decreased mortality from stroke in OC users discussed above: because strokes are included as harms, the net harm in terms of lifetime deaths is smaller when vascular events are included then when they are not. As discussed, these results are due to modeled changes in age-specific incidence leading to changes in age-specific mortality. Taken at face value, these results raise an important point about the limitations of simply counting harms and benefits—clearly, the potential morbidity from a stroke at a young age is substantial, even if mortality is lower, and this needs to be taken into account by decisionmakers at every level, whether through an informal weighting process or formal methods such as quality-adjusted life expectancy. On the benefit side, the pattern was similar to that seen for incident benefits, although the relative contribution of ovarian cancer alone was much greater (Figure 83).

Figure 82 Effect of specific harms on harm/benefit acceptability for mortality (duration model only)

Description: Figure 82 shows that removing vascular events actually resulted in decrease in the acceptability threshold at WTO values below 0.1. This is due to the consistent model prediction of increased incidence but decreased mortality from stroke in OC users discussed above: because strokes are included as harms, the net harm in terms of lifetime deaths is smaller when vascular events are included then when they are not.

Figure 83 Effect of specific benefits on harm/benefit acceptability for mortality (duration model only)

Description: Figure 83 shows that reduction in ovarian cancer mortality is the major contributor to favorable harm/benefit ratios in terms of mortality.

## Discussion

Previous sections of this report have provided discussion of the findings, limitations, and clinical and public health implications of the detailed analyses of OC use and ovarian cancer (Section 2), OC use and other cancers (Section 3), and OC use and vascular events (Section 4). In Section 5, we used mathematical modeling methods to integrate the results of the systematic reviews and meta-analyses of these individual outcomes to better understand the combined effects. In Section 5, we also:

- Summarize the findings of the evidence synthesis
- Compare the results with previous studies
- Discuss the uncertainties, limitations, and subsequent future research needs
- Discuss the clinical and public health implications of the findings, given the uncertainties and limitations

### Summary of the Evidence Synthesis

The following are key points from our systematic review and meta-analyses:

- The incidences of ovarian cancer, colorectal cancer, and endometrial cancer were significantly reduced among women who used OCs, with the magnitude of reduction in ovarian cancer risk significantly associated with duration of use (risk declined with longer duration of use, with no evidence of a threshold effect); endometrial cancer risk was also reduced by longer duration of use. The meta-analysis also found a statistically significant effect of time since last use (protective effect decreased as time since last use increased) but not for other characteristics of OC use including ages at use or formulation.
- The reduction in ovarian cancer risk was consistent in different subgroups of women, including BRCA1 and BRCA2 carriers.
- The incidence of breast cancer was significantly increased among women who used OCs, with the magnitude of the increase significantly associated with time since last use (risk decreased with increasing time since last use). The meta-analyses did not find statistically significant effects of other characteristics of OC use including ages at use or formulation.
- The increase in breast cancer risk was consistent in different subgroups of women, including BRCA1 and BRCA2 carriers.
- The incidence of cervical cancer was increased among women who used OCs, although this result was not statistically significant in the meta-analysis.
- The incidences of DVT (including PE) and ischemic stroke were significantly increased among current users of OCs. Risk was associated with increasing estrogen dose, but the meta-analyses did not identify a significant effect of progestin formulation.
- The incidence of MI was increased among women who use OCs, although the results were not statistically significant in the meta-analysis. Again, risk was associated with increasing estrogen dose and, potentially, progestin formulation.
- All of these results are derived from observational studies and may be affected by unmeasured or uncorrected biases.

#### Modeling Analysis

Key points from our modeling analysis are:

- Using the point estimates for the odds ratios from the meta-analyses (including MI and cervical cancer, where confidence intervals included 1) and adjusting for the age-specific prevalence of OC use, we found the following differences in peak incidence between ever users and never users (for cancers) and current users versus nonusers (for vascular events):
- There was a relatively large absolute increase (maximum increase in annual age-specific incidence 22 per 100,000) in breast cancer risk despite a small relative risk.
- The largest reduction in incidence was in endometrial cancer (maximum decrease in annual age-specific incidence of 55 per 100,000), followed by colorectal cancer (maximum decrease in annual age-specific incidence of 50 per 100,000), and finally ovarian cancer (maximum decrease in annual age-specific incidence of 20 per 100,000), reflecting their relative frequency in women.
- By far the largest absolute increase for any harm was for venous thromboembolism, particularly deep venous thrombosis (maximum increase in annual age-specific incidence of 120 per 100,000); maximum increases in the annual age-specific incidence of PE, stroke, and acute MI were all 30 per 100,000 or less.
- Using a simulation model and these point estimates as well as probabilistic sampling of the age-specific incidence of relevant other events (including hysterectomy, oophorectomy, tubal ligation, and other-cause mortality) to model estimated patterns of OC use in terms of age of starting and duration of use in the general population, we found that:
  ○ The net effect of OC use on these outcomes was to extend mean life expectancy by approximately 1 month, which is consistent with other cancer prevention strategies in the general population.376
  ○ Modeling the association between OC use and ovarian cancer as a function of duration of use, and between OC use and breast cancer as a function of time since last use, resulted in slightly greater gains in life expectancy compared with modeling these results as a function of ever versus never use, due to a greater reduction in ovarian cancer incidence combined with a lower increase in breast cancer incidence when compared with a model where OC effects were solely based on ever versus never use.
  ○ Incorporating the joint effects of duration of use and time since last use decreased the population-level effects of OC use on ovarian cancer incidence and overall mortality slightly compared with duration of use alone, but higher than a simple ever/never model.
  ○ The largest population effect of OC use on incidence of benefits was on colorectal and endometrial cancers rather than ovarian cancers, while reductions in mortality were similar across all three cancers. The largest effect of OC use on both incidence and mortality due to increased risk was seen in breast cancer.
  ○ For all harms, increases in mortality were much smaller than increases in incidence (and, in some simulations, actually lower with OC use), likely due to a shift in incidence to younger ages, when age-specific mortality from all harms (including cancer) is lower.
  ○ Assuming a pattern of use similar to the general population, estimated increases in life expectancy were greatest for BRCA1 carriers (approximately 10 months), due to the much higher incidence of ovarian cancer. Estimates for BRCA2 carriers were approximately equivalent to those for the general population, due to the much larger increase in breast cancer risk relative to the increased ovarian cancer risk.
  ○ Directly modeling ever versus never use results in larger positive effects of OCs compared with alternative methods to simulate lower exposure to OC use.
- When age at first OC use and duration of use were systematically varied, we found that:
  ○ Estimates of the effect on life expectancy were positive for durations of use of 2 years or less and positive for women under age 35 for 5 years of use. Longer duration of use led to either lower life expectancy (women 30 and older) or smaller increases in life expectancy for all except women who started at age 15.
  ○ Estimates for both incidence and mortality for harms (particularly vascular events) were unstable for shorter duration of use across all ages, converging with increasing duration; this is a function of the very low probability of events at younger ages and the assumption of constant risk during use.
  ○ The total reduction in ovarian, colorectal, and endometrial cancer incidence and mortality was directly related to increased duration, which is largely due to the explicitly modeled association between duration and ovarian cancer incidence.
- Using a probabilistic analysis incorporating the range of uncertainty around the relative risk estimates, we found that:
  ○ When the association between OC use and ovarian cancer risk was modeled as a function of duration of use, 45 percent of simulations resulted in a life expectancy gain of 1 and 2 months, while 44 percent resulted in gains of 2 to 3 months. When modeled as a function of ever versus never use, 62 percent of gains were between 1 and 2 months, while only 1 percent was greater than 2 months; 2 percent had a net loss of life expectancy of 1 week.
  ○ For incident harms, breast cancer was the largest contributor. Conversely, for incident benefits, ovarian cancer had almost no effect relative to colorectal and endometrial cancers.
  ○ For mortality, breast cancer was by far the biggest contributor to uncertainty; removing deaths from vascular events had minimal effect. On the benefit side, the contributions of ovarian, colorectal, and endometrial cancers were roughly equivalent.

### Comparison With Previous Modeling Studies

Comparison of the results of the individual meta-analyses with other studies is provided in previous sections of this report. In general, our results were largely consistent with the recent literature, with most of the difference attributable to different inclusion/exclusion criteria.

Our modeling results are roughly consistent with previous U.S.-based studies, which have generally found minimal harms and small-to-moderate net noncontraceptive benefits of OC use—although our overall estimate suggests somewhat larger net benefits, especially in terms of mortality. We briefly describe the main differences in outcomes and approach here.

Fortney et al.351 used a life table approach to estimate net effects on life expectancy, assuming 5 years of use and varying age at first use from 15 to 44 years of age in 5-year increments, and concluded that there was essentially no net effect, with gains of 4 days for women under age 0, and losses of 18 days for women in their 30s up to 80 days for women over age 45. In contrast, we found an overall net increase of 1 to 2 months across all age groups. The following are possible reasons for this discrepancy:

- The paper by Fortney et al. was published in 1986, so we were able to include subsequently published papers. We also used a more formal set of inclusion/exclusion criteria; the authors excluded a condition if there were less than two papers with a significant association, which eliminated breast cancer for consideration, and used formal meta-analysis methods to synthesize the results.
- Fortney et al. did not include breast or colorectal cancer, DVT, or PE, but did include complications of pregnancy, benign gallbladder disease, pelvic inflammatory disease, and rheumatoid arthritis.
- We used different methods for estimating incidence. Although the baseline estimates presented in Table 1 of the paper are reported as those for women not using OCs, it is unclear from either the table or the paper whether these results were adjusted for the prevalence of OC use or simply the overall rates that were subsequently multiplied by the relative risk estimate. Given the high prevalence of a history of OC use, population-based rates—which are the weighted average of the rates in exposed and unexposed—will be much closer to the rates in ever users compared with never users, all else (such as a history of smoking or an inherited thrombophilia) being equal. Thus, simply multiplying the population rate by the relative risk will overestimate the magnitude of the effect of the exposure in users. We estimated expected incidence based both relative risk and prevalence of exposure.
- We modeled competing risks.
- Fortney et al. applied relative risks derived from incidence to mortality. As shown in our results, the increase in mortality for a given outcome resulting from increased incidence in younger ages attributable to OC use may not result in equivalent increases in mortality because of the effect of age on outcome-specific mortality.

Schlesselman66 used meta-analytic methods to estimate relative risks related to duration of use and time since last use and applied these estimates using life-table methods and durations of use of 4, 8, and 12 years to estimate the effect of OCs on ovarian, endometrial, cervical, breast, and liver cancers for women 20 to 54 years of age. The estimated mean number of breast and cervical cancers per 100,000 were similar to ours, but the estimates for ovarian and endometrial cancers were significantly lower.

Differences in approach include:

- As with the paper by Fortney et al., we were able to include papers published subsequent to this 1995 analysis. It is also possible that there were differences in inclusion/exclusion criteria and potential differences in the meta-analytic approach, although this is difficult to ascertain from the paper.
- Schlesselman included estimates of duration of use and time since last use effects for all cancers; we included only those which were statistically significant in the meta-analysis (duration for ovarian cancer, time since last use for breast cancer). As seen in our analysis, this had a noticeable effect on outcomes, and, accumulated across multiple cancers, could result in even greater difference.
- We used a different time horizon of 10 to 100 years compared with Schlesselman's 20 to 54 year range. Depending on the size of any effect of time since last use, this could have a substantial effect. This is likely one of the reasons for the similar results for cervical and breast cancers, which have higher incidences when women are in their 40s and 50s compared with ovarian and endometrial cancers.
- We included different nonreproductive cancers. Schlesselman included liver cancer, which is much less common than colorectal cancer; our analysis shows that a protective effect against colorectal cancer would have a marked impact on overall benefits. It is not clear from the paper how competing risks were modeled.

Sonnenberg et al.350 used a Monte Carlo simulation model to estimate the cost-effectiveness, in dollars per QALY, for a wide range of contraceptive methods. Although the modeling approach is similar to the one we used, the results cannot be directly compared primarily because the results are presented as net effects in terms of QALYs without estimates of individual event rates. The following are other differences:

- Sonnenberg et al. included contraceptive effects, and other contraceptive methods, some of which were assumed to have similar vascular effects as OCs.
- We included papers published subsequent to this 2000 analysis, used different inclusion/exclusion criteria, and used formal meta-analytic methods to derive risk estimates.
- Sonnenberg et al. adjusted for smoking prevalence and the potential interaction between smoking and OC use on relevant outcomes
- They did not include effects on colorectal cancer.
- Data are not provided on the ranges and distributions used in the Monte Carlo simulation.
- The time horizon was very short, only 2 to 5 years, and did not extend past age 50.

### Limitations and Uncertainties

The single most important limitation of this analysis is that it is “synthetic”—it is a synthesis of observational data using statistical and mathematical modeling techniques, rather than a directly observed controlled trial designed to minimize potential biases and optimized to detect a clinically significant effect. Women who use OCs are likely to be different from women who never use OCs in a variety of ways that may affect estimates of the association between OCs and a given outcome. For example, concerns about an increased risk for vascular events among obese women may make providers less likely to prescribe oral contraceptives; to the extent that obesity is associated with increased risk for many cancers, this would lead to an overestimation of a protective effect or an underestimation of an increased risk. Although the effect of these differences on the estimate can be mitigated by appropriate study design and analytic methods, they cannot be eliminated.

The majority of evidence we identified was consistent in both direction and magnitude of effect size, showed some evidence of a duration relationship and was adjusted for known confounders. However, this was also the case for hormone replacement therapy as primary prevention for cardiovascular disease. When synthesized into high-quality models, the results strongly suggested a beneficial effect for most women,377,378 which were subsequently disproven by a randomized trial.379

For most women who are considering OCs for contraception, or who have OCs recommended for indications for which there is strong evidence of effectiveness, the lack of RCT data on OCs and potentially fatal outcomes is important, especially if an increased baseline risk of a particular outcome would affect the decision whether or not to use OCs. Given recent evidence on the comparative effectiveness of OCs and long-acting, reversible contraceptives in terms of pregnancy prevention,380 consideration of the noncontraceptive benefits and harms of OC use relative to other contraceptive methods may become an even greater factor for helping women choose appropriate contraceptive methods. However, quite appropriately, the ultimate decision about using OCs for contraception or as treatment for other conditions should primarily be based on consideration of evidence for their effectiveness for that indication, weighed against the potential harms and other relevant attributes (convenience, duration of effectiveness, etc.).

The considerations are somewhat different when the question being considered is whether to recommend OCs primarily to prevent ovarian cancer; here, the potential for bias in the estimates of both benefits and harms also is particularly critical. As noted in the introduction, ovarian cancer has a high mortality rate; there are no effective screening interventions (and, given the biology of the disease, the prospect of effective screening for most women is poor); and surgical removal of the tubes and ovaries carries risks of operative morbidity and the potential effects of early menopause. (We note that the observed reduction in OC risk with tubal ligation is roughly equivalent to that seen with OC use, even with adjustment of OC use among women with tubal ligation—further evaluation of the potential role of tubal ligation as primary prevention for ovarian cancer for women who have completed childbearing is an important area for future research). Approximately 15 percent of women have never used OCs by age 44,^172^ and based on the distribution reported in the Nurses' Health Study,357 another 10 percent of users have taken OCs for less than 12 months. Given the high mortality of ovarian cancer and the lack of proven alternative strategies for prevention that do not involve removal of the ovaries, a course of OCs as primary prevention is potentially a reasonable strategy but one which warrants further research. Even without the potential for biased estimates from the observational studies in the review, the modeling results indicate substantial remaining uncertainty about the balance of harms and benefits of OC use solely for the prevention of ovarian cancer.

Despite the desirability of an unbiased estimate of risk, a formal prospective trial would face numerous, perhaps insurmountable, challenges, as described below.

Sample size and duration of followup, particularly if ovarian cancer is the primary outcome. For example, in a trial targeting women aged 35 to 39 for prevention of ovarian cancer incidence, the expected incidence ovarian cancer by age 55 would be 0.2 percent; assuming a 70-percent reduction in incidence, a trial would require 20 years of followup of over 70,000 subjects per arm using an alpha of 0.05 and a beta of 0.2. For mortality to be the endpoint, the trial would need to be extended an additional 5 years. Even if endometrial and colorectal cancer were added as trial outcomes, sample sizes would be over 5,000 per arm for a 20-year study to detect differences in incidence and 25,000 for a 25-year study to detect differences in mortality. None of these estimates includes correction for loss to followup or hysterectomy or oophorectomy for other causes.

Although alternative statistical analyses or composite outcomes might reduce sample size somewhat, a trial of OCs versus placebo or another method would still require, at the very least, a similar sample size to the Women's Health Initiative with at least twice the length of followup. Maintaining followup in a study of that size for that duration would be challenging, to say the least. Another issue with a study of such long duration would be the inherent problem of applicability: by the time the study was done, alternative methods of contraception (including OC formulations) may well be available and preferred to the formulations tested in the trial.

Recruitment and inclusion/exclusion criteria. In addition to the normal difficulties of recruitment, a substantial proportion of women who are either never users of OCs or used OCs for less than 12 months would be women who had medical contraindications, religious or other objections to OC use, or who stopped OC use because of side effects. Recruitment is always an issue for any randomized trial; one that uses a daily oral medication with known side effects and potential serious short- and long-term harms for primary prevention of a relatively rare cancer would face more difficulty than usual.

Choice of comparator. For reproductive-age women not using another contraceptive method, placebo alone would not be acceptable, further complicating trial logistics if women in both arms would be required to use an alternative contraceptive method. If some of those methods are also effective against ovarian cancer, or increase risk of vascular events, sample size would need to be increased even more. Given the recognizable effects of OCs on menstrual symptoms, blinding would be difficult.

Safety monitoring. The Women's Health Initiative used a complex composite endpoint that included both benefits and harms; a trial of OCs for primary prevention of ovarian cancer would likely require a similar design. However, establishing appropriate safety monitoring, particularly rules for stopping, would be even more complex since the majority of the vascular harms would occur during treatment, while benefits would not be seen for 15 to 25 years.

These daunting challenges create a dilemma. Ovarian cancer is a disease with high mortality where both the disease itself and the treatments have a profound negative impact on quality-of-life in the time between diagnosis and death—and there are no effective preventive strategies. On one hand, the current evidence, while highly suggestive, has inherent limitations that may be leading to incorrect estimates of OC effectiveness. Even ignoring those limitations, there is a high degree of remaining uncertainty about harm/benefit tradeoffs. Future research to fill in the evidence gaps discussed below should improve the ability of researchers to synthesize the available evidence from observational studies, but ultimately the inherent biases associated with observational studies means that some uncertainty will remain even if all the evidence gaps related to observational studies are filled. On the other hand, a definitive trial to address the question would be, in the best-case scenario, hugely expensive and complex. One option might be a trial in a high-risk population, such as BRCA1 and BRCA 2 carriers, where higher incidence rates would substantially reduce sample size. However, there are different challenges with a study in this population, particularly the choice of appropriate comparator; given the known high risk of these conditions and the availability of other treatment options, a placebo-controlled study might face substantial recruitment challenges, and, without a placebo group, it would be very difficult to draw any inferences about the potential applicability of results in BRCA carriers to the general population.

One important next step in developing a research agenda is to formally identify the situations where a decision to start or continue OCs would be done primarily for the purpose of preventing ovarian cancer (and potentially other cancers) and assess how much certainty would be required to make a recommendation for or against this use. One potential future application of the microsimulation model developed for this review is to address some of these issues quantitatively, to help determine the ultimate feasibility of a definitive trial. A first step might be to apply value-of-information analysis to further quantitate the relative contribution of the uncertainties about the tradeoffs between harms and benefits and evaluate the efficiency of potential study designs and sample sizes.381-383

#### Model Limitations and Evidence Gaps

The limitations of the model and its results can be divided into limitations of the model structure—the type of model, the methods for converting the available literature into probabilities that the model can use, the assumptions about the relationship between different parameters, the methods for analysis—and of the model parameters, which derive from the availability and quality of the data. Because both of these types of limitations are ultimately driven by the data, we discuss how future research can address these limitations in each section.

#### Model Structure Limitations

##### Design

We used a semi-Markov state-transition model, which reflects current practice. Instead of running the model as a cohort analysis, where the model provided estimates of the probability of the events of interest based on the parameter values, we ran the model as a microsimulation, where multiple simulations of a series of “individual” subjects with characteristics drawn from appropriate distributions are performed. The main advantage of this approach is that the conditional probability of a transition from one state to another can be conditioned on the underlying state, the time spent in the simulation, and events in past states in a tractable model structure. The main disadvantage is the computational time required to perform the simulations. Some of this time may be due to the specific software package used, which we chose primarily for its ease of programming; using an alternative program would increase the efficiency of calculations, but would be more difficult to program. Because of the computational time required for some of the analyses, we limited the number of “subjects” for a particular analysis (for example, 5000 per each age at first use and duration of use combination). This resulted in unstable results, especially for rare events. However, even this limitation is helpful, since it reinforces the importance of adequate sample size in achieving stable estimates of rare events, which certainly fits the description of vascular events in young women. More iterations would narrow the confidence intervals for the model-based estimates further—but it is worth considering that if the effect size is small enough to require a very large number of simulations, the individual clinical risk, and public health impact, is likely to be relatively small.

##### Independence of Risks

We assumed that the risk estimates obtained from the meta-analyses, most of which were derived from individual studies with multivariate analyses, were independent of each other—in other words, the estimate for the relative risk for ovarian cancer associated with OC use was independent of any other patient characteristics, such as parity. However, this may not be the case. This may be particularly important for hysterectomy, which is a competing risk for ovarian, cervical, and endometrial cancer, and which may be affected by OC use. We also modeled individual cancer risks independently, but this is clearly not the case, for both familial cancer syndromes and sporadic cancers, which may share risk factors. Ideally, the model would be run using parameter estimates that incorporated correlations where appropriate.

The model-predicted lifetime incidence for cancers, adjusted for population-level estimates of OC use and relative risks estimated from the meta-analyses, closely approximates estimates based directly on age-specific incidence (Appendix F), which provides some reassurance that the assumption of independence is not resulting in substantial bias.

##### Other States and Other Contraceptive Methods

We originally included other relevant health states, including menarche and pregnancy, and the range of other contraceptive methods with their effectiveness against pregnancy. For the purposes of this analysis, we excluded these states and other methods for several reasons. First, there is a lack of data on the dynamics of contraceptive method switching; because the majority of the data on OC use and the outcomes of interest was based on comparisons between OC users and all other methods combined, the assumptions and extra work required to derive reasonable estimates would not have added any extra reliability or precision to our analysis.

Second, during early model runs, it became apparent that pregnancy was also a potential competing risk, one which had different probabilities based on age and contraceptive method. Because parity was almost universally adjusted for in the studies included in the meta-analyses, we elected to eliminate pregnancy as a state. However, for a more comprehensive analysis of the combined harms and benefits of OCs, adding pregnancy (including pregnancy-specific vascular event rates) is an important next step. Including other reproductive states, such as menarche and lactation, would also allow modeling the effect of reduction in ovulation, rather than OC use alone, as a modifier of ovarian cancer risk. However, incorporating these into the model will be facilitated by more standardized reporting, as discussed further below.

Finally, the model, which estimates mortality based on age- and race-specific survival after detection of an incidence case, consistently underestimates lifetime mortality risk compared with estimates derived from death certificate data. This is consistent with other “incidence-based mortality” models, where overall mortality estimates are derived from specific survival functions based on patient or tumor characteristics.384,385 There are multiple explanations for this, including (1) the effect of competing risks for other cause mortality within the model after diagnosis, (2) age/period/cohort effects in the death certificate data that are not reflected in the model estimates, (3) the fact that SEER incidence and survival data represent a sample of the population, while the mortality data are derived from the entire population, and (4) inadequate modeling of mortality more than 5 years after survival (particularly for breast cancer). Since the potential underestimation of cancer mortality affects both potential harms of OC use (breast and cervical cancer) and benefits (ovarian, endometrial, and colorectal), the net effect on the overall balance of mortality harm and benefit is likely to be small but is clearly worthy of further exploration.

##### Other Potential Confounders and Effect Modifiers

We did not model the potential effect of other characteristics, particularly smoking and obesity, which could plausibly affect contraceptive method choice, risk of different cancers or vascular events, or the association between OC use and these outcomes. The potential impact of smoking status and obesity on estimated risks, both at the individual patient level and at the population level, should be incorporated in future modeling studies.

##### Ever Versus Never Exposure Versus Time-Dependent Effects

Although the qualitative results were similar whether ovarian and breast cancer risks were modeled as ever/never exposure versus time dependent, the time-dependent approach resulted in better outcomes (greater life expectancy, lower threshold for acceptable harm/benefit ratios), suggesting that how exposure is modeled (and, implicitly, how exposure is measured in studies) could have a more substantial impact on model predictions if it held for additional outcomes. Conversely, because the increased risk of vascular events during current OC use was assumed to be constant over time, longer duration of OC use resulted in greater risk of a vascular event. If, as some of the studies reviewed suggest, risk is highest in early use, then this assumption overestimates the harms associated with longer duration.

#### Model Structure Evidence Gaps

The following are key future research needs for a model structure:

- Needed are better estimates of correlations between parameters; for example, using the covariate estimates from logistic regression models derived from pooled analyses for all relevant variables instead of the adjusted odds ratios. This would require publication (perhaps in an online appendix), or access to, the actual models used rather than the summary odds ratios and confidence limits typically reported.
- One advantage of microsimulation is that it can generate simulated data sets of individuals, with characteristics such as age of events, history of past events, and so on. These data sets could be used to explore some of these issues related to correlation as well as issues related to study design, sample size, etc. For example, one could simulate a large number of individuals using a fixed estimate of relative risk, then sample the data set using different study designs and sample sizes to identify any systematic effects on bias or precision.
- Incorporate additional reproductive history into models; again, use of simulated data sets could be helpful in exploring the relationship between ovulatory cycles, OC use, and ovarian cancer risk.
- To the extent possible, observational studies should report associations as functions both of ever versus never, or current versus noncurrent use, and duration of use. Pooled analyses, such as those of the Collaborative Group on Epidemiological Studies of Ovarian Cancer,21 are an excellent way to address some of these limitations. Although access to the raw data is extremely useful, the ability to overcome inconsistencies in reporting is ultimately dependent on how consistently the data was collected. As noted below, some standardization of how duration of use and other potentially relevant parameters are both recorded and reported would also be extremely helpful.

#### Model Parameter Limitations

##### Data Reporting/Quality

Data limitations for specific outcomes are noted in the individual sections, but there are general issues that apply to most of the data, particularly for the risk data.

Imprecision and bias. Using a stochastic modeling approach—where data values are drawn from appropriate distributions describing the data—is one way to incorporate the effects of imprecision in estimates resulting from small studies, particularly for rare events, since the effects of the imprecision in the input values are reflected in the distribution of output values. However, even the most precise estimates are not helpful if they are biased in some way; although models can potentially be used to evaluate a possible effect of bias, and to potentially correct for it, there are no clear standards for this.

Data structure. One limitation common to many simulations where age is an important factor affecting probabilities is that available data on age-specific event probabilities are cross-sectional and may represent cohort effects that are not captured in the model. As the figures in Section 1 show, there is some suggestion of a cohort effect in ovarian cancer incidence due to increasing use of OCs; if this is the case, then the reduction in risk predicted by any model that uses these data to generate age-specific probabilities will overestimate the impact of OC use in the future. Some of this effect may also be seen even with harms from vascular events—for example, age-specific probabilities may decrease with time, as awareness of the possibility of complications leads to more selective use of OCs, or increase with time, especially for less severe cases, where a higher index of suspicion on the part of clinicians would lead to a lower threshold for testing to make a definitive diagnosis.

Inconsistency in reporting. As noted in the individual sections, there was wide disparity in how various potential confounders or effect modifiers, such as parity, duration of OC use, time since last use, woman's age, etc., were described in published papers. While we recognize that the needs of specific studies or the idiosyncrasies of particular data sets may require different categorization of relevant parameters during analysis, it would be extremely helpful for meta-analysis and simulation modeling if there were reporting standards that allowed consistent comparison across studies, which could be presented as an alternate to the categorization selected for the main analysis. Again, this could be presented online.

##### Data Choices and Available Data

There were minimal data available for some important potential parameters. For others, available data sources may have inherent biases that affect the model.

Data Sources. We used hospitalization rates, and in-hospital mortality, to derive age-specific probabilities of vascular events. To the extent that these outcomes, in particular DVT, may be managed on an outpatient basis, this will underestimate the rates. Similarly, hysterectomy is increasingly being performed in outpatient settings, and hospital-based data may underestimate true population rates. Use of in-hospital mortality may underestimate longer term mortality due to vascular events, although, to the extent the risk of recurrence is reduced by stopping pills, long-term mortality after OC-associated vascular events may be lower than after events associated with other causes. For cancers, we assumed cure after 5 years and did not incorporate the risk of longer term recurrence, which may underestimate total mortality, particularly for breast cancer.

Utilities/Preferences. Quality-adjusted life expectancy is a generally well-accepted method among health policy researchers for integrating the effects of interventions on both quality-of-life and life expectancy. Although estimates for utilities for all of the relevant outcomes were available, we did not identify any utilities for the use of OCs. The studies that incorporated QALYs in their analyses implicitly assumed that OC use has a utility of 1.0; given that a substantial proportion of women who start OCs discontinue due to side effects, this is clearly not the case.

On the other hand, many women may have improvement in quality of life because of OC effects on menstrual symptoms. Some estimate of the effect of OC use on quality of life in the context of use for prevention purposes is needed. Although groups making recommendations typically focus on a semiquantitative assessment of harms versus benefits with some consideration of quality of life, appropriately capturing patient preferences is especially important for primary prevention. Our acceptability analysis shows that the different harms and benefits contribute differently to incidence (where quality of life is a major factor) compared with mortality. Given that vascular events contribute much more to incidence than mortality (because of the lower age-specific mortality), the potential impact of long-term morbidity from stroke and MI, in particular, should ultimately be considered.

Another factor that needs to be incorporated in any preference/quality-of-life study is time preference. In the setting of OCs for primary prevention of cancer, the benefits occur much later in the future than the potential risks. Deriving empirically-driven discount rates is an important component of future research.

Progestin-only pills. Because the risk of vascular events appears to primarily be related to the estrogen component of combined OCs (Section 4), and because there is evidence from both basic science170 and observational studies (Section 2) that the progestational component of OCs is the primary factor affecting reduction in ovarian cancer risk, use of progestin-only pills as the OC of choice for reducing OC risk seems attractive. However, largely because there is little use of progestin-only pills, there is a paucity of evidence regarding their effects, particularly on long-term outcomes.

Other patterns of use. Although there is no biological reason to suspect that continuous OC use (i.e., no week without pills to allow menses) would have differential effects on any of these outcomes, data to confirm this would be useful. In addition, more data on both the frequency of use and the outcomes of use for OCs in women over 45 would be extremely helpful.

#### Model Parameters Evidence Gaps

The following evidence gaps for model parameters should be addressed:

- Consensus among researchers and editors on standardized reporting of key variables would be extremely helpful. One approach would be through the development of consensus data collection and reporting standards under the sponsorship of one or more organizations with an interest in the area, such as the American Cancer Society, NIH, WHO, etc.
- More precise estimates of longer term outcomes are needed.
- Patient preferences for relevant outcomes, as well as for the use of OCs, need to be incorporated into models used for estimating the outcomes of OC use. Ideally, these would include both utilities derived from standard methods of utility elicitation, as well as by methods such as conjoint analysis which allow elicitation of preferences for multiple attributes.386
- More data are needed on the potential effects of progestin-only pills on long-term outcomes. However, given our findings that vascular events make a minimal contribution to the harm/benefit ratio in terms of mortality, the value of further research into the potential of progestin-only pills for primary prevention should be assessed first. This could be facilitated by better data on the long-term quality-of-life impact of vascular events in young women.

### Potential Next Steps

Although we did not perform a formal value-of-information analysis, the results of our evidence synthesis and modeling do suggest that addressing certain research needs first would have a greater impact in reducing uncertainty about the relative harms and benefits of OCs for primary prevention of ovarian cancer. Within the context of specific issues discussed above, we would suggest the following broad areas be given priority.

Assessing patient preferences, including those related to regular use of OCs for noncontraceptive purposes. Given the finding that vascular events contribute little to uncertainty about the harm/benefit ratio in terms of mortality, a better understanding of how long-term morbidity associated with these events in younger women, would be extremely helpful. This research area also has the advantage of requiring considerably fewer resources than, for example, a 20-year randomized trial of more than 140,000 subjects.

Achieving greater certainty about the importance of time-related effects relative to ever-never exposure. This could be facilitated by consensus on reporting standards. In terms of cancers, we would suggest prioritizing colorectal cancer and breast cancer because (a) there is greater certainty regarding the time-dependent effects of ovarian cancer, (b) although endometrial cancer is an important contributor to the mortality harm/benefit ratio, there is less uncertainty about the benefits of OC use, and (c) increased cervical cancer risk has almost no contribution to the overall mortality risk (note that this is not likely to be true in settings where adequate screening, or widespread population coverage with vaccination against oncogenic human papillomavirus, is unavailable). In terms of vascular events, the most important uncertainty is the extent to which risk may or may not decrease with increasing duration of use.

Another need is for better understanding of the potential effects of OC formulation on breast and colorectal cancer risks. Again, these two contribute substantially to the harm/benefit ratio in terms of mortality. Particularly in the context of the potential use of progestin-only pills, greater certainty about the potential effects relative to combination OCs on these two cancers would be particularly helpful.

### Clinical and Public Health Implications of the Findings

The overall strength of evidence for the literature review was moderate to low with applicability for current practice affected by two major factors. First, there was a large number of studies (many of higher quality) performed outside of the United States, where several differences may affect observed associations—differences in available OC formulations; in population patterns of contraceptive use; in genetic factors (e.g., inherited thrombophilias) and acquired factors (e.g., prevalence of smoking) that interact with OC effects; and in health system attributes, particularly regarding population coverage for screen-detectable cancers. Second, particularly for cancers, the long period between exposure to OCs and development of the cancer means that much of the available literature is based on exposure to OC formulations that are no longer on the market—which has implications for both harms and benefits.

Although there are published guidelines for assessing the quality of modeling studies,387 there is no consensus on how to consider the “strength of evidence” of the results of modeling studies. In most cases, modeling is done because randomized trials are not available and, even in the best-case scenario, will be based on evidence from lesser quality studies. Given the inherent limitations of modeling, many of which are discussed above and in Appendix F, the strength of evidence for even the most sophisticated model will be at best moderate and, realistically, low in most cases. That is certainly the case with these results, which are based on low-moderate quality evidence for the most important parameters of interest.

With these caveats, based on our synthesis of the best available literature, the clinical and public health implications of our review include the following:

- Assuming that the general estimates of increased or decreased risk are not overly biased by observational studies, the net effects on cancers and vascular events of current patterns of OC use in the general population likely result in a net increase in life expectancy of 1-2 months, which is comparable to many other preventive interventions.376 This is in addition to any effects from prevention of unwanted pregnancy. In our probabilistic analysis, OC use resulted in net loss in life expectancy in less than 5 percent of simulations.
- The model predicts similar net gains in BRCA1 and BRCA2 carriers; in BRCA1 carriers, who have marked elevation in ovarian cancer risk, the gain may be as high as 10 months.
- These results should be reassuring to women who are considering OC use for contraceptive purposes or who are prescribed OCs for treatment of other conditions.
- Other than for ovarian cancer, the effects of increasing duration of use for individual outcomes is unclear. The modeling results suggest that the net benefits of OC use decrease between 5 years of use (the approximate mean duration of use in the population) when they are generally positive, especially at younger ages, and 10 years of use for all but the youngest women. This may be a function of a conservative assumption about constant risk over time for exposed women, but based on the available data, there is less confidence in the net benefits of duration of use longer than 5 years for women at average risk of ovarian cancer. For a woman who has used OCs for 5 years and is considering other contraceptive methods, there is insufficient evidence to suggest continuing to use OCs solely for their effect on ovarian cancer risk—particularly since there is consistent evidence that at least one other method (tubal sterilization) reduces risk by a similar order of magnitude and recent evidence that other nonpermanent methods may also reduce risk.123
- For a woman who has never used OCs for contraception, and who otherwise does not have a contraindication to their use, there is insufficient evidence to recommend for or against a course of OCs solely for ovarian cancer prevention, regardless of her age or the potential duration of use. The estimated net benefits of OC use on mortality are equally distributed between prevention of ovarian cancer (relatively low incidence but high mortality), colorectal cancer (intermediate incidence and mortality), and endometrial cancer (high incidence but low mortality), while the net harms are driven by breast cancer (high incidence but relatively low mortality). In terms of incidence, the net benefits of OC use are largely driven by endometrial and colorectal cancer, while the net harms are largely due to the increased incidence of breast cancer. We did not include the potential impact of specific harms on quality of life—for example, a stroke at an early age, even if less likely to be fatal, may have a profound negative impact on quality of life.