# Oral Contraceptives and Vascular Events

## Background

Oral contraceptives (OCs) are the most common form of birth control in the United States.172 Over 10 million women aged 15 to 44 (17%) are current users of OCs, and 45 million women have used OCs at some time in their life (“ever users”).

Since the 1960s, several life-threatening vascular events have been reported to be associated with OC use.258 These include venous thromboembolic (VTE) disease (encompassing deep venous thrombosis [DVT] and pulmonary embolism [PE]), stroke, and myocardial infarction [MI]). Ischemic heart disease and stroke are the leading cause of death in the United States and worldwide, accounting for greater than 30 percent of all deaths.259 Given the large number of women currently using OCs, an increased risk of such vascular events associated with OC use is an important public health issue.

Over the last several decades, formulations of OCs have drastically changed. Many formulations that were used by participants in earlier studies are no longer available. Most contemporary OCs contain lower doses of estrogen and new generations of progestins. Progestin-only OCs are also commonly prescribed. Women using progestin-only OCs, lower dose estrogen OCs, or OCs with newer progestins may experience modified risks of VTE, stroke, and MI compared with users of older OCs.260,261 There are few studies focusing on the acute vascular risks associated with contemporary OC use. In addition, more information is needed to understand whether particular groups of women may be at heightened risk of VTE, stroke, or MI due to use of specific OC formulations or presence of thromboembolic risk factors.

In Section 4 of our systematic review and meta-analysis, we evaluate the association between contemporary OC use and the risks of developing VTE, stroke, or MI. We also investigate whether the risk of these acute vascular complications varies according to estrogen dose, progestin generation, or duration of OC use or among populations of women with elevated risk for thromboembolic events.

## Relevant Key Questions

The seven KQs developed for the entire systematic review are listed in Section 1 (refer to Figure 7 for a roadmap of this report). For Section 4, we performed a systematic review and meta-analysis on the part of KQ 5 that addresses the acute vascular events associated with OC use; namely, VTE, stroke, and MI.

KQ 5: What are the harms of OC use, including breast cancer incidence, cervical cancer incidence, venous thromboembolic disease, stroke, or myocardial infarction? How do these harms vary by dose or formulation, duration of use, or specific population?

### Analytic Framework

Figure 32 shows the analytic framework that guided this section of the review.

Figure 32 Analytic framework for OCs and vascular events

KQ = Key Question; OC = oral contraceptive

Description: Figure 32 depicts Key Question 5 within the context of the PICO (population, interventions, comparators, and outcomes) that will be the focus of Section 4, Oral Contraceptives and Vascular Events.

## Methods

### Inclusion and Exclusion by PICOTS

Table 42 describes the PICOTS criteria that guided the literature search for this section of the review.

Table 42 Summary of inclusion and exclusion criteria for OCs and vascular events

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | - All KQs; ○ Women taking OCs for contraception or women taking OCs for primary prevention of ovarian cancer^a^; ○ Women who do not have a history of ovarian cancer and have not undergone bilateral oophorectomy | Nonhuman studies
Interventions | OC use (includes OC use for varying time periods and OC use with different formulations) | Study does not provide a description of at least one of the following:; 1. OC formulation(s) used; 2. length of OC use
Comparators | No use of combination or progestin-only OCs, including either no contraceptive method at all or contraceptive methods other than combination or progestin-only OCs (e.g., natural family planning, barrier methods, sterilization, intrauterine devices, injectable or implantable hormonal contraception) | Study does not include non-OC controls; i.e., an estimate of outcomes in women not using OCs (population estimates are acceptable) or a comparison between OC formulations
Outcomes | Study reports quantitative association between exposure to OCs and either incidence or disease-specific mortality for any of the following:; - Venous thromboembolic disease (including deep vein thrombosis or pulmonary embolus); - Stroke; - Myocardial infarction | Study only reports outcomes related to assisted reproductive technologies or abortion
Timing | Studies of any duration | None
Setting | All settings | None
Study design | - Controlled studies (randomized trials, cohort studies, case-control studies), pooled patient-level meta-analyses, or systematic reviews and study-level meta-analyses^b^; - Study sample size ≥ 100 subjects for nonrandomized studies^c^ | - Not a clinical study (e.g., editorial, nonsystematic review, letter to the editor); - Exploratory study with inadequate sample size
Publications | - English-language only; - Peer-reviewed articles; - Study reports venous thromboembolic event, stroke, or myocardial infarction outcome of interest and was published on or after 01-Jan-1995^d^ | Non-English articles^e^

KQ = Key Question; OC = oral contraceptive

a If the purpose of OC use was unclear, it was assumed to be contraception.

b Systematic reviews and study-level meta-analyses were excluded from abstraction; those representing key sources were hand-searched as potential sources of additional material.

c Small nonrandomized studies <100 subjects were excluded as confidence intervals for outcomes of interest are generally quite wide if appropriate adjustment for confounding is performed, and variability in reporting of potential confounders makes meta-analysis problematic.

d Date ranges for acute vascular events associated with OC use were restricted to more recent years to reflect currently available formulations.

e Non-English articles were excluded (1) due to the high volume of literature available in English-language publications (including the majority of known important studies) and (2) due to concerns about the applicability of non-English publication studies to populations in the United States. The variability in OC formulations approved for use across countries increases the likelihood that non-English language studies would include OCs not available or not in use in the United States.

### Meta-Analytic Methods

To examine the effect of OCs on the risk of developing acute vascular complications, we analyzed the following relationships:

- Temporal relationships:
  ○ Current versus noncurrent OC use
  ○ Ever versus never OC use
  ○ Duration of current OC use
- OC formulation:
  ○ Estrogen dose (high versus low)
  ○ Progestin generation (first, second, third, and fourth generations)
- Special populations:
  ○ Blood-clotting disorders
  ○ Cardiovascular risk factors
  ○ Migraines

When study designs and outcomes reported were similar and the population in the study was broad (e.g., not Factor V Leiden carriers), we estimated pooled odds ratios with 95% confidence intervals (95% CIs) using a random-effects model. We evaluated heterogeneity visually and with the Cochran Q statistic using a threshold p-value of less than 0.10. We stratified analyses by study type (case-control, cohort, pooled analyses). All meta-analyses were performed using Comprehensive Meta-Analysis Version 2 (Biostat; Englewood, NJ; 2005).68

Confidence intervals from the included study publications were entered into the Comprehensive Meta-Analysis (CMA) program. However, many of these confidence intervals had been rounded to a single decimal place. The CMA program checks the intervals for symmetry in the logarithmic scale. In certain cases, the rounded limits were not accepted by CMA. In such cases, we kept the point estimate as given but changed the confidence limits so that they were symmetric. This resulted in slight differences in the confidence intervals in the forest plots when compared with the study publications.

Results were discussed qualitatively when study numbers were insufficient for meta-analysis, when confidence intervals around measures of association were not reported or could not be calculated, or when a study included a special population that is not likely to be representative of the general population of reproductive age women.

#### Pooled Analyses

We included pooled analyses in our meta-analyses if all three of the following conditions were met:

- None of the individual studies included in the pooled analysis had already been included for meta-analysis.
- At least half of the studies in the pooled analysis were published on or after January 1, 1995.
- Data in the pooled analyses were presented such that their inclusion in the current meta-analysis was feasible.

#### Temporal Relationships

##### Current OC Use

For prior sections of this report, the primary exposure to OCs was defined as ever use compared with never use of OCs. While the exact mechanisms responsible for the increased risk of VTE, stroke, or MI among OC users are unknown, there is evidence that the risk is increased in current users of OCs, with past users demonstrating either no risk or lower risk than current users of OCs.262-265 Indeed, the majority of studies identified for these outcomes defined the primary exposure as current versus noncurrent OC use. Therefore, for Section 4, we defined the primary exposure as current use of OCs. Current use is defined as use within the year preceding the diagnosis of each outcome. The referent category was noncurrent use of OCs, which can consist of never users, former users, or both.

##### Ever OC Use

As noted above, our primary exposure was defined as current use (use within 1 year preceding diagnosis) rather than ever use as defined in the other sections.

##### Duration of OC Use

We were unable to perform meta-analyses for any of the outcomes of interest in relation to duration of OC use because there were too few studies to power the analysis. In order to have adequate power in the analysis, 20 or more studies would be needed for a particular outcome. The results of our included studies are therefore discussed qualitatively.

#### OC Formulation

All current OC formulations contain ethinyl estradiol, but the dose of this estrogen varies and may modify the risk of vascular events. We divided OC formulations by high-dose estrogen (assumed to be ≥50 mcg ethinyl estradiol) and low-dose estrogen (assumed to be <50mcg ethinyl estradiol). For estrogen dose formulation analyses, we included studies that compared the risks of developing VTE, stroke, or MI among current OC users by low versus high estrogen dose.

OC formulations were also categorized according to generation of progestin. Originally, progestins used in OCs were developed for their antigonadotropin effects leading to contraception. The resulting progestins also had effects on other steroid receptors including estrogen receptors, androgen receptors, glucocorticoid receptors, and mineralocorticoid receptors. Each progestin may increase or decrease the activity of these receptors, leading to various symptom profiles (acne, water retention, etc.). Newer progestins have been developed with a goal of not only preventing conception but also offering the best side effect profile: lighter bleeding, less acne, no bloating. Progestins have been classified in generations according to their appearance in the market and not on their chemical structure or interactions.266 For the purpose of our analyses, first-generation progestins include norethindrone and ethynodiol diacetate; second-generation include levonorgestrel and norgestrel; third-generation include gestodene, desogestrel, and norgestimate; and fourth-generation include drospirenone, dienogest, and cytoproterone acetate. When an odds ratio was presented for a specific OC formulation, we included that odds ratio categorized by the generation of the progestin used.

## Results

This section presents results of our detailed analysis of the relationship between OCs and acute vascular events, which include VTE (DVT and PE), stroke, and MI. Of note, no randomized controlled studies were identified for any of the outcomes of interest; therefore, the analyses are based on observational studies.

### OC Use and Venous Thromboembolism Incidence

We identified 33 studies that evaluated the association between OC use and the incidence of VTE.181,260-264,267-313 Of these studies, 20 were case-control studies and 14 were cohort studies; 10 studies were rated good quality, 21 fair quality, and 3 poor quality. Twenty-five studies assembled patient groups that were fully or partially based in Europe or the UK; only 7 included patients from the United States (Table 43).

Table 43 Study characteristics and association between OC use and venous thromboembolism incidence

Study^a^ | Study Details | OR | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^b^
Case-Control
Anonymous, 1995^181^ Anonymous, 1995^268^ Anonymous, 1998^267^ | Women aged 20–44 yr in WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception [underlined: Cases]: 372 VTE, hospital [underlined: Controls]: 460 no VTE, hospital Recruitment period: 1990–1994 | 4.1 | 3.2 to 5.2 | BMI, smoking, alcohol consumption, varicose veins, hypertension in pregnancy | Africa, Asia, Europe, Latin America | Good | 1
Bloemenkamp, 1995^260^ Bloemenkamp 2000^302^ | Consecutive women aged 15–49 yr with a first episode of proven DVT [underlined: Cases]: 126 DVT, anticoagulation clinics [underlined: Controls]: 159 no DVT, source NR Recruitment period: 1988--1992 | NR | NR | NA | Netherlands | Fair | 2
Andersen, 1998^269^ | Women aged 18–49 yr in regional discharge summaries from 10 hospitals First- and second-generation users [underlined: Cases]: 24 VTE (including PE), hospital [underlined: Controls]: 134 no VTE, blood donors Third-generation users [underlined: Cases]: 16 VTE (including PE), hospital [underlined: Controls]: 134 no VTE, blood donors Recruitment period: 1997–NR | 5.2 | 1.6 to 16.4 | Parity, BMI, Smoking | Denmark | Fair | 1
Andersen, 1998^269^ | | 48.6 | 5.6 to 423.0 | Parity, BMI, Smoking | Denmark | Fair | 1
Lidegaard, 1998^270^ | Women aged 15–44 yr in all hospitals in Denmark [underlined: Cases]: 375 VTE, hospital registry [underlined: Controls]: 1041 no VTE, source NR Recruitment period: 1980–1993 | NR | NR | NA | Denmark | Fair | 2
Bloemenkamp, 1999^271^ | Women aged 15–49 yr in medical centers in Amsterdam [underlined: Cases]: 185 VTE, hospital [underlined: Controls]: 591 no VTE, hospital Recruitment period: 1982–1995 | 3.9 | 2.6 to 5.7 | Age, family history, center, calendar time | Netherlands | Good | 1
Lewis, 1999^261^ Heinemann, 1999^272^ Suissa, 1997^273^ Suissa, 2000^274^ | Women aged 16–44 yr in Transnational Study on Oral Contraceptives and the Health of Young Women [underlined: Cases]: 505 VTE, hospital [underlined: Controls]: 2270 no MI, thromboembolic CVA, or VTE, hospital and community Recruitment period: 1993–1996 | 2.90 | 2.06 to 4.09 | Age, BMI, smoking, alcohol use, duration of use by generation, duration of previous use by generation, switching by generation | Austria, France, Germany, Switzerland, UK | Fair | 1
Todd, 1999^299^ | Women aged 15–49 in the UK MediPlus database [underlined: Cases]: 106, idiopathic VTE, registry [underlined: Controls]: 569, no VTE, registry Recruitment period: 1992–1997 | NR | NR | NA | UK | Fair | 2
Jick, 2000^296^ | Women aged 15–39 yr taking third-generation OCs or OCs with levonorgestrel [underlined: Cases]: 99, VTE, registry [underlined: Controls]: 366, no VTE, registry Recruitment period: 1993–1999 | NR | NR | NA | UK | Good | 2
Spannagl, 2000^275^ | Women aged 15–49 yr in population-based cohort study [underlined: Cases]: 80 VTE including PE, from cohort study [underlined: Controls]: 406 no VTE or PE, from cohort study Recruitment period: 1995–1997 | 3.0 | 1.8 to 5.0 | BMI, varicose veins, family history of VTE | Germany | Poor | 1
Lidegaard, 2002^276^ | Women aged 15–44 in national patient registry [underlined: Cases]: 987 VTE including PE, registry [underlined: Controls]: 4054 Recruitment period: 1994–1998 | NR | NR | NA | Denmark | Good | 2
Legnani, 2002^277^ | Women aged 15–68 with specific genetic mutations [underlined: Cases]: 301 VTE including PE, hospital [underlined: Controls]: 650, population Recruitment period: 1994--2000 | NR | NR | NA | Italy | Fair | 2
Legnani, 2004^278^ | Women aged 15–68 yr with specific genetic mutations [underlined: Cases]: 195 VTE including PE, hospital [underlined: Controls]: 488, population Recruitment period: 1994–2000 | NR | NR | NA | Italy | Fair | 2
Sidney, 2004^262^ | Members of California Kaiser Permanente Medical Care Program aged 18–44 yr [underlined: Cases]: 196 VTE hospital and administrative records [underlined: Controls]: 746, hospital and administrative records Recruitment period: 1998–2000 | 2.99 | 1.86 to 4.81 | Age | U.S. | Good | 1
Jick, 2006^298^ | Women aged 15–39 yr in the PharMetrics database who were prescribed OCs containing norgestimate, desogestrel, or levonorgestrel [underlined: Cases]: 281 VTE including PE, registry [underlined: Controls]: 1055, registry Recruitment period: 2000–2005 | NR | NR | NA | U.S. | Fair | 2
Huerta, 2007^264^ Farmer, 2000^279^ | Women aged 20–79 yr in UK General Practice Research Database VTE [underlined: Cases]: 197 VTE, registry [underlined: Controls]: 788, no VTE, registry | 1.85 | 1.38 to 2.48 | Age, BMI, smoking, calendar year, cancer, fractures in last month, surgery in last 6 mo, use of warfarin sodium, visits to family physician in last yr | UK | Good | 1
Huerta, 2007^264^ Farmer, 2000^279^ | DVT [underlined: Cases]: 122 DVT, registry [underlined: Controls]: 788, no DVT, registry | 2.05^c^ | 1.46 to 2.89 | Age, BMI, smoking, calendar year, cancer, fractures in last month, surgery in last 6 mo, use of warfarin sodium, visits to family physician in last yr | UK | Good | 1
Huerta, 2007^264^ Farmer, 2000^279^ | PE [underlined: Cases]: 75 PE, registry [underlined: Controls]: 788 no PE, registry | 1.56^c^ | 1.04 to 2.35 | Age, BMI, smoking, calendar year, cancer, fractures in last month, surgery in last 6 mo, use of warfarin sodium, visits to family physician in last yr | UK | Good | 1
Huerta, 2007^264^ Farmer, 2000^279^ | Recruitment period: 1994–NR | | | Age, BMI, smoking, calendar year, cancer, fractures in last month, surgery in last 6 mo, use of warfarin sodium, visits to family physician in last yr | UK | Good | 1
Austin, 2009^280^ | African-American women aged 18–49 yr [underlined: Cases]: 60 DVT or PE, hospital [underlined: Controls]: 196 no DVT or PE, outpatients Recruitment period: NR | 2.8 | 1.4 to 5.7 | Age | U.S. | Fair | 1
Van Hylckama Vlieg, 2009^281^ | Women <50 yr in anticoagulation clinics MEGA study [underlined: Cases]: 1524 DVT or PE, anticoagulation clinic [underlined: Controls]: 1760 no DVT or PE, partners of cases Recruitment period: 1999–2004 | 4.39^d^ | 3.87 to 5.09 | Age, period of inclusion | Netherlands | Good | 1
Barsoum, 2010^282^ | Rochester Epidemiology Project, age NR [underlined: Cases]: 726 VTE, registry [underlined: Controls]: 830 no VTE, registry Recruitment period: 1988–2000 | 4.03 | 1.83 to 8.89 | BMI, “previously identified risk factors” | U.S. | Good | 1
Dinger, 2010^283^ | Women aged 15–49 in survey of primary care and specialty physicians [underlined: Cases]: 680 DVT or PE, outpatients [underlined: Controls]: 2720 no DVT or PE, outpatients Recruitment period: 2002–2008 | 2.4 | 1.8 to 3.2 | Parity, BMI, family history, smoking, personal history of VTE, duration of OC use, education, chronic disease, concomitant medication | Germany | Fair | 1
Heinemann, 2010^284^ | Women aged 15–49 yr in survey of physicians, and registry [underlined: Cases]: 434 DVT or PE, outpatients and registry [underlined: Controls]: 1920 no DVT or PE, community Recruitment period: 2002–2006 | NR | NR | NA | Austria | Good | 2
Jick, 2011^312^ | Women aged 15–44 yr in the PharMetrics database in the U.S. [underlined: Cases:] 186 OC users with VTE, registry [underlined: Controls]: 681 OC users and no VTE, registry Recruitment period: After 2001 | NR | NR | NA | U.S. | Fair | 2
Parkin, 2011^300^ | Women aged 15-44 yr in UK General Practice Research Database [underlined: Cases]: 61 VTE, registry [underlined: Controls]: 215 no VTE, registry Recruitment period: 2002–2009 | NR | NR | NA | UK | Fair | 2
Cohort
Farmer, 1995^285^ | Women aged 14–45 registered with participating general practices in the UK [underlined: Exposed]: 111,449 person-years [underlined: Unexposed]: 542,906 person-years Recruitment period: 1990–1991 | NR | NR | NA | UK | Fair | 2
Grodstein, 1996^286^ | Women ≥30 yr in Nurses' Health Study [underlined: Exposed]: 731,326 person-years [underlined: Unexposed]: 829,240 person-years Recruitment period: 1976–1992 | 2.2 | 0.8 to 5.9 | Age, parity, BMI, smoking, postmenopausal hormone use, diabetes, high blood pressure, high cholesterol, time period | U.S. | Fair | 1
Farmer, 1997^287^ | Women aged 15–49 in General Practice Research Database [underlined: Exposed]: 234,899 [underlined: Unexposed]: NR (database includes ∼1.1 million women) Recruitment period: 1992–1997 | NR | NR | NA | UK | Fair | 2
Hannaford, 1998^288^ | Royal College of General Practitioners' (RCGP) Oral Contraception Study DVT [underlined: Exposed]: 335,181 person-years [underlined: Unexposed]: 228,727 person-years | 1.6 | 1.25 to 2.04 | Age, parity, smoking, social class | UK | Poor | 1
Hannaford, 1998^288^ | PE [underlined: Exposed]: 335,181 person-years [underlined: Unexposed]: 228,727 person-years | 1.56 | 1.14 to 2.14 | Age, parity, smoking, social class | UK | Poor | 1
Hannaford, 1998^288^ | Mean age at study entry: 49 Recruitment period: 1968–NR | | | Age, parity, smoking, social class | UK | Poor | 1
Herings, 1999^301^ | Women aged 15-49 yr in eight Dutch cities [underlined: Exposed to 3^rd^ generation progestins]: 29,986 person-years [underlined: Exposed to 2^nd^ generation progestins]: 24,953 person-years Recruitment period: 1986–1995 | NR | NR | NA | Denmark | Fair | 2
Conard, 2004^289^ | Women aged 15–50 yr in Hemostasis and Thrombosis Unit [underlined: Exposed]: 102 [underlined: Unexposed]: 102 Recruitment period:1992–1997 | 0.8 | 0.2 to 3.9 | Age, BMI, thrombophilia | France | Fair | 4
Samuelsson, 2004^290^ | Women aged 15–44 yr in hospital in Jamtland [underlined: Exposed]: 43 [underlined: Unexposed]: 32 Recruitment period: 1991–2000 | NR | NR | NA | Sweden | Fair | 2
Dinger, 2007^297^ | Women in the EURAS study [underlined: Exposed]: 16,534 prescribed DRSP-containing OCs [underlined: Unexposed:] 26,341 prescribed other OCs Recruitment period: 2000–2004 | NR | NR | NA | Austria, Belgium, Denmark, France, Germany, Netherlands, UK | Good | 3
Seeger, 2007^291^ | Women aged 10–59 yr in health insurance database [underlined: Exposed]: 22,429 [underlined: Unexposed]: 4858 Recruitment period: 2001–2004 | NR | NR | NA | U.S. | Fair | 2
van Vlijmen, 2007^292^ | Women aged 15–50 yr in specialty clinic [underlined: Exposed]: 135 [underlined: Unexposed]: 87 Recruitment period: NR | 9.7 | 3.0 to 42.4 | Clustering of women within families | Netherlands | Fair | 4
Gronich, 2011^311^ | Women aged 12–50 yr in a health care plan in Israel [underlined: Exposed]: 431,223 use episodes. Total of 819,749 woman-years of followup Recruitment period: 2002–2008 | NR | NR | NA | Israel | Fair | 2
Lidegaard, 2011^293^ | Women aged 15–49 yr in national registries [underlined: Exposed]: 2,821,686 person-years [underlined: Unexposed]: 4,960,730 person-years Recruitment period: 1995–2005 | 2.83 | 2.65 to 3.01 | NA Age, calendar year, education level | Denmark | Fair | 1, 2
Le Gal, 2010^294^ | Women >18 yr in 12 thrombosis clinics [underlined: Exposed]: 49 [underlined: Unexposed]: 247 Recruitment period: 2001–2006 | 0.6 | 0.1 to 2.8 | Age | U.S., Canada, France, Switzerland | Fair | 4
van Vlijmen, 2011^295^ | Female relatives from 4 family cohorts (first-degree relatives of consecutive patients with VTE or premature atherosclerosis) [underlined: Exposed]: 571 [underlined: Unexposed]: 227 Recruitment period: 1995–2004 | 2.1 | 1.1 to 4.1 | Pregnancy and clotting defects | Netherlands | Fair | 4

BMI = body mass index; CI = confidence interval; DRSP = drospirenone; DVT = deep venous thrombosis; mo = month/months; NA = not applicable; NR = not reported; OC = oral contraceptive; OR = odds ratio; PE = pulmonary embolism; UK = United Kingdom; U.S. = United States; VTE = venous thromboembolism; WHO = World Health Organization; yr=year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Meta-analysis code: 1 = Included in this meta-analysis of current versus noncurrent OC use; 2 = Excluded due to current versus noncurrent OR not reported or not calculable; 3 = Excluded due to progesterone-only OC use; 4 = Excluded due to family history of VTE or thrombophilia.

c This odds ratio is not included in the meta-analysis because it represents a subset of the total VTE population (OR=1.85).

d Calculated by pooling the ORs of individual subgroups.

#### Current Versus Noncurrent OC Use

Fourteen studies261-264,268,269,271,275,280-283,286,288 were included in this meta-analysis examining the effect of current versus noncurrent OC use on VTE incidence. Of these, 11 were case-control studies representing a combined 4565 cases and 10,901 controls; and 3 were cohort studies representing 3,888,193 exposed person-years and 6,018,697 unexposed person-years. Six studies were rated good quality, 6 fair quality, and two poor quality (Table 43). Only four studies in this meta-analysis included patients from the United States.262,280,282,286

In addition to the 14 studies included in the meta-analysis, a recently published, good-quality study293 reported relative risks of VTE associated with several different progestin formulations compared with no OC use. The data from this important study were not included in the meta-analysis so as not to inappropriately pool odds ratios with adjusted relative risks, with the latter calculated based on person-years of exposure. This study also included patients from an earlier publication by Lidegaard et al.263 Data from the earlier study are included in the meta-analysis. The study by Andersen et al.269 contributed two ratio measures because the risk was only reported separately by progestin generation. The VTE outcome included PE and DVT in the majority of studies. One study286 included only PE cases. The comparison groups for noncurrent OC users was (1) never users in six studies, (2) former and never users in seven studies, and (3) unspecified in one study.

Abstracted data not included in this meta-analysis are specified (with rationale) in Table 43. Reasons for exclusion from this analysis included the following: no reporting of odds ratios for current versus noncurrent OC users;260,277,278,284,285,287,290,291,296,298-301,311,312 family history of VTE or thrombophilia in control group and cases;289,292,294,295 and only including progesterone only OCs.297

Figure 33 shows the random-effects meta-analysis of the 14 studies. The result is an estimated odds ratio of 2.97 (95% CI, 2.46 to 3.59), demonstrating a significant increase in VTE risk with current OC use. There was significant heterogeneity, with a Q-value of 82.207 for 14 degrees of freedom, p<0.001.

Figure 33 Forest plot for current versus noncurrent OC use and the risk of VTE

CI = confidence interval; OC = oral contraceptive

Note: the study by Andersen (1998) contributed two ratio estimates because the risk was reported separately by progestin generation.

Description: Figure 33 shows the random-effects meta-analysis of the 14 studies. The result is an estimated odds ratio of 2.97 (95% CI, 2.46 to 3.59), demonstrating a significant increase in VTE risk with current OC use.

##### Sensitivity Analyses

We performed sensitivity analyses by excluding studies that did not include patients from the United States. The odds ratio for the remaining four studies was essentially unchanged from the larger analysis (OR, 3.00; 95% CI, 2.15 to 4.19). A second sensitivity analysis excluded the two poor-quality studies and resulted in a similar OR of 3.17 (95% CI, 2.62 to 3.83).

#### Ever Versus Never OC Use

One cohort study288 examined the effect of ever versus never OC use on the risk of VTE. The risks of DVT and PE were significantly increased in ever versus never users with a risk ratio of 1.56 (95% CI, 1.14 to 2.14) for PE and 1.66 (95% CI, 1.25 to 2.04) for PE. However, these “ever users” included current and past users.

Three studies represented in the current versus noncurrent meta-analysis262-264 stratified ever users by current and former users to examine whether current versus ever use conferred different risk for VTE. In all three studies, the odds of developing VTE were significantly increased among current users. However, one case-control study262 found no difference in the odds of VTE for ever versus never users (OR, 1.25; 95% CI, 0.78 to 2.01) and no difference in the odds of VTE for former versus never users (OR, 0.73; 95% CI, 0.44 to 1.21). A second case-control study264 found only slightly increased odds of PE for former versus never users (OR 1.27; 95% CI, 1.08 to 1.49) but no difference in the odds of DVT (OR 1.14; 95% CI, 0.98 to 1.34). The cohort study263 found no increased odds of VTE among former versus never users (OR 1.08; 95% CI, 0.98 to1.18). We did not conduct a meta-analysis of ever versus never OC use because of the high heterogeneity of the studies and the low clinical relevance of the question.

##### PE Incidence Among OC Users

Most studies included PE in the definition of VTE. Three studies, however, examined the relationship between OC use and the incidence of PE separately from DVT. Two studies looked at the risk among current users. The third looked at the risk among ever versus never users. There were not enough data for a meta-analysis. One good-quality case-control study264 evaluated the odds of developing PE, DVT, or both PE and DVT among current versus noncurrent OC users. The adjusted odds ratios were similar for all comparisons. For DVT, the odds ratio was 2.05 (95% CI, 1.46 to 2.89); for PE, odds ratio was 1.56 (95% CI, 1.04 to 2.35); and for both DVT and PE, 1.85 (95% CI, 1.38 to 2.48). A fair-quality cohort study286 that evaluated the risk of PE for current or former OC users demonstrated a trend toward increased risk among current users, but the confidence intervals were not significant, with a risk ratio of 2.2 (95% CI, 0.8 to 5.9). For former OC users, the odds ratio was 0.8 (95% CI, 0.5 to 1.2). A poor-quality cohort study288 evaluated the risk of PE among ever versus never users and found a risk ratio of 1.56 (95% CI, 1.14 to 2.14) and a similar risk ratio of 1.60 for DVT alone (95% CI, 1.25 to 2.04). Ever users included current and former users of OCs.

#### Duration of OC Use

Two fair-quality cohort studies263,292 and four case-control studies (3 good quality and 1 fair)262,276,296,302 evaluated the relationship between duration of OC use and risk of VTE. Related data from articles considered part of one study grouping263,276 are represented in both the case-control and cohort categories due to a relationship between the represented patient populations. There were not enough data for a meta-analysis of the risk of VTE among current OC users by duration of use because of the varying time periods of duration of OC use reported in these 5 studies.

In a European case-control study,302 women using OCs for 6 months or less had an increased odds of VTE compared with longer users (OR, 3.0; 95% CI, 0.6 to 14.8); however, the vast majority of VTEs (97 of 109) occurred in women using OCs for more than a year. In a second European case-control study,276 current OC users of more than 1 year had 0.5 times the odds of developing VTE compared with users of less than 1 year. In a good-quality case-control study from the United States,262 the odds of VTE among current versus noncurrent users was 5.43 (95% CI, 2.12 to 13.94) for use less than 1 year. For women using OCs for 1 to 5 years, the odds were similar at 5.73 (95% CI, 2.98 to 10.99) and were lower for those using OCs for greater than 5 years at 3.12 (95% CI, 1.99 to 4.88). In a European cohort study,263 the rate ratio (RR) of VTE for current users was higher among women who had used for less than 1 year (RR, 4.17; 95% CI, 3.73 to 4.66) than for those who used OCs 1 to 4 years (RR, 2.98; 95% CI, 2.73 to 3.26) or greater than 4 years (RR, 2.76; 95% CI, 2.53 to 3.02). In a fair-quality case-control study from Europe,296 the odds of VTE was higher among users of all types of OCs during the first 6 months versus 7 months or more of use (OR, 3.8; 95% CI, 1.8 to 9.0).

#### OC Formulation

##### Estrogen Dose

Three studies260,271,276,293 evaluated the relationship between high estrogen (≥50 mcg) and low estrogen (<50 mcg) OCs on the risk of VTE (Table 44). Of these, two were case-control studies representing 1298 cases and 4804 controls and one cohort study representing 7,782,416 person-years. One study was rated good quality and two fair quality.

Table 44 Data for risk of VTE on low-dose versus high-dose estrogen

Study^a^ | Formulation | OR or RR | 95% CI | Notes
Low-Dose EE vs. Noncurrent Use
Bloemenkamp, 1995^260^ | EE 30 mcg and desogestrel | 8.7 | 3.9 to 19.3 | Premenopausal women
Bloemenkamp, 1995^260^ | EE 30 mcg and levonorgestrel | 3.8 | 1.7 to 8.4 | Premenopausal women
Bloemenkamp, 1995^260^ | EE 35 mcg and noresthisterone or lynestrenol | 3.8 | 1.2 to 12.5 | Premenopausal women
Bloemenkamp, 1999^271^ | EE 30 mcg and levonorgestrel | 3.7 | 1.9 to 7.2
Bloemenkamp, 1999^271^ | EE 30 mcg and desogestrel | 4.9 | 2.5 to 9.4
Bloemenkamp, 1999^271^ | EE 30 mcg and gestodene | 5.2 | 1.3 to 20.6
Bloemenkamp, 1999^271^ | EE 20 mcg and desogestrel | 24.7 | 2.8 to 213.5
Lidegaard, 2002^276^ | 30-40 EE | 3.4 | 2.4 to 7.1 | <1 year vs nonuse (never + former)
Lidegaard, 2002^276^ | 20 EE | 4.3 | 2.8 to 4.2 | <1 year vs nonuse (never + former)
Lidegaard, 2011^293^ | EE 30-40 mcg and norethisterone | 1.57 | 0.84 to 2.92 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 30-40 mcg and phasic levonorgestrel | 2.28 | 1.85 to 2.83 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 30-40 mcg and levonorgestrel | 2.19 | 1.74 to 2.75 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 30-40 mcg and norgestimate | 2.56 | 2.18 to 3.01 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 30-40 mcg and desogestrel | 4.21 | 3.63 to 4.87 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 30-40 mcg and gestodene | 4.23 | 3.87 to 4.63 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 30-40 mcg and drospirenone | 4.47 | 3.91 to 5.11 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 30-40 mcg and cyproterone | 4.10 | 3.37 to 4.99 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 20 mcg and desogestrel | 3.26 | 2.88 to 3.69 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 20 mcg and gestodene | 3.50 | 3.09 to 3.97 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 20 mcg and drospirenone | 4.84 | 3.19 to 7.33 | Adjusted relative risk
High-dose EE vs. Noncurrent Use
Bloemenkamp, 1995^260^ | EE 50 mcg and levonorgestrel or lynestrenol | 3.4 | 1.1 to 10.7 | Premenopausal women
Bloemenkamp, 1999^271^ | EE 50 mcg and lynestrenol or levonorgestrel or noresthisterone | 8.7 | 2.9 to 25.8
Lidegaard, 2002^276^ | 50 EE | 4.2 | 2.4 to 7.1 | <1 year vs nonuse (never + former)
Lidegaard, 2011^293^ | EE 50 mcg and norethisterone | 5.66 | 3.12 to 10.3 | Adjusted relative risk
Lidegaard, 2011^293^ | EE 50 mcg and levonorgestrel | 3.54 | 2.48 to 5.05 | Adjusted relative risk

CI = confidence interval; EE = ethinyl estradiol; OR = odds ratio; RR = relative risk

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

Table 45 lists the odds ratios for the meta-analysis of estrogen dose level. The cohort study293 was not included in the meta-analysis due to the inability to calculate an odds ratio for the data. The results show no differences in the incidence of VTE by estrogen dose level. A formal test for difference gives a p-value of 0.7974. There was no significant heterogeneity. The estimated value of σ is 0.0.

Table 45 Estimated odds ratio by estrogen-dose level (VTE incidence)

Estrogen Dose | Odds Ratio (95% Confidence Interval)
Low | 3.39 (2.32 to 4.96)
High | 3.06 (1.32 to 7.10)

However, in the study by Lidegaard et al.,293 which was not included in this meta-analysis, the first-generation progestin norethisterone in combination with 50 mcg of ethinyl estradiol was associated with a higher risk (RR 5.66; 95% CI, 3.12 to 10.3) than all of the other formulations studied, including norethisterone in combination with 30 to 40 mcg of ethinyl estradiol (RR 1.57; CI, 0.84 to 2.92) and norethisterone without estrogen (RR 0.56; CI, 0.29 to 1.07). These findings suggest that an increase in the ethinyl estradiol dose in combination with norethisterone from 30–40 mcg to 50 mcg may be associated with a more than doubling of risk of VTE. Notably, there was not as large an increase in VTE risk associated with high-dose versus low-dose estrogen in combination with levonorgestrel (RR 3.54 with high-dose and RR 2.19 with low-dose, overlapping confidence intervals).

We were unable to conduct a meta-analysis for the odds of VTE among progestin-only OC users (i.e., pills containing no estrogen); however, several studies addressed this question. A European case-control study276 found a nonsignificant increase in the odds of VTE (OR 2.0; 95% CI, 0.8 to 5.1) for progestin-only OC users compared with nonusers. This same group of investigators293 subsequently reported data from a large cohort of women in Denmark that demonstrated a nonsignificant decrease in the relative risk of VTE for progestin-only OC users compared with nonusers (RR for norethisterone 0.56; CI, 0.29 to 1.07 and RR for desogestrel 0.64; CI, 0.29 to 1.42). A multinational case-control study272 also found no difference in the odds of VTE (OR 0.68; CI, 0.28 to 1.66) among current users of progestin-only OCs versus nonusers.

##### Progestin Generation

As discussed previously, for the purpose of our analyses, first-generation progestins include norethindrone and ethynodiol diacetate; second-generation include levonorgestrel and norgestrel; third-generation include gestodene, desogestrel, and norgestimate; and fourth-generation include drospirenone, dienogest, and cytoproterone acetate. Six case-control studies representing 4257 cases and 11,791 controls181,261,270,273,276,280,281,284 were included in this meta-analysis examining the effect on VTE incidence of varying progestin generations in current users of combination OCs.

Four studies were rated good quality and three fair quality. Only one study280 included patients from the United States. Table 46 lists the included studies, generation of progesterone studied, and odds ratios. An additional large cohort study representing 8,010,290 person-years293 reported relative risks of VTE associated with several different progestin generations. The findings from this study are summarized in Table 46 but could not be included in the meta-analysis because odds ratios were not reported.

Table 46 Data for outcomes on progestin generation (VTE incidence)

Study^a^ | Formulation^b^ (Vs. Noncurrent OC Use) | OR | 95% CI | Notes
First Generation
Anonymous, 1995^181^ | First generation/EE < 50 mcg | 3.37 | 1.44 to 7.93 | Europe only (developing countries excluded)
Anonymous, 1995^181^ | First generation/EE ≥ 50 mcg | 4.05 | 1.92 to 8.54 | Europe only (developing countries excluded)
Lidegaard, 1998^270^ | First generation | 1.8 | 0.9 to 3.6 | VTE (PE + DVT)
Lewis, 1999^261^ | First generation | 8.48 | 3.03 to 23.86
Lidegaard, 2002^276^ | <1 year of use first generation | 4.1 | 2.4 to 7.1
Austin, 2009^280^ | First generation | 4.1 | 1.1 to 14.9 | African-American women
Van Hylckama Vlieg, 2009^281^ | Lynestrenol | 5.6 | 3.0 to 10.2
Van Hylckama Vlieg, 2009^281^ | Noresthisterone | 3.9 | 1.4 to 10.6
Lidegaard, 2011^293^ | Norethisterone/EE 50 mcg | 5.66 | 3.12 to 10.3 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Lidegaard, 2011^293^ | Norethisterone/EE 30-40 mcg | 1.57 | 0.84 to 2.92 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Lidegaard, 2011^293^ | Norethisterone (no estrogen) | 0.56 | 0.29 to 1.07 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Second Generation
Anonymous, 1995^181^ | Second generation/EE ≥ 50 mcg | 3.83 | 2.44 to 6.02 | Europe only (developing countries excluded)
Anonymous, 1995^181^ | Second generation/EE < 50 mcg | 3.61 | 2.53 to 5.13 | Europe only (developing countries excluded)
Suissa, 1997^273^ | Second generation | 6.6 | 2.5 to 17.8 | <1 year of use
Lidegaard, 1998^270^ | Second generation | 1.6 | 1.0 to 2.5
Lewis, 1999^261^ | Second generation | 2.85 | 1.92 to 4.22
Lewis, 1999^261^ | Other second generation | 3.25 | 1.89 to 5.58
Lewis, 1999^261^ | Levonorgestrel | 2.63 | 1.75 to 3.95
Lidegaard, 2002^276^ | Second generation | 2.9 | 2.2 to 3.8
Lidegaard, 2002^276^ | Levonorgestrel | 3.6 | 2.6 to 4.9
Austin, 2009^280^ | Second generation | 2.9 | 0.9 to 9.3 | African-American women
Van Hylckama Vlieg, 2009^281^ | Second generation (levonorgestrel) vs. none | 3.6 | 2.9, 4.6
Heinemann, 2010^284^ | Second generation | 3.14 | 2.21 to 4.47
Lidegaard, 2011^293^ | Levonorgestrel/EE 50 mcg | 3.54 | 2.48 to 5.05 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Lidegaard, 2011^293^ | Levonorgestrel/EE 30-40 mcg | 2.19 | 1.74 to 2.75 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Lidegaard, 2011^293^ | Phasic levonorgestrel/EE 30-40 mcg | 2.28 | 1.85 to 2.83 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Third Generation
Anonymous, 1995^181^ | Third generation/EE < 50 mcg | 7.36 | 4.20 to 12.90 | Europe only (developing countries excluded)
Lewis, 1999^261^ | Third generation | 2.26 | 1.46 to 3.50
Lewis, 1999^261^ | Norgestimate | 3.65 | 2.17 to 6.12
Lewis, 1999^261^ | Desogestrel 30 mcg | 2.52 | 1.56 to 4.09
Lewis, 1999^261^ | Gestodene | 2.25 | 1.40 to 3.60
Lewis, 1999^261^ | Desogestrel 20 mcg | 1.56 | 0.85 to 2.86
Austin, 2009^280^ | Third generation | 3.4 | 0.48 to 20.3 | African-American women
Lidegaard, 2011^293^ | Norgestimate/EE 30-40 mcg | 2.56 | 2.18 to 3.01 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Lidegaard, 2011^293^ | Desogestrel/EE 30-40 mcg | 4.21 | 3.63 to 4.87 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Lidegaard, 2011^293^ | Gestodene/EE 30-40 mcg | 4.23 | 3.87 to 4.63 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Fourth Generation
Van Hylckama Vlieg, 2009^281^ | Drospirenone | 6.3 | 2.9 to 13.7
Van Hylckama Vlieg, 2009^281^ | Cyproterone acetate | 6.8 | 4.7 to 10.0
Lidegaard, 2011^293^ | Drospirenone/EE 30-40 mcg | 4.47 | 3.91 to 5.11 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Lidegaard, 2011^293^ | Cyproterone/EE 30-40 mcg | 4.10 | 3.37 to 4.99 | Adjusted relative risk (not included in meta-analysis of odds ratios)
Lidegaard, 2011^293^ | Drospirenone/EE 20 mcg | 4.84 | 3.19 to 7.33 | Adjusted relative risk (not included in meta-analysis of odds ratios)

CI = confidence interval; EE = ethinyl estradiol; OC = oral contraceptive; OR = odds ratio

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b First-generation progestins = norethindrone and ethynodiol diacetate; second-generation = levonorgestrel and norgestrel; third-generation = gestodene, desogestrel, and norgestimate; fourth-generation = drospirenone, dienogest, and cytoproterone acetate.

Table 47 lists the results of the meta-analysis. We found no difference in the odds of VTE by progestin generation. An overall test for differences gives a chi-square value of 8.1 for 3 degrees of freedom, p=0.044. There was significant heterogeneity. The estimated value of σ is 0.24. The t-value is 4.89 for 11 degrees of freedom, p=0.0005. The value of σ is larger than many of the standard errors for the observed odds ratios.

Table 47 Estimated odds ratio by progestin generation of combined OCs relative to noncurrent use (VTE incidence)

Generation | Odds Ratio (95% Confidence Interval)
First | 4.06 (2.66 to 6.19)
Second | 3.28 (2,49 to 4.31)
Third | 4.06 (3.09 to 5.32)
Fourth | 5.36 (2.78 to 10.32)

Additional reports260,268,271,279,283,287,291,296,297,299-301,311,312 giving information about the risk of VTE associated with different generations of progestin use are provided in Table 48. These data were not in a format that was useful for meta-analysis because the comparisons were between users of various types of OCs, and the studies did not report odds of VTE between current and noncurrent users. There were also many overlapping patients between these studies and between some of these studies and those included in the meta-analysis reported above. One fair-quality cohort study,287 one good-quality case-control study,279 and one fair-quality case-control study,299 all conducted in the United Kingdom, found no difference in the odds or risk of VTE among users of OCs containing progestins of different generations but similar ethinyl estradiol doses. A good quality large European cohort study297 found no difference in VTE odds among current users of dienogest- or drospirenone-containing OCs and those using other OCs containing similar estrogen dose. Another fair quality case control study283 had similar findings. Another fair-quality European case-control study260 found a significant increase in odds of VTE among current users of desogestrel, a third-generation OC, compared with first- and second-generation OCs (OR, 2.5; 95% CI, 1.2 to 5.2). A separate, good-quality case-control study271 found no difference in VTE risk between OC users of third-generation progestins versus those using second-generation progestins. A large, fair-quality cohort study291 reported VTE incidence among initiators of OCs containing drospirenone (a fourth-generation OC) versus initiators of other OCs followed on average for 7.6 months. They found no significant difference in risk (RR, 0.9; 95% CI, 0.5 to 1.6).

Table 48 Comparative risk of VTE among different progestin formulations and generations (VTE incidence)

Study^a^ | Formulation^b^ | Referent | OR, RR, or HR | 95% CI | Notes
Anonymous, 1995^268^ | Desogestrel | Levonorgestrel | 2.4 | 1.3 to 4.6 | OR adjusted for BMI, alcohol consumption, Oxford region varicose veins, HTN in pregnancy, smoking
Anonymous, 1995^268^ | Gestodene | Levonorgestrel | 3.1 | 1.6 to 5.9 | OR adjusted for BMI, alcohol consumption, Oxford region varicose veins, HTN in pregnancy, smoking
Anonymous, 1995^268^ | Desogestrel or gestodene | Levonorgestrel | 2.7 | 1.6 to 4.6 | OR adjusted for BMI, alcohol consumption, Oxford region varicose veins, HTN in pregnancy, smoking
Bloemenkamp, 1995^260^ | Desogestrel | Levonorgestrel | 2.2 | 0.9 to 5.4 | RR adjusted for age
Bloemenkamp, 1995^260^ | Desogestrel with 30 mcg EE | All other OCs | 2.5 | 1.2 to 5.2 | RR adjusted for age
Farmer, 1997^287^ | All second generation | All third generation | 1.68 | 1.04 to 2.75 | RR adjusted for 5-year bands
Farmer, 1997^287^ | Levonorgestrel | Other second generation | 0.51 | 0.19 to 1.33 | RR adjusted for 5-year bands
Farmer, 1997^287^ | Levonorgestrel | Desogestrel/EE 30 mcg | 1.17 | 0.60 to 2.26 | RR adjusted for 5-year bands
Farmer, 1997^287^ | Levonorgestrel | Desogestrel/EE 20 mcg | 2.51 | 1.09 to 5.44 | RR adjusted for 5-year bands
Farmer, 1997^287^ | Levonorgestrel | All desogestrel | 1.76 | 0.91 to 3.48 | RR adjusted for 5-year bands
Farmer, 1997^287^ | Levonorgestrel | Gestodene | 1.32 | 0.70 to 2.49 | RR adjusted for 5-year bands
Farmer, 1997^287^ | Monophasic levonorgestrel | Sequential levonorgestrel | 2.09 | 0.93 to 4.70 | RR adjusted for 5-year bands
Farmer, 1997^287^ | Monophasic levonorgestrel | All third generation | 1.97 | 1.00 to 3.87 | RR adjusted for 5-year bands
Bloemenkamp, 1999^271^ | Monophasic third generation | Levonorgestrel | 1.9 | 0.8 to 4.5 | OR adjusted for age, family history, center, calendar time
Herings, 1999^301^ | Third-generation OC | Second-generation OC | 4.2 | 1.7 to 10.2 | RR adjusted for year and age
Todd, 1999^299^ | Desogestrel | Levonorgestrel | 1.4 | 0.7 to 2.8 | OR adjusted for BMI, smoking, diastolic blood pressure, non-OC prescriptions
Todd, 1999^299^ | Gestodene | Levonorgestrel | 1.3 | 0.7 to 2.7 | OR adjusted for BMI, smoking, diastolic blood pressure, non-OC prescriptions
Todd, 1999^299^ | Norethisterone | Levonorgestrel | 0.5 | 0.2 to 1.6 | OR adjusted for BMI, smoking, diastolic blood pressure, non-OC prescriptions
Todd, 1999^299^ | Norgestimate | Levonorgestrel | 0.7 | 0.2 to 2.4 | OR adjusted for BMI, smoking, diastolic blood pressure, non-OC prescriptions
Todd, 1999^299^ | Cyproterone acetate | Levonorgestrel | 0.8 | 0.2 to 3.3 | OR adjusted for BMI, smoking, diastolic blood pressure, non-OC prescriptions
Farmer, 2000^279,c^ | Desogestrel/EE 30 mcg | Levonorgestrel/EE 30 mcg | 1.0 | 0.6 to 1.6 | OR adjusted for BMI, smoking status, diastolic BP, asthma, duration of OC exposure, and non-OC/nonasthma prescriptions
Farmer, 2000^279,c^ | Gestodene/EE 30 mcg | Levonorgestrel/EE 30 mcg | 0.8 | 0.5 to 1.3 | OR adjusted for BMI, smoking status, diastolic BP, asthma, duration of OC exposure, and non-OC/nonasthma prescriptions
Farmer, 2000^279,c^ | Desogestrel/EE 20 mcg | Levonorgestrel/EE 30 mcg | 1.3 | 0.6 to 2.5 | OR adjusted for BMI, smoking status, diastolic BP, asthma, duration of OC exposure, and non-OC/nonasthma prescriptions
Farmer, 2000^279,c^ | Triphasic levonorgestrel/EE | Levonorgestrel/EE 30 mcg | 1.4 | 0.6 to 0.8 | OR adjusted for BMI, smoking status, diastolic BP, asthma, duration of OC exposure, and non-OC/nonasthma prescriptions
Farmer, 2000^279,c^ | Norgestimate/EE 35 mcg | Levonorgestrel/EE 30 mcg | 0.9 | 1.6 to 0.4 | OR adjusted for BMI, smoking status, diastolic BP, asthma, duration of OC exposure, and non-OC/nonasthma prescriptions
Farmer, 2000^279,c^ | Norethisterone/EE 35 mcg | Levonorgestrel/EE 30 mcg | 3.3 | 1.0 to 10 | OR adjusted for BMI, smoking status, diastolic BP, asthma, duration of OC exposure, and non-OC/nonasthma prescriptions
Farmer, 2000^279,c^ | Cyproterone/EE 35 mcg | Levonorgestrel/EE 30 mcg | 0.7 | 0.3 to 1.4 | OR adjusted for BMI, smoking status, diastolic BP, asthma, duration of OC exposure, and non-OC/nonasthma prescriptions
Farmer, 2000^279,c^ | Drospirenone | Levonorgestrel | 0.9 | 0.6 to 1.4 | OR adjusted by year of birth
Farmer, 2000^279,c^ | Gestodene | Levonorgestrel | 0.7 | 0.4 to 1.1 | OR adjusted by year of birth
Farmer, 2000^279,c^ | Norgestimate | Levonorgestrel | 0.7 | 0.3 to 1.4 | OR adjusted by year of birth
Jick, 2000^296^ | Third-generation OCs | Levonorgestrel | 2.3 | 1.3 to 3.9 | OR adjusted for BMI, smoking, duration of OC use, OC switching. Controls matched by year of birth, index date, general practice
Dinger, 2007^297,c^ | Desogestrel | Levonorgestrel and other OCs | 1.1 | 0.7 to 1.7 | HR adjusted for age, BMI, duration of OC use, VTE history
Dinger, 2007^297,c^ | Desogestrel | Levonorgestrel | 1.0 | 0.6 to 1.7 | HR adjusted for age, BMI, duration of OC use, VTE history
Dinger, 2007^297,c^ | Desogestrel | Other OCs | 1.3 | 0.8 to 2.0 | HR adjusted for age, BMI, duration of OC use, VTE history
Seeger, 2007^291^ | Drospirenone/EE | Other OCs | 1.0 | 0.5 to 1.9 | RR Current OC use
Dinger, 2010^283^ | Dienogest/EE | Other low-dose OC | 0.9 | 0.6 to 1.4 | OR adjusted for history of VTE, BMI, duration of OC use, parity, education, chronic disease, medications, smoking
Dinger, 2010^283^ | Dienogest/EE | Low-dose levonorgestrel/EE | 1.0 | 0.6 to 1.8 | OR adjusted for history of VTE, BMI, duration of OC use, parity, education, chronic disease, medications, smoking
Dinger, 2010^283^ | Desogestrel/EE | Low-dose levonorgestrel/EE | 1.0 | 0.5 to 1.8 | OR adjusted for history of VTE, BMI, duration of OC use, parity, education, chronic disease, medications, smoking
Gronich, 2011^311^ | Drospirenone | Third-generation OC | 1.43 | 1.15 to 1.78 | Rate ratio adjusted for age, diabetes, hyperlipidemia, hypertension, cancer, smoking, obesity, duration of use
Jick, 2011^312^ | Drospirenone | Levonorgestrel | 2.4 | 1.7 to 3.4 | OR adjusted for age, index year, and duration of OC use
Parkin, 2011^300^ | Drospirenone | Levonorgestrel | 3.3 | 1.4 to 7.6 | OR adjusted for BMI, using multiple imputation analysis

BMI = body mass index; CI = confidence interval; EE = ethinyl estradiol; HR = hazard ratio; OC = oral contraceptive; OR = odds ratio; RR = risk ratio; VTE = venous thromboembolism

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b First-generation progestins=norethindrone and ethynodiol diacetate; second-generation=levonorgestrel and norgestrel; third-generation=gestodene, desogestrel, and norgestimate; fourth-generation=drospirenone, dienogest, and cytoproterone acetate.

c Published study reported odds ratios and 95% CIs with levonorgestrel as the index value. For consistency in this table, we reversed the direction of this comparison and converted the odds ratios and 95% CIs to reflect the relative odds of VTE with use of levonorgestrel as the reference group.

On the other hand, a good-quality analysis of the WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Conception268 reported statistically significant increases in the odds of VTE associated with third-generation progestins desogestrel (OR, 2.4; 95% CI, 1.3 to 4.6) and gestodene (OR, 3.1; 95% CI, 1.6 to 5.9) compared with the second-generation progestin levonorgestrel. Jick et al.296 also reported higher odds of VTE associated with third-generation OCs compared with the second-generation progestin levonorgestrel (OR, 2.3; 95% CI, 1.3 to 3.9) in a good-quality case-control study using the U.K. General Practice Research Database. Herings et al.301 reported similar findings among a population of Dutch women; in a fair-quality cohort study, they reported a risk ratio of 4.2 (95% CI, 1.7 to 10.2) for VTE among new users of third-generation progestins compared with new users of levonorgestrel. Another fair-quality case-control study conducted in the United States312 demonstrated an increased odds ratio of VTE associated with the fourth-generation progestin drospirenone compared with levonorgestrel (OR, 2.4; 95% CI, 1.7 to 3.4). Similarly, Parkin et al.300 reported an increased risk of nonfatal VTE associated with the fourth-generation progestin drospirenone compared with levonorgestrel (OR, 3.3; 95% CI, 1.4 to 7.6) in a fair-quality case-control study that used the U.K. General Practice Research Database. Finally, a fair-quality cohort study conducted in Israel311 reported an elevated risk ratio for VTE of 1.43 (95% CI, 1.15 to 1.78) associated with OCs that contained drospirenone, relative to OCs that contained a third-generation progestin.

#### Special Populations and Risk of VTE with OC use

##### Blood-Clotting Disorders

Several studies evaluated the risk of VTE among special populations, including women with known predispositions to blood clotting. We were not able to perform a meta-analysis on this relationship because of a small number of studies that differed from each other in several important ways, including patient population and selections of controls.

One fair-quality case-control study269 found an interaction between the use of OCs and the presence of inherited thrombophilia—protein C, protein S, antithrombin deficiencies, or Factor V Leiden mutation—such that OC users with inherited thrombophilia had a higher risk of VTE than is explained by the presence of either risk factor (i.e., a “multiplicative” effect). The odds ratio for inherited thrombophilia was 2.6 (95% CI, 0.7 to 9.3), and the odds ratio for inherited thrombophilia plus OC use was 63 (CI, 6.2 to 65). A second, poor-quality case-control study275 found that Factor V Leiden carriers compared with noncarriers had an odds ratio of 1.7 (CI, 0.6 to 4.8), while carriers plus OC users had an odds ratio of 6.4 (CI, 2.8 to 14.3). Another fair-quality case-control study280 showed a similar finding for a population of OC users with and without sickle cell trait. Compared with a reference group of nonusers without sickle cell trait, OC users without sickle cell trait had an odds ratio for VTE of 2.6 (CI, 1.1 to 6.2) and nonusers with sickle cell trait had an odds ratio of 1.8 (CI, 0.51 to 6.3). However, sickle cell trait patients who also used OCs had an odds ratio of 12.1 (CI, 2.8 to 52) for VTE. The sample size was too small to allow correction for potential confounding variables. Two cohorts of women whose family members had been diagnosed with VTE292,295 had a two-fold increased risk of VTE during current OC use and risk regardless of presence of known thrombophilias.

### OC Use and Venous Thromboembolism Mortality

No studies evaluated the association between OC use and mortality from VTE events.

### Strength of Evidence for OC Use and Risk of Venous Thromboembolism

We found strong evidence that current OC use conferred a three-fold increased risk of VTE and PE when compared with the risk among noncurrent users (Table 49). The risk of VTE did not change among users of pills containing varying estrogen doses or progestin generations.

Table 49 Strength of evidence domains for the effect of OC use on venous thromboembolic events

Comparison | Number of Studies (Women and/or Person-Years) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Comparison | Number of Studies (Women and/or Person-Years) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Incidence of All VTE and Mixed DVT/PE
Current vs. noncurrent use/never | 14 (15,466 plus 9,906,890 person-years) | Medium | Consistent | Direct | Precise | High 2.97 (2.46 to 3.59)
Incidence of PE Only
Current vs. noncurrent use/never | 3 (863 plus 2,124,474 person-years) | Medium | Consistent | Direct | Precise | Low Elevated risk appears similar to that of VTE
Incidence of All VTE and Mixed DVT/PE
Duration of use | 5 (6955 plus 7,782,416 person-years) | Medium | Consistent | Direct | Precise | Low Elevated risk may be present during first year of use
Estrogen | 3 (6102 plus 7,782,416 person-years) | Medium | Consistent | Direct | Precise | High Low dose: 3.39 (2.32 to 4.96) High dose: 3.06 (1.32 to 7.10)
Progestin | 6 (16,048) | Medium | Consistent | Direct | Precise | High First generation: 4.06 (2.66 to 6.19) Second generation: 3.28 (2.49 to 4.31) Third generation: 4.06 (3.09 to 5.32) Fourth generation: 5.36 (2.78 to 10.32)
Mortality From VTE
Current vs. noncurrent use/never | 0 | NA | NA | NA | NA | Insufficient NA

CI = confidence interval; DVT = deep venous thrombosis; PE = pulmonary embolism; SOE = strength of evidence; VTE = venous thromboembolism

### OC Use and Stroke Incidence

We identified 15 studies that evaluated the association between OC use and the incidence of stroke, including ischemic, hemorrhagic, and undifferentiated stroke.261,265,267,272,288,304-307,314-333 Of these, 10 were case-control studies, 4 were cohort studies, and 1 was a pooled analysis; 5 studies were rated good quality, 9 fair quality, and 3 poor quality (Table 50). The pooled analysis332 includes data from the individual studies by Petitti et al.315 and Schwartz et al.333 Nine studies assembled cohorts that were either fully or partially based in Europe or the United Kingdom; three studies occurred in the United States. All 10 case-control studies recruited or identified patients from hospitals or hospital databases.

Table 50 Study characteristics and association between OC use and stroke incidence

Study^a^ | Study Details | OR | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^b^
Case-Control
Tzourio,1995^314^ | Patients <45 yr in 5 hospitals in Paris [underlined: Cases]: 72 ischemic stroke, hospital [underlined: Controls]: 173 no stroke, hospital Recruitment period: 1990–1993 Type of stroke: Ischemic | NA | NA | NA | France | Fair | 3
Petitti,1996^315^ | Members of California Kaiser Permanente Medical Care Program aged 15–44 yr Ischemic stroke [underlined: Cases]: 144 ischemic stroke, hospital and administrative records [underlined: Controls]: 744, hospital and administrative records | 1.18 | 0.54 to 2.59 | Race, BMI, smoking, treated diabetes and hypertension | U.S. | Fair | 1
Petitti,1996^315^ | Hemorrhagic stroke [underlined: Cases]: 151 hemorrhagic stroke, hospital and administrative records [underlined: Controls]: 744 hospital and administrative records | 1.14 | 0.60 to 1.16 | Race, BMI, smoking, treated diabetes and hypertension | U.S. | Fair | 2
Petitti,1996^315^ | Recruitment period: 1991–1994 | | | Race, BMI, smoking, treated diabetes and hypertension | U.S. | Fair
Anonymous, 1996^317^ Anonymous, 1996^318^ Anonymous, 1998^267^ Chang, 1999^316^ | Women aged 20–44 yr in WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception | 4.20^316^ (ischemic stroke) | 1.74 to 10.12 | Smoking, history of hypertension | UK, Germany, Hungary, Yugoslavia, Slovenia | Good | 1
Anonymous, 1996^317^ Anonymous, 1996^318^ Anonymous, 1998^267^ Chang, 1999^316^ | [underlined: Cases]: Hospital* [underlined: Controls]: No stroke, hospital* *Different sample size across articles | 1.10^316^ (hemorrhagic stroke) | 0.63 to 1.93 | Smoking, history of hypertension | UK, Germany, Hungary, Yugoslavia, Slovenia | Good | 2
Anonymous, 1996^317^ Anonymous, 1996^318^ Anonymous, 1998^267^ Chang, 1999^316^ | Recruitment period: 1990–1994 | | | Smoking, history of hypertension | UK, Germany, Hungary, Yugoslavia, Slovenia | Good
Heinemann, 1997^326^ Heinemann, 1999^272^ Lewis, 1999^261^ | Women aged 16–44 yr in Transnational Study on Oral Contraceptives and the Health of Young Women [underlined: Cases]: Undifferentiated stroke, hospital* [underlined: Controls]: No MI, thromboembolic CVA, or VTE, hospital and community* *Different sample size across articles Recruitment period: 1993–1996 | 2.86^261^ | 2.02 to 4.04 | Hypertension, occupation, education level, hyperlipidemia, genetic polymorphisms of ACE gene | Austria, France, Germany, Switzerland, UK | Fair | 1
Schwartz, 1997^333^ | Members of California Kaiser Permanente Medical Care Program aged 15–44 yr Ischemic stroke [underlined: Cases]: 60 ischemic stroke, hospital and administrative records [underlined: Controls]: 485, community | 0.90 | 0.27 to 2.94 | Age, treated hypertension, smoking, race, alcohol use | U.S. | Good | 1
Schwartz, 1997^333^ | Hemorrhagic stroke [underlined: Cases]: 102 hemorrhagic stroke, hospital and administrative records [underlined: Controls]: 485 community | 0.93 | 0.37 to 2.31 | Age, treated hypertension, smoking, race, alcohol use | U.S. | Good | 2
Schwartz, 1997^333^ | Recruitment period: 1991–1994 | | | Age, treated hypertension, smoking, race, alcohol use | U.S. | Good
Barinagarrementeria, 1998^327^ | Women aged 11–44 yr in stroke clinic and neurology department of a hospital in Mexico City [underlined: Cases]: 130 undifferentiated stroke, hospital [underlined: Controls]: 122 no stroke, hospital Recruitment period: “Last 11 years” | 2.5 | 0.8 to 8.1 | Unadjusted | Mexico | Poor | 1
Kemmeren, 2002^320^ | Women aged 19–49 yr in Risk of Arterial Thrombosis in Relation to Oral Contraceptives Study [underlined: Cases]: 203 ischemic stroke, hospital [underlined: Controls]: 925, community Recruitment period: 1990–1995 | 2.1 | 1.5 to 3.1 | Age, area of residence, calendar yr | Netherlands | Good | 3
Siritho, 2003^322^ | Patients aged 15–55 yr in 4 city hospitals in Melbourne [underlined: Cases]: 234 ischemic stroke, hospital discharge records [underlined: Controls]: 234, community Recruitment period: 1984–1996 | 1.62 | 0.69 to 3.83 | Smoking, alcohol, exercise, cholesterol, MI, hypertension, TIA, diabetes | Australia | Fair | 1
Martinelli, 2006^323^ | Woman <45 yr referred to a thrombosis center [underlined: Cases]: 105, ischemic stroke, hospital [underlined: Controls]: 293, healthy, partner or friend of cases | NA | NA | NA | Italy | Poor | 4
Wang, 2012^325^ Li, 2010^324^ | 25 towns in Jiangsu Province Either ischemic or hemorrhagic stroke [underlined: Cases]: 449 either ischemic or hemorrhagic stroke, hospital [underlined: Controls]: 830 no stroke, hospital | 4.05 | 2.19 to 7.47 | Parity, BMI, smoking, hypertension, hyperlipidemia, alcohol use, diabetes, family history of stroke, duration of current OC use | China | Fair | 1
Cohort
Hannaford, 1998^288^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 335,181 person-years [underlined: Unexposed]: 28,727 person-years Mean age at study entry: 49 Recruitment period: 1968–NR | NA | NA | NA | UK | Poor | 3
Mant, 1998^265^ | Women aged 25–39 yr in Oxford Family Planning Association Study [underlined: Exposed]: 186,848 person-years [underlined: Unexposed]: 123,716 person-years Note: After age 45, only women who had never used OCs or those who had used it for ≥8 yr were followed until 1994. Recruitment period: 1968–1974 | 2.9 | 1.3 to 6.7 | Age, parity, BMI, smoking, social class | UK | Fair | 1
Yang, 2009^319^ | Women aged 30–49 yr in Women's Lifestyle and Health Cohort Study [underlined: Exposed]: 38,258 [underlined: Unexposed]: 7471 | 1.1 | 0.6 to 2.0 | Age, BMI, smoking, education, physical activity, alcohol use, high blood pressure, diabetes | Sweden | Fair | 1
Yang, 2009^319^ | Recruitment period: 1991–1992 | 0.4 | 0.1 to 2.1 | Age, BMI, smoking, education, physical activity, alcohol use, high blood pressure, diabetes | Sweden | Fair | 2
Lidegaard, 2012^329^ | Women aged 15–49 yr in Denmark Either ischemic or undifferentiated stroke [underlined: Exposed]: 4,651,766 person-years [underlined: Unexposed]: 9,336,662 person-years | NR | NR | Age, education, year, risk factors | Denmark | Fair | 5
Lidegaard, 2012^329^ | Ischemic stroke [underlined: Exposed]: 4,651,766 person-years [underlined: Unexposed]: 9,336,662 person-years | NR | NR | Age, education, year, risk factors | Denmark | Fair | 5
Lidegaard, 2012^329^ | Recruitment period: 1995–2009 | NR | | Age, education, year, risk factors | Denmark | Fair | 5
Pooled
Schwartz, 1998^332^ | Members of California Kaiser Permanente Medical Care Program and Washington State aged 18–44 yr Ischemic stroke [underlined: Cases]: 175 ischemic stroke, hospital and administrative records [underlined: Controls]: 485, hospital and administrative records and community Hemorrhagic stroke [underlined: Cases]: 198 hemorrhagic stroke, hospital and administrative records [underlined: Controls]: 485 hospital and administrative records and community Recruitment period: 1991–1994 | NR | NR | NA | U.S. | Good | 6

BMI = body mass index; CI = confidence interval; mo = month/months; NA = not applicable; NR = not reported; OC = oral contraceptive; OR = odds ratio; UK = United Kingdom; U.S. = United States; VTE = venous thromboembolism; WHO = World Health Organization; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Meta-analysis code: 1=Included in ischemic stroke meta-analysis; 2=Included in hemorrhagic stroke meta-analysis; 3=Excluded due to current versus noncurrent OC use odds ratio not reported; 4=Excluded due to population of high-risk patients recruited from a thrombosis center; 5=Excluded due to adjusted relative risks as calculated from person-years of exposure cannot be converted to odds ratios; 6=Excluded this pooled study due to having duplicate patients reported in single studies above.

#### Current Versus Noncurrent OC Use

Of the 15 studies that evaluated the association between OC use and the incidence of stroke, nine261,265,315,316,319,322,325,327,333 were included in a meta-analysis examining the effect of current versus noncurrent OC use on ischemic or undifferentiated stroke incidence. Of these, 7 were case-control studies representing 1490 cases and 3786 controls, and 2 were cohort studies representing 45,729 participants and 310,564 person-years. Two studies were rated good quality, six studies were rated fair quality, and one poor quality (Table 50). One study327 did not specify whether the patients included in the analysis had ischemic or hemorrhagic stroke; we assumed that the majority of strokes were ischemic, and therefore we included this study in the meta-analysis. Abstracted data not included in this meta-analysis is specified (with rationale) in Table 50. Reasons for exclusion from this analysis included the following: no reporting of an odds ratio for current versus noncurrent use of OCs; representing a special, high-risk population; and reporting results not as odds ratios, but as relative risks calculated from person-years of exposure.

We also conducted separate meta-analyses of the seven studies of known ischemic stroke261,265,315,316,319,322,333 representing 911 cases, 2834 controls, 38,258 exposed people, 7471 unexposed people, 186,848 person-years of exposure, and 123,716 unexposed person-years. We conducted a separate meta-analysis of the four studies that reported data separately for known hemorrhagic stroke representing 688 cases, 1965 controls, 38,258 exposed people, and 7471 unexposed people.315,316,319,333

##### Ischemic/Undifferentiated Stroke

We included all ischemic study results and also included any study of undifferentiated stroke if the ischemic stroke results were not available. Figure 34 shows that the random effects estimated odds ratio is 2.15 (95% CI, 1.49 to 3.11), demonstrating a significant increase in stroke risk for current OC use. There was significant heterogeneity, with a Q-value of 818.47 for 8 degrees of freedom, p=0.018.

Figure 34 Forest plot for ischemic/undifferentiated stroke

CI = confidence interval; OC = oral contraceptive

Description: Figure 34 shows that the random effects estimated odds ratio is 2.15 (95% CI, 1.49 to 3.11), demonstrating a significant increase in stroke risk for current OC use.

###### Sensitivity Analyses

We performed a sensitivity analysis by dropping the single poor-quality study.327 The results were essentially unchanged with an odds ratio of 2.12 (95% CI, 1.42 to 3.16). Only two of the studies in this meta-analysis315,333 were conducted in the United States; we did not, therefore, conduct a sensitivity analysis by excluding studies that did not include patients in the United States.

##### Ischemic Stroke

Figure 35 shows the odds ratios for the five case-control and two cohort studies of ischemic stroke incidence as a function of OC use. These studies represent a total of 1,100 cases, 2,975 controls, 38,258 exposed people, 7471 unexposed people, 186,848 person-years of exposure, and 123,716 unexposed person-years. The random-effects estimated odds ratio is 1.90 (95% CI, 1.24 to 2.91). There was significant heterogeneity, with a Q-value of 5.76 for 6 degrees of freedom, p=0.036.

Figure 35 Forest plot for ischemic stroke

CI = confidence interval; OC = oral contraceptive

Description: Figure 35 shows the odds ratios for the five case-control and two cohort studies of ischemic stroke incidence as a function of OC use. The random-effects estimated odds ratio is 1.90 (95% CI, 1.24 to 2.91).

##### Hemorrhagic Stroke

Figure 36 shows the odds ratios for the three case-control studies and one cohort study of hemorrhagic stroke incidence as a function of OC use. The random-effects estimated odds ratio is 1.03 (95% CI, 0.71 to 1.49), showing no evidence of increased hemorrhagic stroke risk among current OC users. There was no significant heterogeneity, with a Q-value of 1.48 for 3 degrees of freedom, p=0.489. Although current OC use is associated with a doubling of risk for ischemic/undifferentiated stroke, current OC use does not appear to be associated with an increased risk of hemorrhagic stroke.

Figure 36 Forest plot for hemorrhagic stroke

CI = confidence interval; OC = oral contraceptive

Description: Figure 36 shows the odds ratios for the three case-control studies of hemorrhagic stroke incidence as a function of OC use. The random-effects estimated odds ratio is 1.03 (95% CI, 0.71 to 1.49), showing no evidence of increased hemorrhagic stroke risk among current OC users.

##### Past OC Use and Stroke Incidence

The majority of studies evaluated the risk of stroke among current users compared with noncurrent users; however, three studies evaluated whether there was any risk associated with ever versus never use of OCs. One poor-quality cohort study288 found an elevated risk for cerebrovascular disease associated with ever OC use compared with never use (RR 1.37; 95% CI, 1.12 to 1.67). OC users in this study included current users. One Australian case-control study322 found a trend toward increased odds of ischemic stroke among current OC users but no evidence of increased odds among past users. A case-control study from China324,325 found a mildly increased risk of stroke among past users (OR 1.36; CI,1.04 to 1.77) but a much greater increased risk of stroke among current users (OR 4.05; CI,2.19 to 7.47). A fair-quality cohort study319 found no elevated risk of stroke among current OC users (RR 1.1; CI, 0.6 to 2.0) or past users (RR 0.9; CI, 0.6 to 1.4). In a second fair-quality cohort study,265 the significant increased risk of ischemic stroke among current users of OCs disappeared among past users (RR 0.7; CI, 0.2 to 2.2).

#### Duration of OC Use

There was an insufficient number of studies to conduct a meta-analysis examining the effect of duration of OC use on risk of stroke. A fair-quality European cohort study319 demonstrated no increased risk of stroke with ever OC use; this did not change when stratified by duration of use by less than 5 years, 5 to 10 years, or more than 10 years. A fair-quality U.K. cohort study265 found no significant difference in stroke risk for ever users who used OCs less than 5 years, 5 to 10 years, 10 to 15 years, 15 to 20 years, or greater than 20 years. A fair-quality Australian case-control study322 similarly found no significant increased stroke risk by duration of use (up to 8 years or more than 8 years). In a European case-control study,321 there were similar odds of cerebral thrombosis of any type among current users compared with never users when stratified by duration of use (<1 year, 1–5 years, and >5 years). In a fair-quality nested case-control study from China,325 ever users of OCs for 15 years or more had increased odds of hemorrhagic stroke (OR 3.7; CI, 1.9 to 7.3) but not ischemic stroke (OR 1.3; CI, 0.8 to 2.2) when compared with never users.

#### OC Formulation

##### Estrogen Dose

Two good-quality and one fair-quality case-control studies317,320,321 representing 1897 cases and 8080 controls were included in a meta-analysis to evaluate the relationship between high-dose and low-dose estrogen on the risk of ischemic or undifferentiated stroke. Additional data abstracted from a cohort study329 representing 13,988,428 person-years, and a case-control study involving women without migraines are summarized in Tzourio et al.314 (Table 51) were not included in the meta-analysis because the former reported relative risks that could not be readily converted to odds ratios, and the latter did not provide confidence intervals. None of these studies included women from the United States.

Table 51 Stroke incidence odds by estrogen dose compared with nonuse of OCs

Study^a^ | Comparison^b^ | OR | 95% CI | Comparison^b^ | OR | 95% CI | Notes
Study^a^
Study^a^ | Low-Dose vs. Nonuse | | | High-Dose vs. Nonuse
Tzourio, 1995^314^ | Low (20) | 1.7 | NA | High (50) | 4.8 | NA | Women without migraines; undifferentiated stroke
Tzourio, 1995^314^ | Low (30-40) | 2.7 | NA | High (50) | 4.8 | NA | Women without migraines; undifferentiated stroke
Anonymous, 1996^317^ | Low (<50) | 1.27 | 0.70 to 2.32 | High (≥50) | 1.42 | 0.67 to 2.97 | Undifferentiated stroke
Kemmeren, 2002^320^ | Low (<50) | 2.3 | 1.5 to 3.4 | High (50) | 3.1 | 1.2 to 7.9 | Undifferentiated stroke
Lidegaard, 2002^321^ | Low (20) | 1.7 | 1.0 to 3.1 | High (50) | 4.5 | 2.6 to 7.7 | Current vs. never use; undifferentiated stroke
Lidegaard, 2002^321^ | Low (30-40) | 1.6 | 1.3 to 2.0 | High (50) | 4.5 | 2.6 to 7.7 | Current vs. never use; undifferentiated stroke
Lidegaard, 2012^329^ | Norethindrone/EE 30-40 | 2.17 | 1.49 to 3.15 | | | | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Levonorgestrel/EE 30-40 | 1.65 | 1.39 to 1.95 | | | | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Norgestimate/EE 30-40 | 1.52 | 1.21 to 1.91 | | | | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Desogestrel/EE 30-40 | 2.20 | 1.79 to 2.69 | | | | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Gestodene/EE 30-40 | 1.80 | 1.58 to 2.04 | Norethindrone/EE 50 | 1.27 | 0.66 to 2.45 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Drospirenone/EE 30-40 | 1.64 | 1.24 to 2.18 | Levonorgestrel/EE 50 | 2.26 | 1.59 to 3.20 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Cyproterone/EE 30-40 | 1.40 | 0.97 to 2.03 | | | | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Desogestrel/EE 20 | 1.53 | 1.26 to 1.87 | | | | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Gestodene/EE 20 | 1.70 | 1.37 to 2.12 | | | | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Drospirenone/EE 20 | 0.88 | 0.22 to 3.53 | | | | Adjusted relative risk, based on person-years of exposure

CI = confidence interval; EE = ethinyl estradiol; OR = odds ratio

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b First-generation progestins=norethindrone and ethynodiol diacetate; second-generation=levonorgestrel and norgestrel; third-generation=gestodene, desogestrel, and norgestimate; fourth-generation=drospirenone, dienogest, and cytoproterone acetate.

Table 52 lists the odds ratios for the meta-analysis of the risk of ischemic/undifferentiated stroke by estrogen dose level. The results show a significant difference by dose. The estimated odds ratio comparing high dose with low dose is 2.37 (95% CI, 1.05 to 5.38, p-value for no difference=0.0437). There was no significant heterogeneity. The estimated value of σ is 0.0.

Table 52 Estimated odds ratios by estrogen dose compared with nonuse of OCs (stroke incidence)

Estrogen Dose | Odds Ratio (95% Confidence Interval)
Low | 1.73 (1.29 to 2.32)
High | 4.10 (1.91 to 8.80)

The findings from the large cohort study by Lidegaard, et al. provide additional evidence that estrogen dose may affect risk of stroke associated with OC use. This may be modified by the type of progestin the estrogen is combined with. Compared with nonusers of OCs, users of high-dose estrogen with norethindrone had a relative risk for stroke of 1.27 (95% CI, 0.66 to 2.45) compared with a relative risk of 2.17 (95% CI, 1.49 to 3.15) for low-dose estrogen and norethindrone. Interestingly, high-dose estrogen in combination with levonorgestrel was associated with a relative risk for stroke of 2.26 (95% CI, 1.59 to 3.20) compared with a relative risk of 1.65 (95% CI, 1.39 to 1.95) when low-dose estrogen was combined with levonorgestrel.

Two studies investigated the use of progestin-only OCs. A fair-quality U.K. case-control study272 found no significant increased risk of stroke among current OC users versus nonusers; however, the confidence intervals were very wide (RR, 1.60; 95% CI, 0.24 to 10.72). A good-quality, multinational case-control study267 found no increased risk of stroke among current versus noncurrent progestin-only OC users (OR, 1.07; 95% CI, 0.62 to 1.86).

##### Progestin Generation

There was an insufficient number of studies to do a meta-analysis regarding the risk of stroke according to OC use of varying progestin generation. In a fair-quality European case-control study,321 there was a significantly increased risk for cerebral thrombus among current users of first-generation progestins (OR, 1.8; 95% CI, 1.0 to 3.3) compared with the reference group of second-generation OC users. There was also a slightly decreased risk for third-generation progestin users (OR, 0.6; 95% CI, 0.4 to 0.9) compared with second-generation users. In another good-quality European case-control study,320 the increased odds of ischemic stroke among current users of contraceptives remained similar when stratified by first-, second- or third-generation OC users. A fair-quality U.K. case-control study326 also found no significant difference in stroke risk between first-, second-, and third-generation OC users. In a recently published, fair-quality cohort study in which 1,626,158 women contributed 14,251,063 person-years of observation, Lidegaard et al.329 reported relative risks of thrombotic stroke associated with several different OC formulations compared with nonusers. Relative risks were reported for OCs representing all four progestin generations. No clear pattern emerged regarding potentially different risks of stroke by progestin generation.

#### Special Populations

Several populations of women are known to be at increased risk for stroke, including women with migraines, thrombophilias, cardiovascular risk factors, and women of older age. We did not identify enough studies to conduct meta-analyses to determine if these risk factors modified the risk of stroke in OC users. Several studies, however, did provide preliminary information about stroke risk in these populations.

##### Migraines

Two studies evaluated the risk of stroke among women with migraines who also used OCs. A fair-quality European case-control study314 found the odds of stroke for OC users with migraines to be 13.9 times that of nonusers without migraines. However, this odds ratio statistically was not significantly different from the four-fold increase in odds reported for both women with migraines only and women who used OCs only. A fair-quality European case-control study316 found the use of OCs had greater than multiplicative effects on the odds ratios for ischemic stroke among users with migraines (17-fold odds compared with 3-fold for OC users without migraine and 2-fold for women not using OCs who had migraines). This difference was not statistically significant.

##### Blood-Clotting Disorders

One poor-quality European case-control study323 found a two-fold increase in odds of stroke in women with a Factor V Leiden mutation; this risk was significantly increased to 13-fold among current OC users with Factor V Leiden. A similar finding was obtained for women with hyperhomocysteinemia (two-fold odds increased to six-fold odds). It is unclear whether these differences were statistically significant. There was no increased risk among women with prothrombin gene mutation whether or not they were users of OCs. One study324,325 found that women with specific genetic polymorphisms such as ACE I/D, rs10958409GA/AA and rs1333040CT/TT had a greater than multiplicative odds of stroke.

##### Age

One good-quality European case-control study320 found the risk of first ischemic stroke among OC users that increased by age. The odds of stroke was 1.3 (95% CI, 0.5 to 3.3) for women 18 to 29 years of age; 2.3 (CI, 1.2 to 4.3) for women 30 to 39 years; and 2.6 (CI, 1.6 to 4.2) for women 40 to 49 years. There was no statistical test of the difference reported.

### OC Use and Stroke Mortality

We identified two fair-quality studies and one poor-quality study that evaluated the association between ever versus never OC use and stroke mortality33,164-166,334 (Table 53).

Table 53 Study characteristics and association between OC use and stroke mortality

Study | Study Details | OR | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^a^
Case-Control
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at study entry: 29 (SD 6.6) Recruitment period: 1968–NR | NR | NR | NA | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-years (total for exposed and unexposed) Recruitment period: 1968–1974 | NR | NR | NA | UK | Fair | 1
Gallagher, 2011^334^ | Female workers in 526 textile factories in Shanghai [underlined: Exposed:] 366,890 person-years [underlined: Unexposed:] 2,122,083 person-years Recruitment period: 1989–2000 | 0.65 | 0.46 to 0.91 | Age | China | Poor | 1

CI = confidence interval; NA = not applicable; NR = not reported; OR = odds ratio; SD = standard deviation; UK = United Kingdom; yr = year/years

a Meta-analysis code: 1 = Included in meta-analysis.

The results of a meta-analysis of these three studies of stroke mortality as a function of OC use are shown in Figure 37. The random-effects estimated odds ratio is 0.80 (95% CI, 0.59 to 1.08). There was no evidence of heterogeneity, with a Q-value of 2.91 for 2 degrees of freedom, p=0.234.

Figure 37 Effect of OC use on stroke mortality

CI = confidence interval; OC = oral contraceptive

Description: Figure 37 shows the results of a meta-analysis of three studies of stroke mortality as a function of OC use. The random-effects estimated odds ratio is 0.80 (95% CI, 0.59 to 1.08).

Vessey et al.165 reported the risk of ischemic stroke mortality in ever users by duration of OC use and by time since last use. The risk ratios of mortality from hemorrhagic stroke compared with never OC use were 0.7 (95% CI, 0.4 to 1.3) for less than 4 years of total use; 1.4 (CI, 0.6 to 3.1) for 4 to 8 years of use; and 0.5 (CI, 0.2 to 1.2) for more than 8 years of use. In a second cohort study, calculating the risk of stroke mortality for ever users of OCs, the risk ratio was 1.1 (CI, 0.0 to 6.6) for those who had used within the last 4 years or at the time of death; 0.6 (CI, 0.0 to 3.6) for those who last used between 4 to 12 years prior to death; 0.7 (CI, 0.1 to 2.2) for those who last used 12 to 20 years prior to death; and 0.9 (CI, 0.4 to 1.8) for those who last used more than 20 years prior to death. Similar findings were noted for hemorrhagic stroke.334

### Strength of Evidence for OC Use and Risk of Stroke

Table 54 shows the strength of evidence for the effects of OC use on the risk of stroke.

Table 54 Strength of evidence domains for the effect of OC use on stroke

Comparison | Number of Studies (Women and/or Person-Years) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Comparison | Number of Studies (Women and/or Person-Years) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Incidence of Ischemic/Undifferentiated Stroke
Current vs. noncurrent use/never | 9 (54,767 plus 310,564 person-years) | Medium | Consistent | Direct | Precise | High 2.15 (1.49 to 3.11)
Duration | 4 (51,038 plus 310,626 person-years) | Medium | Consistent | Direct | Imprecise | Insufficient NR (Insufficient evidence to support quantitative synthesis of findings)
Estrogen | 3 (9977) | Medium | Consistent | Direct | Precise | High Low dose: 1.73 (1.29 to 2.32) High dose: 4.10 (1.91 to 8.80)
Progestin | 3 (6994) | Medium | Inconsistent | Direct | Imprecise | Insufficient NR (heterogeneity in evidence about specific progestin generation)
Incidence of Ischemic Stroke
Current vs. noncurrent use/never | 7 (49,803 plus 310,564 person-years) | Medium | Consistent | Direct | Precise | High 1.90 (1.24 to 2.91)
Incidence of Hemorrhagic Stroke
Current vs. noncurrent use/never | 4 (48,382) | Medium | Inconsistent | Direct | Imprecise | Low No difference, 1.03 (0.71 to 1.49)
Mortality From Stroke
Current vs. noncurrent use/never | 3 (46,112 plus 3,091,673 person-years) | Medium | Consistent | Direct | Imprecise | Moderate 0.80 (0.59 to 1.08)

CI = confidence interval; SOE = strength of evidence

### OC Use and Myocardial Infarction Incidence

We identified 11 studies that evaluated the association between OC use and the incidence of myocardial infarction.261,265,267,270,272,288,304-307,309,313,321,329,331,335-342 Of these, 7 were case-control studies, 4 cohort studies, and 1 pooled analysis of two case-control studies that include data presented in one of the individually included case-control reports. Note that evidence from Lidegaard et al. was abstracted from several publications and included both case-control270 and cohort329 study designs. Six studies were rated good quality, 4 fair quality, and 1 poor quality (Table 55). Eight studies (73%) were conducted either fully or partially in Europe or the United Kingdom. Three studies (27%) were conducted in the United States. In the seven case-control studies, cases were recruited from hospitals or identified by hospital databases. Of these, two studies recruited controls from hospitals, two studies from either hospitals or other settings, and two studies from outpatient-only or community settings. The recruitment source for controls was not clearly indicated in one study.

Table 55 Study characteristics and association between OC use and myocardial infarction incidence

Study^a^ | Study Details | OR | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^b^
Case-Control
Anonymous, 1997^337^ Anonymous, 1998^267^ | Women aged 20–44 yr in WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception [underlined: Cases]: 267 acute MI, hospital [underlined: Controls]: 822 patients hospitalized for reasons other than MI Recruitment period: 1989–1995 | 5.64 | 2.49 to 12.80 | History of hypertension, diabetes, BMI, abnormal blood lipids, smoking status | Africa, Asia, Europe, Latin America | Good | 1
Lidegaard, 1998^270^ | Patients aged 15–44 yr from all Danish hospitals [underlined: Cases]: 94 acute MI, hospital [underlined: Controls]: 1041, source NR Recruitment period: 1994–1995 | NR | NR | NA | Denmark | Fair | 2
Dunn, 1999^339^ Dunn, 1999^338^ | Women aged 16–44 yr in MICA study [underlined: Cases]: 448 incident MI, hospital [underlined: Controls]: 1728 no MI, outpatient Recruitment period:1993–1995 | 0.79 | 0.54 to 1.16 | Crude | Denmark | Good | 1
Lewis, 1999^261^ Heinemann, 1999^272^ | Transnational Study on Oral Contraceptives and the Health of Young Women aged 16–44 yr [underlined: Cases]: 182 MI, hospital [underlined: Controls]: 635 no MI or thromboembolic CVA, hospital and community Recruitment period: 1993–1996 | 0.94 | 0.31 to 2.91 | Smoking, hypertension, diabetes, education | Austria, France, Germany, Switzerland, UK | Fair | 1
Rosenberg, 2001^340^ | Hospitalized patients <45 yr [underlined: Cases]: 627 MI, hospital [underlined: Controls]: 2947 no MI, hospital Recruitment period: 1985–1999 | 1.3 | 0.8 to 2.2 | Age, menopausal status, family history, smoking, region, interview yr, type of interview, hypertension, diabetes mellitus, history of elevated serum cholesterol | U.S. | Good | 1
Tanis, 2001^341^ | Women aged 18–49 in Risk of Arterial Thrombosis in Relation to Oral Contraception study [underlined: Cases]: 248 MI, hospital databases [underlined: Controls]: 925 no history of coronary, cerebral, or peripheral artery disease, community Recruitment period: 1990–1995 | 2.0 | 1.5 to 2.8 | Age, area of residence and calendar yr | Netherlands | Good | 1
Cohort
Hannaford, 1998^288^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 335,181 person-years [underlined: Unexposed]: 228,727 person-years Mean age at study entry: 49 Recruitment period: 1968–NR | NR | NR | NA | UK | Poor | 2
Mant, 1998^265^ | Women aged 25–39 in Oxford Family Planning Association Study [underlined: Exposed]: 186,910 person-years [underlined: Unexposed]: 123,716 person-years Recruitment period: 1968–1974 | 1.5 | 0.6 to 3.2 | Age, parity, BMI, smoking, social class | UK | Fair | 1
Margolis, 2007^342^ | Women aged 30–49 yr in Women's Lifestyle and Health Study [underlined: Exposed]: 6801 [underlined: Unexposed]: 8013 Recruitment period: 1990–1991 | 0.7 | 0.4 to 1.4 | Age, BMI, smoking, education, alcohol intake, physical activity, history of hypertension, history of diabetes, menopausal status | Norway, Sweden | Fair | 1
Lidegaard, 2012^329^ | Women aged 15–49 yr in Denmark Exposed: 4,651,766 person-years Unexposed: 9,336,662 person-years Recruitment period: 1995–2009 | NR | NR | Age, education, year, risk factors | Denmark | Fair | 3
Pooled
Sidney, 1998^336^ Sidney, 1996^335^ | Women aged 15–44 yr in pooled data from Kaiser Permanente Medical Care Program and University of Washington [underlined: Cases]: 166 MI, Kaiser Permanente members and 101 MI, University of Washington patients [underlined: Controls]: 479 no MI, Kaiser Permanente members and 512 no MI, community Recruitment period: 1991–1995 | 0.94 | 0.40 to 2.20 | Age, race, BMI, smoking, education, menopause, whether treated for hypertension or diabetes | U.S. | Good | 1

BMI = body mass index; CI = confidence interval; NA = not applicable; NR = not reported; OC = oral contraceptive; OR = odds ratio; UK = United Kingdom; U.S. = United States; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Meta-analysis code: 1 = Included in this meta-analysis of current versus noncurrent OC use; 2 = Excluded due to current versus noncurrent OR not reported; 3 = Adjusted relative risks as calculated from person-years of exposure cannot be converted to odds ratios.

#### Current Versus Noncurrent OC Use

Eight studies265,272,336,337,339-342 were included in this meta-analysis examining the effect of current versus noncurrent OC use on MI incidence. Of these, five were case-control studies representing 1772 cases and 7057 controls, two were cohort studies representing 310,626 person-years and 14,814 people, and one was a pooled analysis representing 267 cases and 991 controls.

The pooled analysis336 was included in the meta-analysis rather than its individual case-control report.335 The pooled analysis included previously unpublished data on 104 additional patients from a second site using identical methods and analysis as the case-control report, and therefore the pooled patient-level analysis provided the greatest evidence concerning current versus noncurrent OC use and myocardial infarction.

Five studies were rated good quality and three fair quality. Two studies336,340 included patients from the United States; the remaining studies were either fully or partially based in Europe or the United Kingdom. Abstracted data not included in this meta-analysis are specified (with rationale) in Table 55. Reasons include not reporting a current versus noncurrent odds ratio and not providing data in a format that can be converted to an odds ratio.

Figure 38 shows the results of the meta-analysis. The odds ratio of MI among current versus noncurrent OC users was 1.34 (95% CI, 0.87 to 2.08) demonstrating a small increase in MI incidence among current OC users that did not reach statistical significance. There was significant heterogeneity, with a Q-value of 34.47 for 7 degrees of freedom, p<0.001. Most of the heterogeneity was from the WHO Collaborative study.267,337 This study was unique in that it included participants from Africa, Asia, and Latin American in addition to Europe and the United Kingdom. No sensitivity analyses were performed because all included studies were fair or good quality, and only two studies336,340 included participants from the United States.

Figure 38 Forest plot for current versus noncurrent OC use (myocardial infarction incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 38 shows the results of the meta-analysis. The odds ratio of MI among current OC users was 1.34 (95% CI, 0.87 to 2.08) demonstrating a small increase in MI incidence among OC users that did not reach statistical significance.

#### Duration of OC Use

There were too few studies to perform a meta-analysis of the risk of MI by duration of current OC use. A large, fair-quality European cohort study342 found no change in the relative risk of MI according to increasing duration of OC use for less than 5 years, 5 to 9 years, 10 to 14 years, or 15 years or more. In fair-quality cohort study from the United Kingdom,265 ever users of OCs for up to 8 years had 1.9 times the risk of MI (95% CI, 1.0 to 3.5) compared with never users, while ever users for more than 8 years had no change in risk compared with never users (RR 1.0; CI, 0.6 to 1.8). However, in a later analysis of the same cohort,165 there was no difference in ischemic heart disease mortality by the duration of ever use of OCs. This study is discussed in more detail in the section on OC use and MI mortality.

#### OC Formulation

##### Estrogen Dose

We investigated whether the dose of estrogen in OCs is related to risk of MI (high dose was ≥50 mcg of ethinyl estradiol and low dose was <50 mcg of ethinyl estradiol). One fair-quality cohort study342 evaluated the risk of MI associated with low-dose versus high-dose estrogen and reported no difference in risk between these two groups (relative risks were not reported). A good-quality case-control study267,337 evaluated the risk of MI associated with high-dose estrogen use in several European countries. They found a risk ratio of 7.69 (95% CI, 3.29 to 18.0) among users of high-dose estrogen OCs compared with nonusers and a risk ratio of 2.93 (CI, 1.23 to 6.97) for users of low-dose estrogen OCs. This study was unique in that it included populations from Africa, Asia, and Latin America.

Users of OCs containing no estrogen (i.e., progestin-only OCs) were found to have an odds ratio of 0.94 (95% CI, 0.31 to 2.91) for MI in one multinational case-control study.272 In a second multinational case-control study,267 progestin-only OC users were found to have an odds ratio of 0.98 (CI, 0.16 to 5.97).

##### Progestin Generation

Five case-control studies261,270,338,340,341 were included in a meta-analysis examining the effect of current versus noncurrent OC use on MI incidence by progestin generation (Table 56). Three were rated good quality and two fair quality. Only one study340 included patients from the United States. These five studies represented 1599 cases and 7276 controls. A good-quality, large cohort trial329 reported adjusted relative risks of MI associated with progestin formulations across all four generations, but this study was not included in the meta-analysis because the relative risks could not be converted to odds ratios.

Table 56 Data for outcomes on progestin generation (myocardial infarction incidence)

Study^a^ | Formulation^b^ (Vs. Noncurrent OC Use) | OR | 95% CI | Notes
First Generation
Lidegaard, 1998^270^ | First generation | 4.8 | 2.1 to 11
Dunn, 1999^338^ | Noresthisterone | 1.83 | 0.15 to 22.7
Lewis, 1999^261^ | First generation | 4.66 | 1.52 to 14.33
Tanis, 2001^341^ | First generation | 2.7 | 1.0 to 7.3
Rosenberg, 2001^340^ | Progestogen containing <50 mcg of norethindrone | 2.5 | 1.1 to 5.5 | Current vs. never use
Lidegaard, 2012^329^ | Norethindrone/EE 50 mcg | 2.74 | 1.51 to 4.97 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Norethindrone/EE 30-40 mcg | 2.28 | 1.34 to 3.87 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Norethindrone (no estrogen) | 0.81 | 0.42 to 1.56 | Adjusted relative risk, based on person-years of exposure
Second Generation
Lidegaard, 1998^270^ | Second generation | 1.8 | 0.8 to 4.3
Dunn, 1999^338^ | Levonorgestrel | 0.93 | 0.45 to 1.95
Lewis, 1999^261^ | Second generation | 2.99 | 1.51 to 5.91
Tanis, 2001^341^ | Second generation | 2.5 | 1.5 to 4.1
Rosenberg, 2001^340^ | Progestogen containing <50 mcg levonorgestrel | 1.6 | 0.5 to 5.2 | Current vs. never use
Lidegaard, 2012^329^ | Levonorgestrel/EE 50 mcg | 4.31 | 3.09 to 6.00 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Levonorgestrel/EE 30-40 mcg | 2.02 | 1.63 to 2.50 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Levonorgestrel (no estrogen) | 0 | 0.00 to 35.01
Third Generation
Lidegaard, 1998^270^ | Third generation | 1.1 | 0.5 to 2.5
Dunn, 1999^338^ | Third generation | 1.66 | 0.75 to 3.67
Dunn, 1999^338^ | Desogestrel | 1.20 | 0.40 to 3.57
Dunn, 1999^338^ | Gestodene | 2.41 | 0.80 to 7.30
Lewis, 1999^261^ | Third generation | 0.85 | 0.30 to 2.39
Tanis, 2001^341^ | Third generation | 1.3 | 0.7 to 2.5
Lidegaard, 2012^329^ | Norgestimate/EE 30-40 mcg | 1.33 | 0.91 to 1.94 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Desogestrel/EE 30-40 mcg | 2.09 | 1.54 to 2.84 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Gestodene/EE 30-40 mcg | 1.94 | 1.62 to 2.33 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Desogestrel/EE 20 mcg | 1.55 | 1.13 to 2.13 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Gestodene/EE 20 mcg | 1.20 | 0.77 to 1.85 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Desogestrel (no estrogen) | 1.46 | 0.55 to 3.90 | Adjusted relative risk, based on person-years of exposure
Fourth Generation
Lidegaard, 2012^329^ | Drospirenone/EE 30-40 mcg | 1.65 | 1.03 to 2.63 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Cyproterone/EE 30-40 mcg | 1.47 | 0.83 to 2.61 | Adjusted relative risk, based on person-years of exposure
Lidegaard, 2012^329^ | Drospirenone/EE 20 mcg | 0 | 0.00 to 12.99 | Adjusted relative risk, based on person-years of exposure

CI = confidence interval; EE = ethinyl estradiol; OC = oral contraceptive; OR = odds ratio

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b First-generation progestins = norethindrone and ethynodiol diacetate; second-generation = levonorgestrel and norgestrel; third-generation = gestodene, desogestrel, and norgestimate; fourth-generation = drospirenone, dienogest, and cytoproterone acetate.

Table 57 lists the results for the meta-analysis of MI odds by progestin generation. MI risk appears to be highest among first generation progestin users. The formal test for difference gives a chi-square value of 8.78 for 2 degrees of freedom, p=0.0125. There is no significant heterogeneity. The estimated value of σ is 0.0.

Table 57 OC progestin generation and myocardial infarction risk in current OC users compared with nonusers

Generation | Odds Ratio (95% Confidence Interval)
First | 3.37 (2.04 to 5.54)
Second | 1.79 (1.16 to 2.75)
Third | 1.34 (0.91 to 1.98)

Most of the risk ratios reported by Lidegaard et al.329 across all four generations of progestins seemed to show no increased risk of MI by progestin generation, pointing instead to a possible increased risk of MI with increasing estrogen dose.

#### Special Populations

##### Cardiovascular Risk Factors

###### Age, Diabetes, Hypertension, Dyslipidemia

There was insufficient information to perform a meta-analysis evaluating the risk of MI among users of OCs with cardiovascular risk factors, but several studies did provide information regarding this question. In a large, fair-quality European cohort study,342 the risk ratio of MI was not elevated among former or current users of OCs, and there was no effect modification by age, hypertension, or diabetes status. The only group with a significant elevated risk of MI were women who had ever been advised by a physician to stop OCs (RR, 1.4; 95% CI, 1.0 to 2.1). A good-quality European case-control study341 found an elevated risk of MI among ever users of OCs in all age categories. There was no reported statistical difference according to age. The risks of MI were highest among OC users who were smokers or who had hypertension, hypercholesterolemia, diabetes, or obesity. In some cases, the risks appeared to be multiplicative.

###### Smoking

In a fair-quality U.K. cohort,265 the risk of MI was not elevated in OC users who were nonsmokers, OC nonusers who were smokers, or OC users who smoked less than 15 cigarettes per day. However, compared with never users, the risk of MI increased four-fold among smokers of 15 or more cigarettes per day whether they were former users (RR, 4.0; 95% CI, 1.3 to 16.2) or current users (RR, 4.9; CI, 1.2 to 23.6). A good-quality U.S. case-control study340 had similar findings; the odds of MI associated with current OC use were not elevated in those who smoked 1 to 25 cigarettes a day. However, the odds were elevated for nonusers who smoked more than 25 cigarettes a day (OR 12; CI, 9 to 16) and significantly more elevated for current users of OCs who smoked more than 25 cigarettes a day (OR 32; CI, 12 to 81; p=0.05). A third fair-quality U.K. case-control study339 found no interaction between smoking and use of OCs on the risk of MI; in this study, the definition of “nonusers” is not clear.

###### Blood-clotting Disorders

A good-quality European case-control study341 evaluated the relationship between inherited clotting disorders and the risk of MI. With a reference group of nonusers with no Factor V Leiden or prothrombin G201210A mutation, the estimated odds ratios were 1.4 (95% CI, 0.7 to 2.7) for nonusers with a mutation; 2.1 (CI, 1.5 to 3.0) for OC users without a mutation; and 1.9 (CI, 0.6 to 5.5) for OC users with a mutation. These findings suggest that there is no interaction between Factor V Leiden or prothrombin G20210A carrier status and OC use upon the odds of MI.

### OC Use and Myocardial Infarction Mortality

We identified three cohort studies33,164-166,334 evaluating the risk of MI mortality in OC ever users versus never users that could be combined into a meta-analysis (Table 58). These studies represent 46,112 participants in one study and 3,091,673 person-years in the other two. Two of the studies were based in the United Kingdom and one in China. The U.K. studies recruited women in the 1960s and 1970s33,165 and were fair quality. The study in China was poor quality.

Table 58 Study characteristics and association between OC use and myocardial infarction mortality

Study | Study Details | OR | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^a^
Case-control (continued)
Dunn, 2001 #1726^343^ | Women aged 16-44 from the Myocardial Infarction Causality study [underlined: Cases:] 148 who died within 28 days of an MI [underlined: Controls:] 24 who died more than 28 days after an MI and 413 MI survivors Recruitment period: 1993—1995 | NR | NR | NA | UK | Poor | 2
Cohort
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at study entry: 29 (SD 6.6) Recruitment period: 1968–NR | NR | NR | NA | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-years (total for exposed and unexposed) Recruitment period: 1968–1974 | NR | NR | NA | UK | Fair | 1
Gallagher, 2011^334^ | Female workers in 526 textile factories in Shanghai [underlined: Exposed:] 366,890 person-years [underlined: Unexposed:] 2,122,083 person-years Recruitment period: 1989–1991 | 0.79 | 0.56 to 1.12 | Age | China | Poor | 1

CI = confidence interval; NA = not applicable; NR = not reported; OR = odds ratio; SD = standard deviation; UK = United Kingdom; yr = year/years

a Meta-analysis code: 1 = Included in meta-analysis; 2 = Excluded due to difference in reference group and definition of OC use.

A fourth study343 reported on the relationship between OC use and MI mortality. We did not include this secondary analysis of a case-control study338 conducted in the United Kingdom in the meta-analysis because the reference group and the definition of OC use differed from the other three studies. This poor-quality study compared 148 women who died within 28 days of an MI to 24 women who died more than 28 days after an MI plus 413 MI survivors. The authors reported adjusted ORs of 0.83 (95% CI, 0.25 to 2.81), 2.88 (CI, 1.22 to 6.77), and 0.89 (CI, 0.27 to 2.92) for third-generation OC use, second-generation OC use, and other OC use, respectively, compared with no OC use, with OC use in all cases being defined as OC use the 3 months prior to the MI.

The results of a meta-analysis of these three studies of MI mortality as a function of oral contraceptive use are shown in Figure 39 The random-effects estimated odds ratio is 0.85 (95% CI, 0.67 to 1.07). There was some evidence of heterogeneity, with a Q-value of 4.48 for 2 degrees of freedom, p=0.107. Of note, the risk of MI mortality trended higher among current users (as opposed to ever users) in the Chinese cohort (OR 2.38), but the finding was not statistically significant (CI, 0.58 to 9.76).

Figure 39 Effect of OC use on myocardial infarction mortality

CI = confidence interval; OC = oral contraceptive

Description: Figure 39 shows the results of a meta-analysis of three studies of MI mortality as a function of oral contraceptive use. The random-effects estimated odds ratio is 0.85 (95% CI, 0.67 to 1.07).

### Strength of Evidence for OC Use and Risk of Myocardial Infarction

Table 59 shows the strength of evidence for the effect of OC use on the risk of myocardial infarction.

Table 59 Strength of evidence domains for the effect of OC use on myocardial infarction

Comparison | Number of Studies (Women and/or Person-Years) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Comparison | Number of Studies (Women and/or Person-Years) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Incidence of Myocardial Infarction
Current vs. noncurrent use/never | 8 (24,901 plus 310,626 person-years) | Medium | Inconsistent | Direct | Imprecise | Low 1.34 (0.87 to 2.08)
Estrogen | 2 (15,903) | Medium | Consistent | Direct | Imprecise | Insufficient NR
Progestin | 5 (8875) | Medium | Consistent | Direct | Precise | High First generation: 3.37 (2.04 to 5.54) Second generation: 1.79 (1.16 to 2.75) Third generation: 1.34 (0.91 to 1.98)
Mortality From Myocardial Infarction
Current vs. noncurrent use/never | 3 (46,112 plus 3,091,673 person-years) | Medium | Inconsistent | Direct | Imprecise | Low 0.85 (0.67 to 1.07)

CI = confidence interval; SOE = strength of evidence

## Discussion

We found strong evidence of a three-fold increased risk of VTE among current users of OCs and a two-fold increased risk of ischemic and undifferentiated stroke among current users of OCs. We found no conclusive evidence of an increased risk of MI or hemorrhagic stroke. The implications of OC use for each of these outcomes are discussed in detail below.

### OC Use and Venous Thromboembolism

We found a three-fold increase in the odds of VTE diagnosis among current users of OCs (95% CI, 2.46 to 3.59). There was significant heterogeneity among the study characteristics and among the risk estimates noted by the Q scores. However, the finding was robust in our sensitivity analysis and was almost identical to the findings in a recent meta-analysis.43 The odds ratio for VTE among current versus noncurrent OC users in that analysis was 3.41 (95% CI, 2.98 to 3.92). They analyzed 55 manuscripts, of which 32 were included in their meta-analysis of current versus noncurrent OC use and VTE risk. These manuscripts overlapped with 9 studies in our meta-analysis of 14 studies. The authors included all studies indexed in MEDLINE, Embase, and HealthSTAR regardless of date of publication. The odds of developing PE specifically appeared to be similar to that of developing VTE. The increased risk of DVT associated with OC use appears to be due to current use and not ever use. The only study to report a significantly increased risk among ever users also included current users in that group. The three studies that separately analyzed former and current use of OCs found increased odds of VTE for current users but not for former users.

#### Duration and Formulation

There was some evidence that the risk of VTE among current users was higher in the first few years of use. Manzoli et al.43 found a pooled odds ratio of 5.28 (95% CI, 4.27 to 6.55) for those who had used OCs for less than 1 year, and a pooled odds ratio of 3.52 (CI, 2.83 to 4.37) for those who had used OCs for more than 1 year. One potential explanation for this finding is that some women who develop VTE while on OCs may have an undiscovered predisposition to blood clots. Therefore, they develop VTE quickly after initiation of OC use, while women who are on OCs for years without forming a VTE presumably are less likely to have a predisposition to blood clotting. On the other hand, many factors that predispose women to blood clots will vary over time (e.g., trauma, sedentary lifestyle, and antiphosopholipid antibodies) and these risk factors have not been studied in a longitudinal fashion.

We found inconclusive evidence that estrogen dose or progestin generation was associated with VTE risk among current users of OCs. However, Manzoli et al.43 found a mildly increased risk of VTE among current users of high-dose versus low-dose estrogen (OR 1.42; 95% CI, 1.15 to 1.76). They also found an increased risk for third-generation versus second-generation progestin users (OR 1.57; CI, 1.24 to 1.98). However, as was similar with our findings, they did not find an increased risk of VTE among drospirenone users compared with other OC users. This question has generated recent media attention since several studies indicated an increased risk of DVT among users of OCs containing fourth-generation progesterones.

#### Special Populations

There may be a multiplicative relationship in the risk of VTE among users of OCs who had concomitant Factor V Leiden, sickle cell trait, or elevated homocysteine levels; however ,these findings would need to be confirmed in additional studies.

#### Clinical Application

The three-fold increased odds of VTE among current users of OCs is important given the life-threatening nature of VTE. The mortality rate of DVT in the general population is 5 percent within the first month after diagnosis; for PE, it is 12 percent within the first month after diagnosis.344 However, these estimates come from cohorts that include males, older individuals, and patients with cancers or heart disease. Young, healthy women who take OCs likely have lower mortality rates, but there is a paucity of data addressing this question. In one cohort of patients from the United States with DVT or PE, the univariate hazard ratio of death within the first week after VTE diagnosis among OC users was 0.08 (95% CI, 0.03 to 0.26) compared with other patients with VTE.345 The clinical significance of the increased incidence of VTE among OC users must also be understood in the context of the low prevalence of VTE in this population. The annual incidence of VTE among childbearing-age women is 2 to 3 per 10,000 people.346 Therefore, a three-fold increased risk translates to a still low absolute risk of fewer than 10 per 10,000 people per year. Perhaps most importantly, the incidence of VTE is four times higher among pregnant or postpartum women than among nonpregnant women. Therefore, the VTE risks associated with using OCs to prevent pregnancy are thought to be outweighed by the benefits of preventing pregnancy. Our findings will be used in a Markov model that estimates the overall risks and benefits of OC use for the prevention of ovarian cancer.

### OC Use and Stroke

We found a two-fold risk of both undifferentiated and ischemic stroke among current OC users, but no increased risk of hemorrhagic stroke. As with VTE, this risk seemed to be due to current and not ever use. Many of the studies that evaluated the relationship between OC use and stroke did not differentiate between hemorrhagic and ischemic stroke. Since most cerebral vascular accidents have an ischemic etiology, we combined studies of patients with known ischemic stroke and studies of undifferentiated stroke. To the extent that studies of undifferentiated stroke included hemorrhagic patients, this approach would be expected to underestimate the true association between OC use and ischemic stroke.

#### Duration and Formulation

We found inconclusive evidence that the risk of stroke changed with duration of OC use or progestin generation. There was, however, evidence that the risk of stroke increased with increasing estrogen dose (from 1.7 to 4.1). This evidence was confirmed by trials of progestin-only OCs that showed no elevated ischemic stroke risk.

#### Special Populations

Women with migraines, Factor V Leiden, and elevated homocysteine levels who use OCs may have a multiplicative increase in the risk of stroke. However, these findings need to be confirmed in larger studies. Increasing age of OC users may be associated with increasing risk of ischemic stroke. However, these data also need to be confirmed in larger studies.

#### Clinical Implications

As with VTE, the two-fold risk of ischemic stroke is important because stroke is both life-threatening and morbid.347 Between 8 to 12 percent of ischemic stroke victims die within one month of the diagnosis—and the vast majority have major neurologic deficits. Stroke is the leading cause of long-term disability in the United States. However, ischemic stroke incidence among women aged 15 to 44 is only 10.7 per 100,000 women-years348 and, similarly to VTE, pregnant and postpartum women have a three- to eight-fold increased risk of ischemic stroke.347 Therefore, the stroke risks associated with OC use are likely balanced by the benefits of preventing pregnancy. This may not be the case for women who are using OCs for ovarian cancer prevention and are not planning pregnancy.

### OC Use and Myocardial Infarction

We found a small increased risk of MI among current OC users (1.2), but the confidence intervals were not significant. There was also inconclusive evidence that duration of OC use or estrogen dose increased the risk. However, we did note a significant increased risk for first-generation progesterone users compared with second-and third-generation users. There may be a small increased risk of MI among current OC users that our meta-analysis is underpowered to find. This risk may be greater among specific groups, such as users of first-generation progestins, heavy smokers (15 cigarettes or more daily), or women with cardiovascular disease risk factors.

Notably, one study found a decreased mortality from MI among ever users of OCs. Reasons for this could be decreases in competing risks associated with pregnancy, bias of ascertainment in women who were known OC users, or decreased prescribing of OCs to women with cardiovascular disease risk factors. These issues may not have been fully adjusted for in the analysis.

#### Clinical Implications

For now, there is inconclusive evidence about increased MI risk associated with current OC use. Like VTE, MI is rare in women of reproductive age. In the United States, the annual incidence of MI is 0.3 to 0.7 percent among women; however, it is the sixth leading cause of death. Additional evidence is needed to effectively counsel patients about the risk of MI associated with OC use.

### Limitations

The major limitation to our findings is the lack of randomized trials available to determine if OCs cause increased risk of VTE, stroke, or MI. Of the studies included, the majority were case-control studies, likely due to the relative rarity of the outcomes in young women. Observational data are limited by unmeasurable confounding and inability to establish causation.

A second limitation of these data is the high degree of heterogeneity among the studies. There were many differences across studies in the covariates used in the analyses to adjust for potential confounding. For example, few studies of stroke incidence adequately controlled for well-established stroke risk factors such as hypertension, diabetes, and hyperlipidemia. The outcome definitions were also heterogeneous between studies. In the case of VTE, several studies included central venous thrombosis and superficial venous thromboembolism despite the fact that VTE is traditionally defined as DVT and/or PE. Further, some investigators excluded “nonidiopathic” or unexplained DVT from the analysis, but the majority did not. In the case of stroke, some investigators included central venous thrombosis, and transient ischemic attacks in the definition of stroke. Others did not differentiate between ischemic and hemorrhagic stroke.

Finally, the definition of the exposure varied by studies. A minority of studies compared ever OC users with never users. The majority of studies used current OC use as the exposure; however, many different definitions of current use existed (e.g., recently filled prescriptions, reported use in the last 3 months, or reported use in the last month). We included all studies that defined current use as sometime within the year prior to outcome assessment. The referent group also varied. In some cases, this was never users and in others this was noncurrent users, which included past and never users.

A limitation for all our formulation analyses is the large number of OC formulations that have been available during the course of these studies. Not only is it difficult to correctly identify a formulation used, but it is also impossible to know if that formulation was the one most proximal to an outcome of interest. Women taking OCs frequently change formulations due to cost or side effects, and so the formulation identified may not have been the one that should have been associated with the event. In addition, estrogen dose is not independent of progestin generation. Most higher dose estrogens are only found in combination with earlier generation progestins. We were unable to control for this in the analysis. Even if there were enough data to compare risks across formulations, the sheer volume of formulation combinations would cause a problem with multiple testing. Finally, current OC prescribing patterns in the United States involve mostly “very low dose” estrogen (e.g., 20 mcg or less); this dose of estrogen was infrequently reported in the included studies, and the risk associated could not be analyzed separately.

For each of the outcomes of interest, increasing age is associated with increased risk in the general population. Although every study corrected for age of the participant in the analysis, there were few studies that assessed the risk of each outcome in current OC users stratified by age. This information would be clinically meaningful when counseling patients. The age of participants is very integral to the risk–benefit calculation of using OCs to prevent ovarian cancer. For example, very few women over age 35 use OCs for contraception; therefore, this age group is probably underrepresented in the current data. However, this is the very age group that may be interested in using OCs for prevention of ovarian cancer.

### Future Research

Given the increased risk of VTE and stroke among OC users, future randomized controlled trials (RCTs) are unlikely. However, it would be useful if women who participated in RCTs of OC use investigating other outcomes could be followed to determine long-term risk of VTE, stroke, and MI. Future observational research into the risk of acute vascular complications associated with OC use should (1) clearly define the outcome of interest (e.g., ischemic vs. hemorrhagic stroke, not including transient ischemic attacks), (2) define the exposure as current versus never use and former versus never use and clearly define “current use,” (3) adjust for all known risk factors of the outcome (e.g., hypertension), (4) collect duration data according to years of use instead of categories so that more detailed analysis could be undertaken, (5) collect data on contemporary OCs such as very low dose estrogen pills, and (6) prioritize longitudinal cohort data. Studies addressing the risk of MI among current users of OCs are needed most.

### Applicability

The most important applicability issues are the time period of study for some of the large studies (going all the way back to the 1960s, with subsequent problems around dissimilar OCs used then vs. used now) and that very few of the included studies were conducted in the United States. Inadequate or incomplete reporting of age-related variables (e.g., age at first use of OCs, age at time of outcome event, and age at time of study participation) also contribute to the difficulty in applying these findings to specific age-groups of women in the United States.