# Oral Contraceptives and Other Cancers

## Background

Nearly half (49%) of all pregnancies in the United States are unintended, with 19 percent considered unwanted pregnancies.171 Oral contraceptives (OCs) are the most common form of effective and reversible contraception in the United States.172 Use of OCs significantly decreases personal and societal burdens associated with unintended or unwanted pregnancy.173,174 Additionally, OCs have significant noncontraceptive health benefits, such as improving acne or regulating dysmenorrhoea.175-178 Using OCs, however, is not without risks. Numerous studies demonstrate serious complications associated with OC use including venous thromboembolic disease, myocardial infarction, and stroke.179-181

Use of OCs also may influence the risk of certain cancers.56 OC use may promote or initiate tumors of the breast or cervix.50,67,182 For breast cancer, these risks may be even greater for populations at elevated risk due to family history of cancer or genetic mutation carrier status (e.g., BRCA1/2); however, results from studies are inconclusive.51,183 Moreover, the use of OCs has also been associated with a greater risk of certain clinically challenging types of breast tumors.184 Conversely, OC use is associated with significant reductions in colorectal and endometrial cancers.54,56 Our systematic review and meta-analyses support a significant risk reduction for ovarian cancer incidence and mortality associated with OC use (Section 2). However, assessment of the risk of cancer associated with OC use is fraught with difficulties. For example, cancer is a disease with a long latency period, and the time between exposure to OCs and diagnosis of cancer may span decades. Also, temporal variations in the OC formulations available on the market and used over a woman's lifetime may influence associations between cancer risk and OC use. Further, patterns of OC use over a lifetime may be influenced by factors that also affect cancer risks (e.g., gravidity, parity, breastfeeding). Last, duration of OC use or length of time since ceasing use (i.e., recency) may moderate the risk of cancers associated with OCs.50,121

In this section of our systematic review, we summarize the current data on associations between OC use and four common cancers among women—breast, cervical, colorectal, and endometrial. When possible, we conducted meta-analyses of the literature assessing the risk of cancer incidence and mortality associated with the use of OCs. We date-limited our search to studies published after 1999 to minimize the influence of OC formulations that are no longer available on the U.S. market and to increase generalizability to current clinical practice. When possible, we also examined associations by duration of OC use and time since last OC use on incidence of these cancers.

## Relevant Key Questions

The seven KQs developed for the entire systematic review are listed in Section 1 (refer to Figure 7 for a roadmap of this report). For Section 3, we performed a systematic review and meta-analysis for the cancer outcomes described in two of the seven KQs that address the potential effect of OCs on the risk of developing other cancers (breast, cervical, colorectal, and endometrial):

KQ 4: Aside from pregnancy prevention, are there other benefits of OC use in reducing the risks of endometrial cancer or colorectal cancer?

KQ 5: What are the harms of OC use, including breast cancer incidence, cervical cancer incidence, venous thromboembolic disease, stroke, or myocardial infarction? How do these harms vary by dose or formulation, duration of use, or specific population?

### Analytic Framework

Figure 22 shows the analytic framework that guided this section of the review.

Figure 22 Analytic framework for OCs and other cancers

KQ = Key Question; OC = oral contraceptive

Figure 22 depicts Key Questions 4-5 within the context of the PICO (population, interventions, comparators, and outcomes) that will be the focus of Section 3, Oral Contraceptives and Other Cancers.

## Methods

### Inclusion and Exclusion by PICOTS

Table 17 describes the PICOTS criteria that guided the literature search for this section of the review.

Table 17 Summary of inclusion and exclusion criteria for OCs and other cancers

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | - All KQs:; ○ Women taking oral contraceptives (OCs) for contraception or women taking OCs for primary prevention of ovarian cancer^a^; ○ Women who do not have a history of ovarian cancer and have not undergone bilateral oophorectomy | Nonhuman studies
Interventions | OC use (includes OC use for varying time periods and OC use with different formulations) | Study does not provide a description of at least one of the following:; 1. OC formulation(s) used; 2. Length of OC use
Comparators | No use of combination or progestin-only OCs, including either no contraceptive method at all or contraceptive methods other than combination or progestin-only OCs (e.g., natural family planning, barrier methods, sterilization, intrauterine devices, injectable or implantable hormonal contraception) | Study does not include controls; i.e., an estimate of outcomes in women not using OCs (population estimates are acceptable)
Outcomes | Study reports quantitative association between exposure to OCs and either incidence or disease-specific mortality for any of the following:; - KQ 4:; ○ Endometrial cancer; ○ Colorectal cancer; - KQ 5:; ○ Breast cancer; ○ Cervical cancer | Study only reports outcomes related to assisted reproductive technologies or abortion
Timing | Studies of any duration | None
Setting | All settings | None
Study design | - Controlled studies (randomized trials, cohort studies, case-control studies), pooled patient-level meta-analyses, or systematic reviews and study-level meta-analyses^b^; - Study sample size ≥ 100 subjects for nonrandomized studies^c^ | - Not a clinical study (e.g., editorial, non–systematic review, or letter to the editor); - Exploratory study with inadequate sample size
Publications | - English-language only; - Peer-reviewed articles; - Study reports a breast, endometrial, cervical, or colorectal cancer outcome of interest and was published on or after 01-Jan-2000^d^ | Non-English articles^e^

KQ = Key Question; OC = oral contraceptive

a If the purpose of OC use was unclear, it was assumed to be contraception.

b Systematic reviews and study-level meta-analyses were excluded from direct abstraction; those representing key sources were hand-searched as potential sources of additional material.

c Small nonrandomized studies <100 subjects were excluded because confidence intervals for outcomes of interest are generally quite wide if appropriate adjustment for confounding is performed, and variability in reporting of potential confounders makes meta-analysis problematic.

d Date ranges for these cancer outcomes were selected to balance generalizability (OC formulations used in earlier studies not currently on market) and power (peak incidence of cancers 10 to 30 years after typical use of oral contraceptives).

e Non-English articles were excluded (1) due to the high volume of literature available in English-language publications (including the majority of known important studies) and (2) due to concerns about the applicability of non-English publication studies to populations in the United States. The variability in OC formulations approved for use across countries increases the likelihood that non-English language studies would include OCs not available or not in use in the United States.

### Meta-Analytic Methods

To examine quantitatively the effect of OCs on the risk of breast, cervical, colorectal, or endometrial cancer, we performed meta-analyses on the following relationships when we had sufficient studies:

- Ever versus never OC use:
  ○ Ever versus never OC use among BRCA1 and BRCA2 genetic mutation carriers (breast cancer only)
- Temporal relationships:
  ○ Duration of OC use
  ○ Time since last OC use (breast cancer only)

We performed the meta-analyses using Comprehensive Meta-Analysis Version 2 (Biostat; Englewood, NJ; 2005).68 Confidence intervals from the included study publications were entered into the Comprehensive Meta-Analysis (CMA) program. However, many of these confidence intervals had been rounded to a single decimal place. The CMA program checks the intervals for symmetry in the logarithmic scale. In certain cases, the rounded limits were not accepted by CMA. In such cases, we kept the point estimate as given but changed the confidence limits so that they were symmetric. This resulted in slight differences in the confidence intervals in the forest plots when compared with the study publications.

We excluded studies that were conducted in special populations, such as BRCA mutation carriers, women with family histories of cancer, or specific cancer subtypes. When studies only gave results by subgroup (premenopausal, postmenopausal), we combined subgroups only when the combined group represented the total study population. We estimated pooled odds ratios with 95% confidence intervals (95% CIs) using a random-effects model when study designs and outcomes reported were similar. We evaluated heterogeneity visually and with the Cochran Q statistic using a threshold p-value of less than 0.10 to define significant heterogeneity. We stratified analyses by study type (case-control, cohort).

#### Pooled Analyses

We included pooled analyses in our meta-analyses if all three of the following conditions were met:

- None of the individual studies included in the pooled analysis had already been included for meta-analysis.
- At least half of the studies in the pooled analysis were published on or after January 1, 2000.
- Data in the pooled analyses were presented such that their inclusion in the current meta-analysis was feasible.

#### Ever Versus Never OC Use

For the ever versus never OC use meta-analysis, we excluded studies that reported effects for only a particular subpopulation (e.g., studies reporting odds ratios only for women with a BRCA mutation) but that did not report the effects for the general population. Studies that reported ever OC use odds ratios for two or more mutually exclusive subpopulations were included in the meta-analysis and results for the subpopulations were combined.

#### Temporal Relationships

##### Duration of OC Use

We used a random-effects model to compute odds ratios after determination that sufficient studies met criteria to perform a meta-analysis on the effect of duration of OC use. We required that the odds ratios were given relative to no OC use and that the population studied was not restricted to a particular special population. We assumed that each odds ratio, OR_ij_, could be described by the following model:

Ln [ OR_ij_ ] = α_i_ + ∑_j = 1_^k^ X_ij_ β_j_ ,

where i denotes the study, j denotes the specific time interval, and k is the number of time intervals used in the model. The α_i_ are assumed to be random and normal with mean 0 and variance (SE_ij_^2^ + σ^2^). SE_ij_ is the standard error of the j^th^ odds ratio from the i^th^ study. σ^2^ is the extra variation from the random effects model. The x_ij_ are the fixed terms that describe the time period covered by that particular odds ratio. The β_j_ (j=1, … , k) are the odds ratios to be estimated for each duration interval.

We originally assumed that there was a term for each year (up to 10) and a final term for greater than 10 years. However, the large number of terms resulted in very unstable estimates. For that reason, we broke the time points into 4 intervals: (1) 1 to 12 months, (2) 13 to 60 months, (3) 61 to 120 months, and (4) more than 120 months. We then used the x_ij_ to create the time period desired. For example, if the first interval were from 1 to 36 months, then the vector of x_ij_ would be (1/3, 2/3, 0, 0, 0). This would reflect that one-third of the patients in the interval were in the 1 to 12 month interval and two-thirds of the patients were in the 13 to 60 month interval. Using this methodology, any interval could be described. The model was fitted using SAS PROC NLMIXED (SAS Institute Inc.; Cary, NC; 2009) with “subject” set to the particular study, i.

##### Time Since Last OC Use

Using the equation above, we grouped time since last OC use into 4 intervals: (1) 0 to 5 years, (2) 5 to 10 years, (3) 10 to 20 years (4) more than 20 years. We then used the x_ij_ to create the time period desired. For example, if the first interval were from 1 to 15 years, then the vector of x_ij_ would be (2/3, 1/3, 0, 0, 0). This would reflect that two-thirds of the patients in the interval were in the 0 to 10 year interval and one-third of the patients were in the 10 to 20 year interval. Using this methodology, any interval could be described. The model was fitted using SAS PROC NLMIXED (SAS Institute Inc.; Cary, NC; 2009) with “subject” set to the particular study, i.

## Results

This section presents results of our detailed analysis of the relationship between OCs and the following outcomes:

- Breast cancer incidence and mortality
- Cervical cancer incidence and mortality
- Colorectal cancer incidence and mortality
- Endometrial cancer incidence and mortality

### OC Use and Breast Cancer Incidence

We identified 44 studies that evaluated the association between OC use and the incidence of breast cancer.37,88,94,99,138,139,155,156,183-228 Of these, 29 were case-control studies, 14 cohort studies, and 1 pooled analysis; 19 studies were rated good quality, 25 fair quality, and 3 poor quality. Roughly half of the studies (21) assembled cohorts fully or partially based in the United States (Table 18).

Table 18 Study characteristics and association between OC use and breast cancer incidence

Study^a^ | Study Details | OR^b^ | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^c^
Case-Control (continued)
Shapiro, 2000^185^ | Black or Colored women aged 20–54 yr in Cape Town [underlined: Cases:] 484 invasive breast cancer, hospital [underlined: Controls]: 1625, hospital Recruitment period: 1994–1997 | 1.2 | 1.0 to 1.5 | Age, sex, injectable progesterone use, ethnicity | South Africa | Fair | 1
Van Hoften, 2000^186^ | Women aged 41–52 yr in Doorlopend Onderzoek Morbiditeit/Mortaliteit Cohort Study [underlined: Cases]: 309 incident breast cancer, breast cancer screening program [underlined: Controls]: 610 cohort members Recruitment period: 1982–1984 | 1.24 | 0.96 to 1.78 | Age, parity, menopausal status, age at menarche, smoking, marital status, education, age at first delivery, maternal history of breast cancer | Netherlands | Good | 1
Gomes, 2001^187^ | Hospital patients in Belo Horizonte (age NR) [underlined: Cases]: 280 breast cancer, hospital [underlined: Controls]: 569 outpatients or gynecology inpatients Recruitment period: 1978–1987 | 1.93 | 1.19 to 3.11 | Parity, menopausal status, family history, occupation (housewife, housekeeper, other) irregular menstrual cycles, and possibly other (hard to tell) | Brazil | Poor | 1
Moorman, 2001^188^ | Women aged 20–74 yr in Carolina Breast Cancer Study White <50 yr [underlined: Cases:] 328 invasive breast cancer, registry [underlined: Controls]: 236, DMV or Medicare lists | 1.27 | 0.76 to 2.21 | Age, family history, age at menarche, breastfeeding , age at first pregnancy, age at menopause | U.S. | Fair | 1
Moorman, 2001^188^ | African American <50 yr [underlined: Cases:] 175 invasive breast cancer, registry [underlined: Controls]: 171, DMV or Medicare lists | 1.41 | 0.82 to 2.41 | Age, family history, age at menarche, breastfeeding , age at first pregnancy, age at menopause | U.S. | Fair | 1
Moorman, 2001^188^ | White ≥50 yr [underlined: Cases:] 195 invasive breast cancer, registry [underlined: Controls]: 221, DMV or Medicare lists | 0.95 | 0.59 to 1.53 | Age, family history, age at menarche, breastfeeding , age at first pregnancy, age at menopause | U.S. | Fair | 1
Moorman, 2001^188^ | African American ≥50 yr [underlined: Cases:] 160 invasive breast cancer, registry [underlined: Controls]: 161, DMV or Medicare lists | 0.90 | 0.51 to 1.57 | Age, family history, age at menarche, breastfeeding , age at first pregnancy, age at menopause | U.S. | Fair | 1
Moorman, 2001^188^ | Recruitment period: 1993–1996 | | | Age, family history, age at menarche, breastfeeding , age at first pregnancy, age at menopause | U.S. | Fair | 1
Heimdal, 2002^189^ | Women aged 40–60 yr from breast cancer families in a cancer family clinic [underlined: Cases]: 380 breast cancer [underlined: Controls]: 1043 Recruitment period: 1999 | 0.90 | 0.68 to 1.19 | Parity, age at menarche, BRCA1 mutation status | Norway | Fair | 2
Marchbanks, 2002^183^ | Women aged 35–64 yr in Women's Contraceptive and Reproductive Experiences (CARE) Study [underlined: Cases]: 4575 breast cancer, SEER registries [underlined: Controls]: 4682, community Recruitment period: 1994–1998 | 0.9 | 0.80 to 1.01 | Age, race, parity, menopausal status, BMI, family history, age at menarche, study site, age at menopause, age at first term pregnancy, hormone replacement therapy | U.S. | Good | 1
Narod, 2002^190^ | Known carriers of BRCA1 or BRCA2 mutations BRCA1 carriers [underlined: Cases:] 981 breast cancer, research studies [underlined: Controls]: 981, research studies | | | Race, parity | 52 centers in 11 countries | Fair | 3
Narod, 2002^190^ | BRCA2 carriers [underlined: Cases:] 330 breast cancer, research studies [underlined: Controls]: 330, research studies | 1.20 | 1.02 to 1.40 | Race, parity | 52 centers in 11 countries | Fair | 3
Narod, 2002^190^ | Mean age of cases at diagnosis: 39.1 yr (SD 8.1) Recruitment period: 1977–2001 | 0.94 | 0.72 to 1.24 | Race, parity | 52 centers in 11 countries | Fair | 3
Tryggvadottir, 2002^227^ | All Icelandic women diagnosed with first invasive breast cancer from 1979–1995 [underlined: Cases]: 1120, registry [underlined: Controls]: 10,537, registry Recruitment period: 1979–1995 | NR | NR | NA | Iceland | Good | 5
Althuis, 2003^191^ | Premenopausal women aged 20–54 yr [underlined: Cases]: 265 breast cancer, <35 yr [underlined: Controls]: 280 community controls, <35 yr | 0.73 | 0.5 to 1.1 | Age, race, BMI, age at menarche, study site, number of mammograms within 5 yr prior to diagnosis, recent oral contraceptive use, a combination variable for age at birth and number of full-term births, family history of breast cancer, alcohol consumption | U.S. | Good | 1
Althuis, 2003^191^ | [underlined: Cases]: 1214 breast cancer, 35–44 yr [underlined: Controls]: 1033 community controls, 35–44 yr | 1.13 | 0.9 to 1.4 | | U.S. | Good | 1
Althuis, 2003^191^ | [underlined: Cases]: 271 breast cancer, 45–54 yr [underlined: Controls]: 244 community controls, 45–54 yr | 2.03 | 1.3 to 3.1 | | U.S. | Good | 1
Althuis, 2003^191^ | Recruitment period: 1990–1992 | | | | U.S. | Good | 1
Althuis, 2003^192^ | Women aged 20–54 yr in 5 metropolitan areas [underlined: Cases]: 1640 invasive or in situ breast cancer, registries [underlined: Controls]: 1492 no breast cancer, community Recruitment period: 1990–1992 | NR | NR | NA | U.S. | Fair | 4
Newcomer, 2003^193^ | Women <75 yr in Collaborative Breast Cancer Study [underlined: Cases]: 5510 breast cancer, registries [underlined: Controls]: 9311, community Note: ductal cancer only (lobular cancer cases excluded) Recruitment period: NR | 1.00 | 0.90 to 1.11 | Age, race, BMI, family history, type of and age at menopause, state, education, alcohol | U.S. | Fair | 10
Norman, 2003^194^ | Women aged 35–64 yr in Women's Contraceptive and Reproductive Experiences (CARE) Study [underlined: Cases]: 1847 breast cancer, SEER registries [underlined: Controls]: 1932, community Recruitment period: 1994–1998 | NR | NR | NA | U.S. | Fair | 5
Suter, 2003^195^ | Women <45 yr in Western Washington [underlined: Cases]: 524 breast cancer, SEER registry [underlined: Controls]: 461, community Recruitment period: 1990–1992 | 1.3 | 0.9 to 1.8 | Age | U.S. | Fair | 1
Wrensch, 2003^228^ | Residents of Marin County, California All subjects [underlined: Cases]: 285, registry [underlined: Controls]: 286, community | 0.43 | 0.26 to 0.72 | Age, residence at birth | U.S. | Good | 1
Wrensch, 2003^228^ | Age <50 [underlined: Cases]: 201, registry [underlined: Controls]: 201, community | 0.41 | 0.22 to 0.75 | Age, residence at birth | U.S. | Good | 1
Wrensch, 2003^228^ | Age >50 [underlined: Cases]: 84, registry [underlined: Controls]: 85, community | 0.15 | 0.03 to 0.65 | Age, residence at birth | U.S. | Good | 1
Wrensch, 2003^228^ | Recruitment period: 1997–1999 | | | Age, residence at birth | U.S. | Good | 1
Fowke, 2004^196^ | Women aged 25–70 yr in Shanghai Breast Cancer Study Premenopausal [underlined: Cases]: 103 breast cancer, hospitals and registry [underlined: Controls]:103, resident registry | 0.92 | 0.67 to 1.26 | Age, parity, BMI, age at menarche, education, fibroadenoma history, leisure time activity, age at first live birth | China | Fair | 9
Fowke, 2004^196^ | Postmenopausal [underlined: Cases]: 110 breast cancer, hospitals and registry [underlined: Controls]: 127, resident registry | 0.96 | 0.70 to 1.32 | Age, parity, BMI, age at menarche, education, fibroadenoma history, leisure time activity, age at first live birth | China | Fair | 9
Fowke, 2004^196^ | Recruitment period: 1996–1998 | | | Age, parity, BMI, age at menarche, education, fibroadenoma history, leisure time activity, age at first live birth | China | Fair | 9
Jernstrom, 2005^197^ | Women <40 yr in South Swedish Health Care Region [underlined: Cases]: 245 breast cancer, registry [underlined: Controls]: 735, community Recruitment period: 1990–1995 | 1.65 | 0.95 to 2.87 | Parity, family history, age at menarche, smoking | Sweden | Fair | 4
Milne, 2005^198^ | Women <40 yr in San Francisco, Ontario, Melbourne, and Sydney Cases with BRCA1 mutation [underlined: Cases]: 47 breast cancer, registries [underlined: Controls]: 815, community | 0.22 | 0.10 to 0.49 | Age, parity, family history, age at menarche, study location/period, education, marital status, country of birth | U.S., Canada, Australia | Good | 4
Milne, 2005^198^ | Cases with BRCA2 mutation [underlined: Cases]: 36 breast cancer, regional registries [underlined: Controls]: 815, community | 1.02 | 0.34 to 3.09 | Age, parity, family history, age at menarche, study location/period, education, marital status, country of birth | U.S., Canada, Australia | Good | 4
Milne, 2005^198^ | Cases with neither BRCA1 or 2 mutations [underlined: Cases]: 1073 breast cancer, registries [underlined: Controls]: 815, community | 0.93 | 0.69 to 1.24 | Age, parity, family history, age at menarche, study location/period, education, marital status, country of birth | U.S., Canada, Australia | Good | 4
Milne, 2005^198^ | Recruitment period: 1995–1998 | | | Age, parity, family history, age at menarche, study location/period, education, marital status, country of birth | U.S., Canada, Australia | Good | 4
Gronwald, 2006^94^ | BRCA1 carriers, Hereditary Cancer Center (age NR) [underlined: Cases]: 348 breast cancer, cancer center [underlined: Controls]: 348, cancer center Recruitment period: NR | 0.80 | 0.50 to 1.20 | NR | Poland | Fair | 3
Haile, 2006^199^ | White women <40 yr BRCA1 or BRCA2 carriers BRCA1 carriers (cases and controls) [underlined: Cases]: 111 breast cancer, registries [underlined: Controls]: 185, registries | 0.64 | 0.35 to 1.16 | Age, parity, family history, study site | U.S., Canada, Australia | Good | 3
Haile, 2006^199^ | BRCA2 carriers (cases and controls) [underlined: Cases]: 71 breast cancer, registries [underlined: Controls], 94, registries | 1.29 | 0.61 to 2.76 | Age, parity, family history, study site | U.S., Canada, Australia | Good | 3
Haile, 2006^199^ | Recruitment period: NR | | | Age, parity, family history, study site | U.S., Canada, Australia | Good | 3
Ma, 2006^201^ | Women aged 35–64 yr in Women's Contraceptive and Reproductive Experiences (CARE) Study [underlined: Cases]: 1725 breast cancer, SEER registries [underlined: Controls]: 440, community Recruitment period: 1994–1998 | NR | NR | NA | U.S. | Good | 5
Rosenberg, 2006^200^ | Extension of a case-control study among Swedish residents aged 50–74 yr [underlined: Cases]: 2289 ductal, lobular, or tubular cancer, registries [underlined: Controls]: 3065, population registry Recruitment period: 1993–1995 | NR | NR | NA | Sweden | Fair | 5
Faheem, 2007^202^ | Hospital patients in Islamabad [underlined: Cases]: 150,breast cancer, hospital [underlined: Controls]: 159, community Mean age of cases: 42 yr (SD 12) Recruitment period: 2005 | NR | NR | NA | Pakistan | Poor | 5
Folger, 2007^203^ | Women aged 35–64 yr with history of short-term OC use, Women's CARE study Premenopausal [underlined: Cases]: 497 breast cancer, SEER registries [underlined: Controls]: 456, community Postmenopausal [underlined: Cases]: 729 breast cancer, SEER registries [underlined: Controls]: 707, community Recruitment period: 1994–1998 | NR | NR | NR | U.S. | Fair | 5
Nichols, 2007^204^ | Women aged 20–74 yr in Collaborative Breast Cancer Study [underlined: Cases]: 1878 breast cancer in situ, registry [underlined: Controls]: 8041, community Recruitment period: 1997–2001 | 1.10 | 0.99 to 1.25 | Age, parity, menopausal status, family history, age at menarche, smoking, state, age at first birth, age at menopause, HRT, weight at age 18, height, weight gain since age 18, education, mammography screening, history of benign breast disease | U.S. | Good | 6
Shantakumar, 2007^205^ | Long Island Breast Cancer Study Project (age NR) Premenopausal women [underlined: Cases]: 468 in situ or invasive breast cancer, rapid case ascertainment [underlined: Controls]: 500, community | 0.82 | 0.57 to 1.19 | Age | U.S. | Good | 1
Shantakumar, 2007^205^ | Postmenopausal <65 years old [underlined: Cases]: 491 in situ or invasive breast cancer, registry, rapid case ascertainment [underlined: Controls]: 554, community | 0.95 | 0.74 to 1.22 | Age | U.S. | Good | 1
Shantakumar, 2007^205^ | Postmenopausal >65 years old [underlined: Cases]: 519 in situ or invasive breast cancer, registry [underlined: Controls]: 439, community | 1.37 | 1.04 to 1.81 | Age | U.S. | Good | 1
Shantakumar, 2007^205^ | Recruitment period: 1996–1997 | | | Age | U.S. | Good | 1
Sweeney, 2007^206^ | Hispanic and non-Hispanic white women ≤64 yr All subjects [underlined: Cases]: 2303 breast cancer, registries [underlined: Controls]: 2513, community | 1.08 | 0.94 to 1.24 | Age, parity, menopausal status, family history, study center, education, alcohol, language acculturation, years since last birth, use of contraception injections and HRT | U.S. | Good | 1
Sweeney, 2007^206^ | Hispanics only [underlined: Cases]: 796 breast cancer, registries [underlined: Controls]: 919, community | 1.08 | 0.90 to 1.29 | Age, parity, menopausal status, family history, study center, education, alcohol, language acculturation, years since last birth, use of contraception injections and HRT | U.S. | Good | 1
Sweeney, 2007^206^ | Non-Hispanic Whites [underlined: Cases]: 1522 breast cancer, registries [underlined: Controls]: 1586, community | 1.10 | 0.88 to 1.37 | Age, parity, menopausal status, family history, study center, education, alcohol, language acculturation, years since last birth, use of contraception injections and HRT | U.S. | Good | 1
Sweeney, 2007^206^ | Recruitment period: 1999–2004 | | | Age, parity, menopausal status, family history, study center, education, alcohol, language acculturation, years since last birth, use of contraception injections and HRT | U.S. | Good | 1
Figueiredo, 2008^207^ | Women <55 yr in Women's Environment, and Radiation Epidemiology Study Women with history of unilateral breast cancer [underlined: Cases]: 708 asynchronous bilateral breast cancer, registry [underlined: Controls]: 1399 unilateral breast cancer only, registry Recruitment period: 1985–2000 | 0.88 | 0.67 to 1.16 | Parity, menopausal status, family history, age at menarche, counter-matching sampling, age at diagnosis of first breast cancer, family history of breast cancer in a first degree relative, histology, stage, chemotherapy, hormonal therapy, radiation therapy | U.S. | Fair | 7
Lee, 2008^208^ | Women aged 20–49 yr in Women's Learning the Influence of Family and Environment Study [underlined: Cases]: 94, breast cancer and BRCA1/2 carrier, registry [underlined: Controls]: 444 BRCA1/2 unknown, community | 0.68 | 0.33 to 1.38 | Age, race, parity, family history, education, Ashkenazi Jewish | U.S. | Good | 3
Lee, 2008^208^ | [underlined: Cases]: 1375 breast cancer, not BRCA1/2 carrier, registry [underlined: Controls]: 444 BRCA1/2 unknown, community | 0.81 | 0.57 to 1.14 | Age, race, parity, family history, education, Ashkenazi Jewish | U.S. | Good | 1
Lee, 2008^208^ | Recruitment period: 1998–2003 | | | Age, race, parity, family history, education, Ashkenazi Jewish | U.S. | Good
Nyante, 2008^209^ | Women aged 20–44 yr in Women's Interview Study of Health Ductal cancer [underlined: Cases]: 1164 invasive or in situ cancer, rapid reporting system [underlined: Controls]: 1501, community | 1.21 | 1.01 to 1.45 | Age, site, frequency of pap smears | U.S. | Fair | 4
Nyante, 2008^209^ | Lobular cancer [underlined: Cases]: 100, invasive or in situ cancer, rapid reporting system [underlined: Controls]: 1501, community | 1.10 | 0.68 to 1.78 | Age, site, frequency of pap smears | U.S. | Fair | 4
Nyante, 2008^209^ | Recruitment period: 1990–1992 | | | Age, site, frequency of pap smears | U.S. | Fair | 4
Phillips, 2009^211^ | Women aged 20–74 yr in Carolina Breast Cancer Study [underlined: Cases]: 1808 invasive breast cancer, registry [underlined: Controls]: 1564, community | 1.11 | 0.94 to 1.32 | Age, race | U.S. | Fair | 1
Phillips, 2009^211^ | [underlined: Cases]: 446 in situ cancer, registry [underlined: Controls]: 458, community | 1.11 | 0.80 to 1.53 | Age, race | U.S. | Fair | 1
Phillips, 2009^211^ | Recruitment period: 1993–2001 | | | Age, race | U.S. | Fair | 1
Rosenberg, 2009^210^ | Women aged 25–69 yr in Case-Control Surveillance Study Cases: all invasive cancers [underlined: Cases]: 907 breast cancer, hospital [underlined: Controls]: 1711, hospital Age <50 [underlined: Cases]: 431 breast cancer, hospital [underlined: Controls]: 939, hospital Age>50 [underlined: Cases]: 476 breast cancer, hospital [underlined: Controls]: 772, no breast cancer, hospital Black women [underlined: Cases]: 176 breast cancer, hospital [underlined: Controls]: 559, hospital White women [underlined: Cases]: 731 breast cancer, hospital [underlined: Controls]: 1152, hospital Recruitment period: 1976–1996 | NR | NR | NA | U.S. | Fair | 5
Figueiredo, 2010^212^ | Women <55 yr in Women's Environment, and Radiation Epidemiology Study BRCA1 carriers (cases and controls) [underlined: Cases]: 67 contralateral breast cancer, registry [underlined: Controls]: 42 unilateral breast cancer, registry | 0.82 | 0.21 to 3.13 | Age | U.S. | Fair | 7
Figueiredo, 2010^212^ | BRCA2 carriers (cases and controls) [underlined: Cases]: 41 contralateral breast cancer, registry [underlined: Controls]: 31 contralateral breast cancer, registry | 2.38 | 0.72 to 7.83 | Age | U.S. | Fair | 7
Figueiredo, 2010^212^ | Recruitment period: 1985–2000 | | | Age | U.S. | Fair | 7
Lumachi, 2010^213^ | Women who underwent curative surgery for breast cancer Postmenopausal women [underlined: Cases]: 238 breast cancer, surgically treated [underlined: Controls]: 255, mammography screening Mean age of cases at diagnosis: 62 yr (SD 10) Recruitment period: NR | 2.06 | 1.14 to 3.70 | Unadjusted | Italy | Fair | 1
Ma, 2010^214^ | White or African-American women aged 35–64 yr [underlined: Cases]: 335 triple-negative breast cancer, registries [underlined: Controls]: 2015, community | 0.93 | 0.74 to 1.17 | Age, race, parity, menopausal status, BMI, family history, age at menarche, study site, education | U.S. | Good | 8
Ma, 2010^214^ | [underlined: Cases]: 97 ER-/PR/HER2+ breast cancer, registries [underlined: Controls]: 2015, community | 1.00 | 0.72 to 1.39 | Age, race, parity, menopausal status, BMI, family history, age at menarche, study site, education | U.S. | Good | 8
Ma, 2010^214^ | [underlined: Cases]: 645 luminal A breast cancer, registries [underlined: Controls]: 2015, community | 1.21 | 0.69 to 2.11 | Age, race, parity, menopausal status, BMI, family history, age at menarche, study site, education | U.S. | Good | 8
Ma, 2010^214^ | [underlined: Cases]: 120 luminal B breast cancer, registries [underlined: Controls]: 2015, community | 1.23 | 0.73 to 2.10 | Age, race, parity, menopausal status, BMI, family history, age at menarche, study site, education | U.S. | Good | 8
Ma, 2010^214^ | Recruitment period: 2000–2003 | | | Age, race, parity, menopausal status, BMI, family history, age at menarche, study site, education | U.S. | Good | 8
Xu, 2011^224^ | Women aged 25–65 yr in Shanghai Breast Cancer Study [underlined: Cases]: 2073 breast cancer, hospitals and registry [underlined: Controls]: 2084, resident registry Recruitment periods: 1996–1998; 2002–2005 | 0.98 | 0.83 to 1.15 | Age, parity, menopausal status, BMI, family history, age at menarche, education | China | Good | 1
Marchbanks, 2012^226^ | White or black women aged 35–64 yr [underlined: Cases]: 2282, registries [underlined: Controls]: 2424, community Recruitment period: 1994–1998 | NR | NR | NA | U.S. | Good | 5
Urban, 2012^155^ | Black South African women aged 18–79 yr [underlined: Cases]: 256, hospital [underlined: Controls]: 156, hospital Recruitment period: 1995–2006 | 1.28 | 1.0 to 1.64 | Age, parity, smoking, year of diagnosis, education, alcohol consumption, sexual partners, urban/rural residence, province of birth | South Africa | Good | 1
Cohort
Grabrick, 2000^215^ | Family members of women aged 21–88 yr diagnosed with breast cancer between 1944 and 1952 [underlined: Exposed]: 3156 [underlined: Unexposed]: 2994 Recruitment period: 1991–1996 | 1.4 | 1.0 to 2.0 | Age, birth cohort, class effect of family | U.S. | Good | 2
Kumle, 2002^216^ | Women aged 30–49 yr in prospective cohort study [underlined: Exposed]: 74,856 [underlined: Unexposed]: 28,171 Recruitment period: 1991–1992 | 1.3 | 1.1 to 1.5 | Age, parity, menopausal status, BMI, family history, age at menarche, breastfeeding , age at first birth, HRT use, region, BMI times menopausal status | Norway, Sweden | Good | 1
Dumeaux, 2003^217^ | Women aged 30–70 yr in Norwegian Women and Cancer Study [underlined: Exposed]: 49,322 [underlined: Unexposed]: 37,690 Recruitment period: 1991–1997 | 1.25 | 1.07 to1.46 | Age, parity, menopausal status, BMI, family history, age at menarche, geographic area, invitation of breast cancer screening, age at first birth, HRT use, alcohol consumption | Norway | Fair | 1
Dumeaux, 2005^218^ | E3N-EPIC Cohort women aged 40–60 yr [underlined: Exposed]: 28,251 [underlined: Unexposed]: 40,419 Recruitment period: 1990 | 0.91 | 0.81 to 1.03 | Parity, BMI, family history, age at menarche, frequency of pap smears, history of benign breast disease, alcohol consumption, time since menopause | France | Fair | 1
Silvera, 2005^219^ | Women aged 40–59 yr in Canadian National Breast Screening Study Women with first- or second-degree relatives with breast cancer [underlined: Exposed]: 962 [underlined: Unexposed]: 745 | 0.88 | 0.73 to 1.07 | Age, parity, menopausal status, BMI, age at menarche, alcohol, history of breast disease, age at first birth, HRT use, study center, randomization group | Canada | Good | 2
Silvera, 2005^219^ | Women with first-degree relatives with breast cancer [underlined: Exposed]: 433 [underlined: Unexposed]: 362 | 1.03 | 0.78 to 1.38 | Age, parity, menopausal status, BMI, age at menarche, alcohol, history of breast disease, age at first birth, HRT use, study center, randomization group | Canada | Good | 2
Silvera, 2005^219^ | Women with second-degree relatives with breast cancer [underlined: Exposed]: 414 [underlined: Unexposed]: 284 | 0.74 | 0.54 to 1.00 | Age, parity, menopausal status, BMI, age at menarche, alcohol, history of breast disease, age at first birth, HRT use, study center, randomization group | Canada | Good | 2
Silvera, 2005^219^ | Recruitment period: 1980–1985 | | | Age, parity, menopausal status, BMI, age at menarche, alcohol, history of breast disease, age at first birth, HRT use, study center, randomization group | Canada | Good | 2
Vessey, 2006^156^ | Women aged 25–39 yr at study entry in Oxford Family Planning Association Contraceptive Study [underlined: Exposed]: 301,000 person-years [underlined: Unexposed]: 187,000 person-years Recruitment period: 1968–1974 | 1.0 | 0.8 to 1.1 | Age, parity, BMI, breastfeeding, social class, height, age at first term pregnancy, age at first marriage | UK | Good | 1
Brohet, 2007^220^ | Women aged 19–74 yr in International BRCA1/2 Carrier Cohort Study [underlined: Exposed]: 21,569 person-years [underlined: Unexposed]: 43,611 person-years Recruitment period: NR | 1.47 | 1.16 to 1.87 | Age, parity, family clustering, history of oophorectomy before right censoring | UK, France, Netherlands | Fair | 3
Hannaford, 2007^37^ | Royal College of General Practitioner's Oral Contraception Study [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–NR | 0.98 | 0.87 to 1.10 | Age, parity, smoking, social status; ever use HRT | UK | Fair | 1
Lund, 2007^221^ | Women aged 34–70 yr in Norwegian Women and Cancer Study [underlined: Exposed]: 11,371 [underlined: Unexposed]: 18,747 Recruitment period: 1991–1997 | 1.33 | 1.11 to 1.59 | Parity, BMI, family history, age at menarche, mammography, age at first delivery | Norway | Good | 1
Dorjgochoo, 2009^88^ | Women aged 40–70 yr in Shanghai Women's Health Study [underlined: Exposed]: 12,957 [underlined: Unexposed]: 15,557 Recruitment period: 1997–2000 | 1.05 | 0.84 to 1.31 | Age, parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | China | Fair | 1
Rosenblatt, 2009^138^ | Textile Workers aged 30–64 yr in Shanghai [underlined: Exposed]: 352,695 person-years [underlined: Unexposed]: 2,057,377 person-years Recruitment period: 1989–1991 | 0.9 | 0.78 to 1.03 | Age, parity | China | Poor | 1
Hunter, 2010^222^ | Nurses' Health Study II of women aged 24–43 yr at study entry [underlined: Exposed]: 1,070,386 person-years [underlined: Unexposed]: 176,581 person-years Recruitment period: 1989–2001 | NR | NR | NA | U.S. | Good | 4
Rosenberg, 2010^223^ | Women aged 21–69 yr in Black Women's Health Study [underlined: Exposed]: 445,824 person-years [underlined: Unexposed]: 128,768 person-years | | | Age, parity, BMI, family history, age at menarche, education, age at first birth, age at menopause, HRT, exercise, alcohol, questionnaire cycle | U.S. | Fair | 8
Rosenberg, 2010^223^ | ER+/PR+ receptor status [underlined: Cases]: 284 | IRR=1.11 | 0.86 to 1.42 | Age, parity, BMI, family history, age at menarche, education, age at first birth, age at menopause, HRT, exercise, alcohol, questionnaire cycle | U.S. | Fair | 8
Rosenberg, 2010^223^ | ER+/PR- receptor status [underlined: Cases]: 80 | IRR=0.97 | 0.61 to 1.54 | Age, parity, BMI, family history, age at menarche, education, age at first birth, age at menopause, HRT, exercise, alcohol, questionnaire cycle | U.S. | Fair | 8
Rosenberg, 2010^223^ | ER-/PR- receptor status [underlined: Cases]: 46 | IRR=1.65 | 1.19 to 2.30 | Age, parity, BMI, family history, age at menarche, education, age at first birth, age at menopause, HRT, exercise, alcohol, questionnaire cycle | U.S. | Fair | 8
Rosenberg, 2010^223^ | Recruitment period: 1995 | | | Age, parity, BMI, family history, age at menarche, education, age at first birth, age at menopause, HRT, exercise, alcohol, questionnaire cycle | U.S. | Fair | 8
Bernholtz, 2011^225^ | Jewish women at high risk of developing breast or ovarian cancer BRCA1 or BRCA2 carriers [underlined: Exposed]: 403 [underlined: Unexposed]: 373 | 1.84 | 1.47 to 2.31 | Age at menarche, breastfeeding, year of birth | Israel | Fair | 3
Bernholtz, 2011^225^ | BRCA1 carriers [underlined: Exposed]: 309 [underlined: Unexposed]: 182 | 1.72 | 1.31 to 2.25 | Age at menarche, breastfeeding, year of birth | Israel | Fair | 3
Bernholtz, 2011^225^ | BRCA2 carriers [underlined: Exposed]: 136 [underlined: Unexposed]: 72 | 2.07 | 1.34 to 3.20 | Age at menarche, breastfeeding, year of birth | Israel | Fair | 3
Bernholtz, 2011^225^ | Recruitment period: 1996–2010 | | | Age at menarche, breastfeeding, year of birth | Israel | Fair | 3
Pooled
Dolle, 2009^184^ | Women aged 21–45 yr in Seattle-Puget Sound [underlined: Cases:] 897 with invasive cancer; 187 with triple negative cancer; registries [underlined: Controls:] 1569, not reported | 1.3 (all subjects) | 1.0 to 1.7 | Age, family history, breastfeeding history, oral contraceptive duration | U.S. | Fair | 8
Dolle, 2009^184^ | Recruitment periods: 1983–1990; 1990–1992 | 2.5 (triple-negative subjects) | 1.4 to 4.3 | Age, family history, breastfeeding history, oral contraceptive duration | U.S. | Fair | 8

BMI = body mass index; CI = confidence interval; DMV = department of motor vehicles; ER = estrogen receptor; HRT = hormone replacement therapy; IRR = incidence rate ratio; NR = not reported; NZ = New Zealand; OC = oral contraceptive; OR = odds ratio; PR = progesterone receptor; SEER = Surveillance, Epidemiology, and End Results registry; UK = United Kingdom; U.S. = United States; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Odds ratios for meta-analysis of ever versus never OC use.

c Meta-analysis code: 1= Included in meta-analysis; 2 = Excluded due to family history of breast cancer; 3 = Excluded due to BRCA mutation carriers; 4 = Excluded due to age at diagnosis ≤45 yr; 5 = Excluded due to overall ever versus never OR not reported or not calculable; 6 = Excluded due to cancer in situ only; 7 = Excluded due to all cases and controls having breast cancer; 8 = Excluded due to ER/PR/HER2 subtypes; 9 = Excluded due to data are subset of Shanghai Breast Cancer Study224; 10 = Excluded due to targeting certain subtypes of cancer only.

#### Ever Versus Never OC Use

Fifteen case-control studies representing 38,682 women155,183,185-188,191,195,205,206,208,211,213,224,228 were included in this meta-analysis examining the effect of ever versus never OC use on the incidence of breast cancer (Table 18). Of these studies, nine were rated good quality, five fair quality, and one poor quality. Abstracted data not included in this analysis are specified (with rationale) in Table 18. Reasons for exclusion from this analysis included the following: study populations representing specialized subgroups (e.g., BRCA mutation populations, family history, cancer subtype); reporting a subset of results from the same study as another article already included in the analysis; and not reporting an odds ratio for ever versus never OC use. Some studies gave results only by subgroup; however, in some instances we were able to combine the subgroups to calculate the odds ratio for the entire study population. Figure 23 shows the results; ever use of OCs increased the risk of breast cancer compared with never use, but the confidence interval included 1 (OR 1.09; 95% CI, 0.98 to 1.21).

Figure 23 Forest plot for ever versus never OC use (case-control studies, breast cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 23 shows the results; ever use of OCs increased the risk of breast cancer compared to never use, but the confidence interval included 1 (OR 1.09; 95% CI, 0.98 to 1.21).

Eight cohort studies representing 317,341 women across five studies and 3,981,072 person-years across three studies37,88,138,156,216-218,221 met inclusion criteria for this meta-analysis (Table 18). Of these studies, three were rated good quality, four fair quality, and one poor quality. Abstracted data not included in this analysis are specified (with rationale) in Table 18. Reasons for exclusion from this analysis included the following: study populations representing specialized subgroups; and not computing an effect size for ever use versus never OC use. As shown in Figure 24, the odds ratio for ever versus never use of OCs was similar to that for the case-control studies (OR 1.07; 95% CI, 0.96 to 1.20).

Figure 24 Forest plot for ever versus never OC use (cohort studies, breast cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 24 shows that the odds ratio for ever versus never use of OCs was similar to that for the case-control studies (OR 1.07; 95% CI, 0.96 to 1.20).

The pooled effect sizes for the two groups were similar, with a test for a difference resulting in a p-value of 0.81. Therefore, we combined case-control studies and cohort studies. Across all included studies, results suggest that a history of OC use slightly but significantly increases the incidence of breast cancer compared with women who never used OCs. The odds ratio was 1.08 (95% CI, 1.00 to 1.17), with a Q-value of 73.35 for 21 degrees of freedom, p<0.001.

##### Sensitivity Analyses

Analyses were repeated excluding the one cohort study rated poor quality. This exclusion had a minor effect on the odds ratio estimates for all studies combined (OR 1.08; 95% CI, 1.00 to 1.16). We also conducted sensitivity analyses among U.S.-based studies only; effect sizes were smaller and no longer statistically significant (OR 1.03; CI, 0.93 to 1.14).

#### Duration of OC Use

Fourteen studies138,156,183,185,188,194,195,201,205,206,211,216-218,228 were included in this meta-analysis examining the effect of duration of OC use on breast cancer incidence (Table 19). Of these, 9 were case-control studies. Six studies were rated good quality, eight fair quality, and one poor quality. We did not include data in the meta-analysis for studies that were conducted in a special population, did not have at least 3 categories for duration of use, or used a referent category other than never users.

Table 19 Data for outcomes on duration of use (breast cancer incidence)

Study^a^ | Subgroup (if Applicable) | Duration | OR | 95% CI
Case-Control
Shapiro, 2000^185^ | | < 1 yr | 1.3 | 0.8 to 1.4
Shapiro, 2000^185^ | | 1–4 yr | 1.3 | 1.0 to 1.8
Shapiro, 2000^185^ | | 5–9 yr | 1.4 | 0.9 to 2.1
Shapiro, 2000^185^ | | > 10 yr | 1.2 | 0.7 to 2.3
Van Hoften, 2000^186^ | Total sample | 1–10 yr | 1.27 | 0.92 to 1.77
Van Hoften, 2000^186^ | Total sample | > 10 yr | 1.43 | 0.92 to 2.22
Van Hoften, 2000^186^
Van Hoften, 2000^186^ | Women ≤55 yr | 1–10 yr | 1.25 | 0.85 to 1.82
Van Hoften, 2000^186^ | Women ≤55 yr | > 10 yr | 1.22 | 0.72 to 2.07
Van Hoften, 2000^186^
Van Hoften, 2000^186^ | Women ≥56 yr | 1–10 yr | 1.26 | 0.74 to 2.14
Van Hoften, 2000^186^ | Women ≥56 yr | > 10 yr | 2.05 | 1.07 to 3.95
Moorman, 2001^188^ | White women <50 yr | ≤ 1 yr | 1.29 | 0.68 to 2.47
Moorman, 2001^188^ | White women <50 yr | 1–5 yr | 1.49 | 0.85 to 2.64
Moorman, 2001^188^ | White women <50 yr | 5–10 yr | 0.94 | 0.52 to 1.70
Moorman, 2001^188^ | White women <50 yr | > 10 yr | 1.41 | 0.74 to 2.70
Moorman, 2001^188^
Moorman, 2001^188^ | African-American women <50 yr | ≤ 1 yr | 1.29 | 0.61 to 2.72
Moorman, 2001^188^ | African-American women <50 yr | 1–5 yr | 1.23 | 0.66 to 2.32
Moorman, 2001^188^ | African-American women <50 yr | 5–10 yr | 1.64 | 0.82 to 3.28
Moorman, 2001^188^ | African-American women <50 yr | > 10 yr | 1.61 | 0.77 to 3.35
Moorman, 2001^188^
Moorman, 2001^188^ | White women ≥50 yr | ≤ 1 yr | 0.92 | 0.49 to 1.73
Moorman, 2001^188^ | White women ≥50 yr | 1–5 yr | 0.90 | 0.43 to 1.89
Moorman, 2001^188^ | White women ≥50 yr | 5–10 yr | 0.80 | 0.38 to 1.67
Moorman, 2001^188^ | White women ≥50 yr | > 10 yr | 1.34 | 0.59 to 3.07
Moorman, 2001^188^
Moorman, 2001^188^ | African-American women ≥50 yr | ≤ 1 yr | 0.90 | 0.40 to 2.01
Moorman, 2001^188^ | African-American women ≥50 yr | 1–5 yr | 0.39 | 0.16 to 0.99
Moorman, 2001^188^ | African-American women ≥50 yr | 5–10 yr | 2.06 | 0.77 to 5.53
Moorman, 2001^188^ | African-American women ≥50 yr | > 10 yr | 1.37 | 0.27 to 6.90
Marchbanks, 2002^183^ | | < 1 yr | 0.9 | 0.8 to 1.1
Marchbanks, 2002^183^ | | 1 to < 5 yr | 0.9 | 0.8 to 1.0
Marchbanks, 2002^183^ | | 5 to < 10 yr | 0.9 | 0.8 to 1.0
Marchbanks, 2002^183^ | | 10 to < 15 yr | 0.8 | 0.7 to 1.0
Narod, 2002^190^ | BRCA1 carriers | 0–4 yr | 1.10 | 0.92 to 1.31
Narod, 2002^190^ | BRCA1 carriers | 5–9 yr | 1.36 | 1.11 to 1.67
Narod, 2002^190^ | BRCA1 carriers | 10–14 yr | 1.27 | 0.99 to 1.64
Narod, 2002^190^ | BRCA1 carriers | 15–30 yr | 1.30 | 0.91 to 1.87
Narod, 2002^190^
Narod, 2002^190^ | BRCA2 carriers | 0–4 yr | 0.90 | 0.67 to 1.20
Narod, 2002^190^ | BRCA2 carriers | 5–9 yr | 0.82 | 0.56 to 1.91
Narod, 2002^190^ | BRCA2 carriers | 10–14 yr | 1.16 | 0.75 to 1.78
Narod, 2002^190^ | BRCA2 carriers | 15–30 yr | 1.35 | 0.71 to 2.56
Newcomer, 2003^193^ | Ductal carcinoma vs. controls | < 1 yr | 1.1 | 1.0 to 1.3
Newcomer, 2003^193^ | Ductal carcinoma vs. controls | 1–4 yr | 1.0 | 0.9 to 1.1
Newcomer, 2003^193^ | Ductal carcinoma vs. controls | 5–9 yr | 1.0 | 0.9 to 1.2
Newcomer, 2003^193^ | Ductal carcinoma vs. controls | 10–14 yr | 1.0 | 0.9 to 1.3
Newcomer, 2003^193^ | Ductal carcinoma vs. controls | > 15 yr | 1.0 | 0.7 to 1.3
Newcomer, 2003^193^
Newcomer, 2003^193^ | Lobular carcinoma vs. controls | < 1 yr | 1.4 | 1.0 to 2.0
Newcomer, 2003^193^ | Lobular carcinoma vs. controls | 1–4 yr | 1.1 | 0.8 to 1.6
Newcomer, 2003^193^ | Lobular carcinoma vs. controls | 5–9 yr | 1.1 | 0.7 to 1.7
Newcomer, 2003^193^ | Lobular carcinoma vs. controls | 10–14 yr | 1.1 | 0.7 to 1.9
Newcomer, 2003^193^ | Lobular carcinoma vs. controls | > 15 yr | 1.7 | 0.9 to 3.5
Norman, 2003^194^ | | < 0.5 yr | 0.73 | 0.5 to 1.05
Norman, 2003^194^ | | 0.5 to < 2 yr | 0.91 | 0.63 to 1.31
Norman, 2003^194^ | | 2 to < 5 yr | 0.83 | 0.56 to 1.22
Norman, 2003^194^ | | 5 to < 10 yr | 0.81 | 0.55 to 1.19
Norman, 2003^194^ | | > 10 yr | 0.62 | 0.41 to 0.95
Suter, 2003^195^ | | < 1 yr | 1.3 | 0.9 to 1.8
Suter, 2003^195^ | | 5 to <10 yr | 1.4 | 0.9 to 2.1
Suter, 2003^195^ | | > 10 yr | 1.2 | 0.7 to 1.8
Wrensch, 2003^228^ | | < 2 yr | 0.55 | 0,33 to 0.93
Wrensch, 2003^228^ | | 2-6 yr | 0.52 | 0.30 to 0.89
Wrensch, 2003^228^ | | 6-10 yr | 0.57 | 0.32 to 1.00
Wrensch, 2003^228^ | | >10 yr | 0.47 | 0.27 to 0.82
Dumeaux, 2005^218^ | | < 5 yr | 0.94 | 0.81 to 1.09
Dumeaux, 2005^218^ | | 5–9 yr | 0.91 | 0.75 to 1.11
Dumeaux, 2005^218^ | | > 10 yr | 0.87 | 0.72 to 1.06
Milne, 2005^198^ | BRCA1 carriers | 1–4 yr | 0.25 | 0.09 to 0.70
Milne, 2005^198^ | BRCA1 carriers | 5–9 yr | 0.22 | 0.09 to 0.58
Milne, 2005^198^ | BRCA1 carriers | > 10 yr | 0.20 | 0.08 to 0.54
Milne, 2005^198^
Milne, 2005^198^ | BRCA2 carriers | 1–4 yr | 0.97 | 0.26 to 3.56
Milne, 2005^198^ | BRCA2 carriers | 5–9 yr | 1.34 | 0.41 to 4.45
Milne, 2005^198^ | BRCA2 carriers | > 10 yr | 0.73 | 0.20 to 2.65
Milne, 2005^198^
Milne, 2005^198^ | Noncarriers | 1–4 yr | 0.76 | 0.54 to 1.07
Milne, 2005^198^ | Noncarriers | 5–9 yr | 0.97 | 0.70 to 1.34
Milne, 2005^198^ | Noncarriers | > 10 yr | 1.02 | 0.74 to 1.41
Gronwald, 2006^94^ | | < 2 yr | 0.9 | 0.5 to 1.2
Gronwald, 2006^94^ | | ≥ 2 yr | 0.8 | 0.5 to 1.4
Haile, 2006^199^ | BRCA1 carriers | 1–4 yr | 0.61 | 0.31 to 1.17
Haile, 2006^199^ | BRCA1 carriers | ≥ 5 | 0.61 | 0.32 to 1.16
Haile, 2006^199^
Haile, 2006^199^ | BRCA2 carriers | 1–4 yr | 0.79 | 0.26 to 2.37
Haile, 2006^199^ | BRCA2 carriers | ≥ 5 yr | 1.45 | 0.64 to 3.27
Ma, 2006^201^ | | < 1 yr | 0.78 | 0.51 to 1.18
Ma, 2006^201^ | | 1–4 yr | 0.80 | 0.54 to 1.19
Ma, 2006^201^ | | 5–9 yr | 0.62 | 0.42 to 0.93
Ma, 2006^201^ | | > 10 yr | 0.84 | 0.56 to 1.26
Rosenberg, 2006^200^ | Ductal breast cancer | < 5 yr | 0.9 | 0.7 to 1.0
Rosenberg, 2006^200^ | Ductal breast cancer | > 5 yr | 0.9 | 0.7 to 1.1
Rosenberg, 2006^200^
Rosenberg, 2006^200^ | Lobular cancer | < 5 yr | 0.6 | 0.4 to 0.9
Rosenberg, 2006^200^ | Lobular cancer | > 5 yr | 0.9 | 0.6 to 1.4
Rosenberg, 2006^200^
Rosenberg, 2006^200^ | Tubular cancer | < 5 yr | 1.3 | 0.7 to 2.2
Rosenberg, 2006^200^ | Tubular cancer | > 5 yr | 1.0 | 0.5 to 1.9
Folger, 2007^203^ | Premenopausal | < 6 mo | 1.3 | 0.60 to 1.0
Folger, 2007^203^
Folger, 2007^203^ | Postmenopausal | < 6 mo | 0.8 | 0.60 to 1.28
Nichols, 2007^204^ | | 1–1.9 yr | 1.13 | 0.96 to 1.33
Nichols, 2007^204^ | | 2–2.4 yr | 1.22 | 1.04 to 1.44
Nichols, 2007^204^ | | 4.5–8.9 yr | 1.04 | 0.86 to 1.25
Nichols, 2007^204^ | | > 9 yr | 1.06 | 0.88 to 1.27
Shantakumar, 2007^205^ | Premenopausal women | < 6 mo | 1.31 | 0.68 to 2.55
Shantakumar, 2007^205^ | Premenopausal women | 6–12 mo | 1.38 | 0.93 to 2.03
Shantakumar, 2007^205^ | Premenopausal women | 13–60 mo | 1.27 | 0.90 to 1.79
Shantakumar, 2007^205^ | Premenopausal women | > 60 mo | 1.54 | 1.06 to 2.24
Shantakumar, 2007^205^
Shantakumar, 2007^205^ | Postmenopausal <65 yr | < 6 mo | 1.52 | 0.77 to 3.03
Shantakumar, 2007^205^ | Postmenopausal <65 yr | 6–12 mo | 0.78 | 0.53 to 1.16
Shantakumar, 2007^205^ | Postmenopausal <65 yr | 13–60 mo | 0.88 | 0.60 to 1.28
Shantakumar, 2007^205^ | Postmenopausal <65 yr | > 60 mo | 1.01 | 0.69 to 1.48
Shantakumar, 2007^205^
Shantakumar, 2007^205^ | Postmenopausal >65 yr | < 6 mo | 0.93 | 0.23 to 3.77
Shantakumar, 2007^205^ | Postmenopausal >65 yr | 6–12 mo | 0.51 | 0.27 to 0.95
Shantakumar, 2007^205^ | Postmenopausal >65 yr | 13–60 mo | 1.15 | 0.58 to 2.31
Shantakumar, 2007^205^ | Postmenopausal >65 yr | > 60 mo | 0.86 | 0.44 to 1.66
Sweeney, 2007^206^ | Hispanics only | < 5 yr | 1.14 | 0.87 to 1.49
Sweeney, 2007^206^ | Hispanics only | 5–9 yr | 1.06 | 0.77 to 1.46
Sweeney, 2007^206^ | Hispanics only | 10–19 yr | 1.03 | 0.74 to 1.43
Sweeney, 2007^206^ | Hispanics only | > 20 yr | 1.43 | 0.69 to 2.95
Sweeney, 2007^206^
Sweeney, 2007^206^ | Non-Hispanic whites | < 5 yr | 1.14 | 0.93 to 1.40
Sweeney, 2007^206^ | Non-Hispanic whites | 5–9 yr | 0.99 | 0.78 to 1.25
Sweeney, 2007^206^ | Non-Hispanic whites | 10–19 yr | 0.96 | 0.75 to 1.23
Sweeney, 2007^206^ | Non-Hispanic whites | > 20 yr | 1.49 | 0.96 to 2.30
Figueiredo, 2008^207^ | | < 5 yr | 0.88 | 0.65 to 1.20
Figueiredo, 2008^207^ | | ≥ 5 yr | 0.82 | 0.61 to 1.10
Lee, 2008^208^ | BRCA1/2 carriers | < 4 yr | 0.65 | 0.30 to 1.42
Lee, 2008^208^ | BRCA1/2 carriers | 5–9 yr | 0.78 | 0.34 to 1.77
Lee, 2008^208^ | BRCA1/2 carriers | ≥ 10 yr | 0.63 | 0.26 to 1.51
Lee, 2008^208^
Lee, 2008^208^ | Noncarriers | ≤ 4 yr | 0.80 | 0.55 to 1.16
Lee, 2008^208^ | Noncarriers | 5–9 yr | 0.66 | 0.45 to 0.98
Lee, 2008^208^ | Noncarriers | ≥ 10 yr | 0.95 | 0.64 to 1.42
Nyante, 2008^209^ | Ductal carcinoma | < 1 yr | 1.13 | 0.80 to 1.61
Nyante, 2008^209^ | Ductal carcinoma | 1–3 yr | 1.11 | 0.89 to 1.38
Nyante, 2008^209^ | Ductal carcinoma | > 4 yr | 1.30 | 1.06 to 1.59
Nyante, 2008^209^
Nyante, 2008^209^ | Lobular breast carcinoma | < 1 yr | 1.63 | 0.72 to 3.65
Nyante, 2008^209^ | Lobular breast carcinoma | 1–3 yr | 1.23 | 0.70 to 2.14
Nyante, 2008^209^ | Lobular breast carcinoma | > 4 yr | 0.92 | 0.53 to 1.59
Phillips, 2009^211^ | Invasive breast carcinoma | < 5 yr | 1.06 | 0.88 to 1.28
Phillips, 2009^211^ | Invasive breast carcinoma | 5–10 yr | 1.15 | 0.93 to 1.42
Phillips, 2009^211^ | Invasive breast carcinoma | > 10 yr | 1.21 | 0.94 to 1.56
Phillips, 2009^211^
Phillips, 2009^211^ | DCIS | < 5 yr | 0.75 | 0.49 to 1.15
Phillips, 2009^211^ | DCIS | 5–10 yr | 1.27 | 0.79 to 2.04
Phillips, 2009^211^ | DCIS | > 10 yr | 0.94 | 0.59 to 1.49
Rosenberg, 2009^210^ | All invasive breast cancers | 1–4 yr | 1.3 | 1.0 to 1.6
Rosenberg, 2009^210^ | All invasive breast cancers | 5–9 yr | 1.6 | 1.2 to 2.1
Rosenberg, 2009^210^ | All invasive breast cancers | 10–14 yr | 1.9 | 1.4 to 2.7
Rosenberg, 2009^210^ | All invasive breast cancers | > 15 yr | 1.7 | 1.0 to 2.9
Rosenberg, 2009^210^
Rosenberg, 2009^210^ | Women <50 yr | 1–4 yr | 1.3 | 1.0 to 1.8
Rosenberg, 2009^210^ | Women <50 yr | 5–9 yr | 1.9 | 1.3 to 2.7
Rosenberg, 2009^210^ | Women <50 yr | 10–14 yr | 1.8 | 1.1 to 2.8
Rosenberg, 2009^210^ | Women <50 yr | > 15 yr | 1.3 | 0.6 to 2.7
Rosenberg, 2009^210^
Rosenberg, 2009^210^ | Women >50 yr | 1–4 yr | 1.3 | 0.9 to 1.8
Rosenberg, 2009^210^ | Women >50 yr | 5–9 yr | 1.3 | 0.8 to 2.0
Rosenberg, 2009^210^ | Women >50 yr | 10–14 yr | 2.0 | 1.2 to 3.5
Rosenberg, 2009^210^ | Women >50 yr | > 15 yr | 2.4 | 1.0 to 5.5
Rosenberg, 2009^210^
Rosenberg, 2009^210^ | Black women | 1–4 yr | 1.3 | 0.8 to 2.1
Rosenberg, 2009^210^ | Black women | 5–9 yr | 2.3 | 1.3 to 3.9
Rosenberg, 2009^210^ | Black women | 10–14 yr | 2.5 | 1.3 to 4.7
Rosenberg, 2009^210^ | Black women | > 15 yr | NR | NR
Rosenberg, 2009^210^
Rosenberg, 2009^210^ | White women | 1–4 yr | 1.3 | 1.0 to 1.7
Rosenberg, 2009^210^ | White women | 5–9 yr | 1.4 | 1.0 to 1.9
Rosenberg, 2009^210^ | White women | 10–14 yr | 1.8 | 1.2 to 2.5
Rosenberg, 2009^210^ | White women | > 15 yr | 1.4 | 0.8 to 2.6
Figueiredo, 2010^212^ | BRCA1 carriers | < 5 yr | 2.91 | 0.75 to 11.30
Figueiredo, 2010^212^ | BRCA1 carriers | ≥ 5 yr | 2.07 | 0.60 to 7.11
Figueiredo, 2010^212^
Figueiredo, 2010^212^ | BRCA2 carriers | < 5 yr | 0.86 | 0.21 to 3.57
Figueiredo, 2010^212^ | BRCA2 carriers | ≥ 5 yr | 2.02 | 0.52 to 7.81
Ma, 2010^214^ | Triple-negative breast cancer | < 1 yr | 0.94 | 0.63 to 1.42
Ma, 2010^214^ | Triple-negative breast cancer | 1–4 yr | 0.93 | 0.63 to 1.36
Ma, 2010^214^ | Triple-negative breast cancer | 5–9 yr | 1.12 | 0.75 to 1.66
Ma, 2010^214^ | Triple-negative breast cancer | ≥ 10 yr | 1.06 | 0.70 to 1.61
Ma, 2010^214^
Ma, 2010^214^ | ER-/PR-/HER2+ breast cancer | < 1 yr | 1.22 | 0.61 to 2.43
Ma, 2010^214^ | ER-/PR-/HER2+ breast cancer | 1–4 yr | 1.15 | 0.59 to 2.23
Ma, 2010^214^ | ER-/PR-/HER2+ breast cancer | 5–9 yr | 0.86 | 0.40 to 1.85
Ma, 2010^214^ | ER-/PR-/HER2+ breast cancer | ≥ 10 yr | 1.59 | 0.81 to 3.10
Ma, 2010^214^
Ma, 2010^214^ | Luminal A breast cancer | < 1 yr | 0.98 | 0.73 to 1.32
Ma, 2010^214^ | Luminal A breast cancer | 1–4 yr | 1.04 | 0.79 to 1.37
Ma, 2010^214^ | Luminal A breast cancer | 5–9 yr | 0.78 | 0.57 to 1.06
Ma, 2010^214^ | Luminal A breast cancer | ≥ 10 yr | 0.87 | 0.63 to 1.19
Ma, 2010^214^
Ma, 2010^214^ | Luminal B breast cancer | < 1 yr | 1.17 | 0.62 to 2.24
Ma, 2010^214^ | Luminal B breast cancer | 1–4 yr | 1.12 | 0.60 to 2.07
Ma, 2010^214^ | Luminal B breast cancer | 5–9 yr | 1.50 | 1.80 to 2.78
Ma, 2010^214^ | Luminal B breast cancer | ≥ 10 yr | 1.20 | 0.62 to 2.32
Xu, 2011^224^ | | < 18 months | 0.96 | 0.78 to 1.18
Xu, 2011^224^ | | ≥ 18 months | 1.11 | 0.89 to 1.37
Marchbanks, 2012^226^ | 100 mcg mestranol/1.0 mg ethynodiol diacetate | < 2 yr | 0.8 | 0.4 to 1.5
Marchbanks, 2012^226^ | 100 mcg mestranol/1.0 mg ethynodiol diacetate | ≥ 2 yr | 0.8 | 0.5 to 1.1
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 35 mcg ethinyl estradiol/0.5 mg norethindrone | < 2 yr | 1.2 | 0.7 to 2.0
Marchbanks, 2012^226^ | 35 mcg ethinyl estradiol/0.5 mg norethindrone | ≥ 2 yr | 1.2 | 0.6 to 1.4
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 35 mcg ethinyl estradiol/1.0 mg norethindrone | < 2 yr | 0.9 | 0.6 to 1.4
Marchbanks, 2012^226^ | 35 mcg ethinyl estradiol/1.0 mg norethindrone | ≥ 2 yr | 1.0 | 0.8 to 1.4
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 50 mcg mestranol/1.0 mg norethindrone | < 2 yr | 0.8 | 0.5 to 1.2
Marchbanks, 2012^226^ | 50 mcg mestranol/1.0 mg norethindrone | ≥ 2 yr | 0.8 | 0.6 to 1.1
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 80 mcg mestranol/1.0 mg norethindrone | < 2 yr | 0.6 | 0.4 to 0.99
Marchbanks, 2012^226^ | 80 mcg mestranol/1.0 mg norethindrone | ≥ 2 yr | 0.8 | 0.6 to 1.0
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 100 mcg mestranol/2.0 mg norethindrone | < 2 yr | 1.1 | 0.7 to 1.6
Marchbanks, 2012^226^ | 100 mcg mestranol/2.0 mg norethindrone | ≥ 2 yr | 0.7 | 0.5 to 0.9
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 100 mcg mestranol/2.5 mg norethindrone | < 2 yr | 0.8 | 0.4 to 1.4
Marchbanks, 2012^226^ | 100 mcg mestranol/2.5 mg norethindrone | ≥ 2 yr | 1.0 | 0.6 to 1.7
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 30 mcg ethinyl estradiol/0.3 mg norgestrel | < 2 yr | 1.5 | 0.9 to 2.6
Marchbanks, 2012^226^ | 30 mcg ethinyl estradiol/0.3 mg norgestrel | ≥ 2 yr | 0.8 | 0.5 to 1.1
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 50 mcg ethinyl estradiol/0.5 mg norgestrel | < 2 yr | 1.1 | 0.6 to 2.0
Marchbanks, 2012^226^ | 50 mcg ethinyl estradiol/0.5 mg norgestrel | ≥ 2 yr | 0.6 | 0.4 to 0.98
Marchbanks, 2012^226^
Marchbanks, 2012^226^ | 35 mcg ethinyl estradiol/0.5 mg (7 days), 0.75 mg (7 days), 1.0 mg (7 days) norethindrone | < 2 yr | 0.5 | 0.2 to 1.4
Marchbanks, 2012^226^ | 35 mcg ethinyl estradiol/0.5 mg (7 days), 0.75 mg (7 days), 1.0 mg (7 days) norethindrone | ≥ 2 yr | 0.4 | 0.2 to 0.8
Cohort
Grabrick, 2000^215^ | | 1–4 yr | 1.5 | 1.0 to 2.3
Grabrick, 2000^215^ | | > 4 yr | 1.3 | 0.9 to 1.9
Kumle, 2002^216^ | | < 5 yr | 1.2 | 1.0 to 1.5
Kumle, 2002^216^ | | 5–9 yr | 1.2 | 1.0 to 1.5
Kumle, 2002^216^ | | 10–14 yr | 1.4 | 1.1 to 1.8
Kumle, 2002^216^ | | > 15 yr | 1.3 | 1.0 to 1.8
Dumeaux, 2003^217^ | | 0–4 yr | 0.94 | 0.81 to 1.09
Dumeaux, 2003^217^ | | 5–9 yr | 0.91 | 0.75 to 1.11
Dumeaux, 2003^217^ | | > 10 yr | 0.87 | 0.72 to 1.06
Silvera, 2005^219^ | Women with any family history of breast cancer | 1–12 mo | 1.05 | 0.79 to 1.42
Silvera, 2005^219^ | Women with any family history of breast cancer | 12–36 mo | 0.94 | 0.70 to 1.26
Silvera, 2005^219^ | Women with any family history of breast cancer | 36–84 mo | 0.85 | 0.64 to 1.12
Silvera, 2005^219^ | Women with any family history of breast cancer | > 84 mo | 0.74 | 0.55 to 0.99
Silvera, 2005^219^
Silvera, 2005^219^ | Women with first-degree relatives of breast cancer | 1–12 mo | 1.18 | 0.75 to 1.38
Silvera, 2005^219^ | Women with first-degree relatives of breast cancer | 12–36 mo | 1.24 | 0.82 to 1.88
Silvera, 2005^219^ | Women with first-degree relatives of breast cancer | 36–84 mo | 1.07 | 0.72 to 1.59
Silvera, 2005^219^ | Women with first-degree relatives of breast cancer | > 84 mo | 0.75 | 0.47 to 1.19
Silvera, 2005^219^
Silvera, 2005^219^ | Women with second-degree relatives with breast cancer | 1–12 mo | 0.92 | 0.58 to 1.44
Silvera, 2005^219^ | Women with second-degree relatives with breast cancer | 12–36 mo | 0.72 | 0.45 to 1.17
Silvera, 2005^219^ | Women with second-degree relatives with breast cancer | 36–84 mo | 0.52 | 0.32 to 0.84
Silvera, 2005^219^ | Women with second-degree relatives with breast cancer | > 84 mo | 0.84 | 0.55 to 1.27
Vessey, 2006^156^ | | < 48 mo | 0.9 | 0.8 to 1.1
Vessey, 2006^156^ | | 49–96 mo | 0.9 | 0.8 to 1.1
Vessey, 2006^156^ | | > 97 mo | 1.0 | 0.8 to 1.1
Brohet, 2007^220^ | | 1–3 yr | 1.34 | 1.00 to 2.78
Brohet, 2007^220^ | | 4–8 yr | 1.59 | 1.19 to 2.13
Brohet, 2007^220^ | | > 9 yr | 1.61 | 1.18 to 2.20
Hannaford, 2007^37^ | | < 48 mo | 1.00 | 0.81 to 1.23
Hannaford, 2007^37^ | | 49–96 mo | 0.95 | 0.75 to 1.21
Hannaford, 2007^37^ | | > 96 mo | 1.22 | 0.97 to 1.52
Dorjgochoo, 2009^88^ | | < 2 yr | 1.18 | 0.89 to 1.56
Dorjgochoo, 2009^88^ | | > 2 yr | 0.93 | 0.68 to 1.25
Rosenblatt, 2009^138^ | | 1–11 mo | 0.71 | 0.56 to 0.90
Rosenblatt, 2009^138^ | | 12–59 mo | 1.04 | 0.86 to 1.27
Rosenblatt, 2009^138^ | | 60–119 mo | 0.97 | 0.69 to 1.36
Rosenblatt, 2009^138^ | | > 120 mo | 0.94 | 0.66 to 1.32
Hannaford, 2010^33^ | | < 4 yr | 0.92 | 0.64 to 1.34
Hannaford, 2010^33^ | | 4–8 yr | 0.87 | 0.58 to 1.31
Hannaford, 2010^33^ | | > 8 yr | 1.13 | 0.75 to 1.70
Hunter, 2010^222^ | | 0–8 yr | 1.16 | 0.80 to 1.69
Hunter, 2010^222^ | | > 8 yr | 1.42 | 1.05 to 1.94
Rosenberg, 2010^223^ | ER+/PR+ breast cancers | < 5 yr | 1.03 | 0.79 to 1.35
Rosenberg, 2010^223^ | ER+/PR+ breast cancers | 5–9 yr | 1.09 | 0.78 to 1.52
Rosenberg, 2010^223^ | ER+/PR+ breast cancers | 10–14 yr | 1.45 | 1.02 to 2.07
Rosenberg, 2010^223^ | ER+/PR+ breast cancers | > 15 yr | 1.24 | 0.74 to 2.09
Rosenberg, 2010^223^
Rosenberg, 2010^223^ | ER-/PR- breast cancers | < 5 yr | 1.67 | 1.18 to 2.36
Rosenberg, 2010^223^ | ER-/PR- breast cancers | 5–9 yr | 1.37 | 0.89 to 2.11
Rosenberg, 2010^223^ | ER-/PR- breast cancers | 10–14 yr | 1.83 | 1.11 to 2.90
Rosenberg, 2010^223^ | ER-/PR- breast cancers | > 15 yr | 2.25 | 1.23 to 4.11
Rosenberg, 2010^223^
Rosenberg, 2010^223^ | ER+/PR- breast cancer | < 5 yr | 0.91 | 0.55 to 1.49
Rosenberg, 2010^223^ | ER+/PR- breast cancer | 5–9 yr | 1.31 | 0.74 to 2.33
Rosenberg, 2010^223^ | ER+/PR- breast cancer | 10–14 yr | 0.82 | 0.37 to 1.78
Rosenberg, 2010^223^ | ER+/PR- breast cancer | > 15 yr | 0.75 | 0.22 to 2.54
Pooled
Dolle, 2009^184^ | All subjects | 1–2 yr | 1.3 | 0.9 to1.7
Dolle, 2009^184^ | All subjects | 3–5 yr | 1.4 | 1.0 to 2.0
Dolle, 2009^184^ | All subjects | > 6 yr | 1.3 | 1.0 to1.8
Dolle, 2009^184^
Dolle, 2009^184^ | Women with triple-negative breast cancer | 1–2 yr | 1.6 | 0.9 to 3.3
Dolle, 2009^184^ | Women with triple-negative breast cancer | 3–5 yr | 2.8 | 1.5 to 5.3
Dolle, 2009^184^ | Women with triple-negative breast cancer | > 6 yr | 2.9 | 1.6 to 5.3

BRCA = breast cancer genetic mutation; CI = confidence interval; ER = estrogen receptor; mo = month/months; NR = not reported; OR = odds ratio; PR = progesterone receptor; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

As described in the Methods section, we categorized duration of OC use in the included studies into four intervals: (1) 1 to 12 months, (2) 13 to 60 months, (3) 61 to 120 months, and (4) more than 120 months. These results, summarized in Table 20, show no time-dependent relationship as a function of duration of use. There was significant heterogeneity, with a t-value of 5.84 for 19 degrees of freedom, p<0.0001. However, the test was underpowered; there would have to be a 40-percent difference in risk of breast cancer by time period in order to detect significant differences.

Table 20 Estimated odds ratios by duration of OC use (breast cancer incidence)

Duration Interval | Odds Ratio (95% Confidence Interval) | P-Value
0–12 months | 0.95 (0.83 to 1.09) | 0.465
13–60 months | 1.03 (0.92 to 1.15) | 0.644
61–120 months | 1.01 (0.90 to 1.13) | 0.895
>120 months | 1.04 (0.93 to 1.17) | 0.457

#### Time Since Last OC Use

Eleven studies183,185,188,191,195,196,203,206,208,210,216,218 were included in this meta-analysis examining the effect of time since last OC use on breast cancer incidence. Of these, 9 were case-control studies and 2 cohort studies. Five studies were rated good quality and seven fair quality. We did not include data in the meta-analysis for studies that only reported time since last use data for a special population, did not have at least three categories for duration of use, or used a referent category other than never users.

As described in the Methods, we categorized time since last OC use into four intervals: (1) 0 to 5 years, (2) 5 to 10 years (3) 10 to 20 years, (4) more than 20 years. These results, summarized in Table 21, show a time-dependent relationship as a function of time since last OC use, with higher risk associated with more recent use of OCs and the odds ratio approaching 1 (no effect) by 20+ years of use. There was significant heterogeneity. The estimated value of σ is 0.12. The t-value is 4.95 for 11 degrees of freedom, p=0.0004.

Table 21 Estimated odds ratios by time since last OC use (breast cancer incidence)

Time Interval | Odds Ratio (95% Confidence Interval) | P-Value
0–5 years | 1.21 (1.04 to 1.41) | 0.0178
5–10 years | 1.17 (0.98 to 1.38 ) | 0.0776
10–20 years | 1.13 (0.97 to 1.31) | 0.1705
>20 years | 1.02 (0.88 to 1.18) | 0.7686

We also fitted a model to the individual reported odds ratios. The time (in years) was assumed to be the middle of the interval reported. The fitted model was odds ratio equals (1 + 0.2711 * EXP(-0.06551 * years) (Figure 25). The slope was significant, with a chi-square of 4.8 for 1 degree of freedom, p=0.0285. The model produced a slightly better fit than did the individual odds ratios in Table 21 and show a time-dependent relationship.

Figure 25 Estimated and model-fitted odds ratios for time since last OC use (breast cancer incidence)

OR = odds ratio

Description: Figure 25 shows a model fitted to the individual reported odds ratios. The time (in years) was assumed to be the middle of the interval reported. The fitted model was odds ratio equals (1 + 0.2711 * EXP(-0.06551 * years).

#### Special Populations

##### BRCA Mutation Carriers

We identified eight studies that were conducted with women who were BRCA1 or BRCA2 carriers.94,190,198,199,208,212,220,225 Five BRCA1/2 carrier studies representing 4555 women across 4 studies and 65,180 person-years in 1 study assessed the risk of breast cancer as a function of OC use comparing BRCA carriers with each other and were included in a meta-analysis.94,190,199,220,225 Three were case-control studies and two cohort studies; one was rated good quality and four fair quality. Two additional studies198,208 examined the risk of breast cancer incidence in OC users among carriers of the BRCA mutation compared with control groups who were noncarriers, and one report212 was conducted with BRCA carriers with either bilateral (cases) or unilateral (controls) cancers. Data from these three articles were not included in this meta-analysis.

Figure 26 shows pooled results indicating a slight, but not significant, increase in the risk of breast cancer among BRCA carriers who have ever used OCs, with an odds ratio of 1.21 (95% CI, 0.93 to 1.58). There was evidence of heterogeneity, with a Q-value of 20.005 for 4 degrees of freedom, p<0.001.

Figure 26 Forest plot for BRCA carriers compared with each other (breast cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 26 shows pooled results indicating a slight, but not significant, increase in the risk of breast cancer among BRCA carriers who have ever used OCs, with an odds ratio of 1.21 (95% CI, 0.93 to 1.58).

##### Family History of Breast Cancer

We identified one case-control study189 and two cohort studies215,219 that assessed the risk of breast cancer among OC users with family histories of breast cancer, but these studies could not be pooled due to differences in study design and comparisons (Table 22). Of these studies, two were rated good quality and one fair quality. Overall, study results were mixed, possibly due to variation in how family history was defined across studies. One study215 recruited first-degree, second-degree, and marry-in relatives of patients with breast cancer. Overall, this study found a significant increase in breast cancer for ever use (risk ratio [RR] 1.4; 95% CI, 1.0 to 2.0). This effect was greater among sisters and daughters (RR 3.3; CI, 1.6 to 6.7) but not among granddaughters and nieces of the affected family member (RR 1.2; CI, 0.8 to 2.0).

Table 22 Family history and association between OC use and breast cancer incidence

Study^a^ | Study Details | Definition of Family History | OR | 95% CI | Region | Study Quality
Case-Control
Heimdal, 2002^189^ | Women aged 40–60 yr [underlined: Cases]: 380 [underlined: Controls]: 1043 | First-degree family member | 0.90 | 0.68 to 1.19 | Norway | Fair
Cohort
Grabrick, 2000^215^ | Family members of women aged 21–88 yr [underlined: Exposed]: 3156 [underlined: Unexposed]: 2994 | First-degree, second-degree, or marry-in family member | 1.4 | 1.0 to 2.0 | U.S. | Good
Silvera, 2005^219^ | Women aged 40–59 yr | First-degree or second-degree family member | | | Canada | Good
Silvera, 2005^219^ | [underlined: Exposed]: 962 [underlined: Unexposed]: 745 | First-degree or second-degree family member | 0.88 | 0.73 to 1.07 | Canada | Good
Silvera, 2005^219^ | Women with first-degree relatives [underlined: Exposed]: 433 [underlined: Unexposed]: 362 | First-degree or second-degree family member | 1.03 | 0.78 to 1.38 | Canada | Good
Silvera, 2005^219^ | Women with second-degree relatives [underlined: Exposed]: 414 [underlined: Unexposed]: 284 | First-degree or second-degree family member | 0.74 | 0.54 to 1.00 | Canada | Good

CI = confidence interval; OC = oral contraceptive; OR = odds ratio; U.S. = United States; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

Another study189 identified breast cancer families. A breast cancer family was defined as four cases of breast cancer (at any age), two breast cancer cases younger than 55 years of age, one case younger than 50 years, or a combination of breast cancer younger than 60 years of age and ovarian cancer (at any age) in a family. First-degree family members of affected women 40 to 60 years of age made up the pool of subjects for cases and controls. OC use was not associated with an increase in breast cancer (RR 0.90; 95% CI, 0.68 to 1.18). However, among BRCA1 mutation carriers, risk of breast cancer was associated with OC use, but the test was not significant (RR 2.00; CI, 0.36 to 10.9).

Another study219 recruited women with either a first-degree or second-degree family member with breast cancer. OC use was associated with a reduction in risk of breast cancer among all women with breast cancer (hazard ratio [HR], 0.88; 95% CI, 0.73 to 1.07). However, among first-degree relatives, OC use did not reduce the risk of breast cancer (HR, 1.03; CI, 0.78 to 1.38). Among second-degree relatives, a protective effect for OC use was observed, but the comparison was not significant (HR, 0.74; CI, 0.54 to 1.00). This study highlights the heterogeneity of effects associated with multiple definitions of family history of breast cancer.

##### Breast Cancer in Younger Women

Three case-control studies197,198,209 assessed the risk of breast cancer among younger women, defined as under 45 years of age at time of diagnosis (Table 18). Of these studies, one was good quality and two fair quality; all were conducted in Western countries. We were not able to quantitatively synthesize studies because one study was conducted in a special population209 leaving only two studies. No clear pattern emerged from these studies. One study conducted among women with either ductal or lobular carcinomas209 reported a significant increase in the odds of breast cancer among younger women who had ever used OCs (OR 1.21; 95% CI, 1.01 to 1.45). Two studies not conduced among special populations197,198 did not find significant effects for ever use of OCs on risk of breast cancer (OR 1.65; 95% CI, 0.95 to 1.45^197^ and OR 0.93; 95% CI, 0.69 to 1.24^198^).

##### Specific Types of Breast Cancers

Three case-control studies,204,207,214, one cohort study,223 and one pooled analysis184 reported on associations between OCs and specific subtypes of breast cancer. Study characteristic and results of ever versus never use are presented in Table 23.

Table 23 Breast cancer subtype and association between OC use and breast cancer incidence

Study^a^ | Study Details | Subtype of Breast Cancer | OR | 95% CI | Region | Study Quality
Case-Control
Nichols, 2007^204^ | Women aged 20–74 yr in Collaborative Breast Cancer Study [underlined: Cases]: 1878 [underlined: Controls]: 8041 Recruitment period: 1997–2001 | Breast cancer in situ | 1.10 | 0.99 to 1.25 | U.S. | Good
Figueiredo, 2008^207^ | Women <55 yr in Women's Environment, and Radiation Epidemiology Study [underlined: Cases]: 708 asynchronous bilateral breast cancer [underlined: Controls]: 1399 unilateral breast cancer only Recruitment period: 1985–2000 | Unilateral or bilateral breast cancer | 0.88 | 0.67 to 1.16 | U.S. | Fair
Ma, 2010^214^ | White or African-American women aged 35–64 yr [underlined: Cases]: 335 triple-negative breast cancer, registries [underlined: Controls]: 2015, community | Triple-negative, luminal A, luminal B, or ER-/PR-/HER2+ breast cancers | 0.93 | 0.74 to 1.17 | U.S. | Good
Ma, 2010^214^ | [underlined: Cases]: 97 ER-/PR/HER2+ breast cancer, registries [underlined: Controls]: 2015, community | Triple-negative, luminal A, luminal B, or ER-/PR-/HER2+ breast cancers | 1.00 | 0.72 to 1.39 | U.S. | Good
Ma, 2010^214^ | [underlined: Cases]: 645 luminal A breast cancer, registries [underlined: Controls]: 2015, community | Triple-negative, luminal A, luminal B, or ER-/PR-/HER2+ breast cancers | 1.21 | 0.69 to 2.11 | U.S. | Good
Ma, 2010^214^ | [underlined: Cases]: 120 luminal B breast cancer, registries [underlined: Controls]: 2015, community | Triple-negative, luminal A, luminal B, or ER-/PR-/HER2+ breast cancers | 1.23 | 0.73 to 2.10 | U.S. | Good
Ma, 2010^214^ | Recruitment period: 2000–2003 | Triple-negative, luminal A, luminal B, or ER-/PR-/HER2+ breast cancers | | | U.S. | Good
Cohort
Rosenberg, 2010^223^ | Women aged 21–69 yr in Black Women's Health Study [underlined: Exposed]: 445,824 person-years [underlined: Unexposed]: 128,768 person-years | ER/PR receptor status breast cancers | IRR=1.11 IRR=0.97 IRR=1.65 | 0.86 to 1.42 0.61 to 1.54 1.19 to 2.30 | U.S. | Fair
Rosenberg, 2010^223^ | ER+/PR+ receptor status [underlined: Cases]: 284 | ER/PR receptor status breast cancers | IRR=1.11 IRR=0.97 IRR=1.65 | 0.86 to 1.42 0.61 to 1.54 1.19 to 2.30 | U.S. | Fair
Rosenberg, 2010^223^ | ER+/PR- receptor status [underlined: Cases]: 80 | ER/PR receptor status breast cancers | IRR=1.11 IRR=0.97 IRR=1.65 | 0.86 to 1.42 0.61 to 1.54 1.19 to 2.30 | U.S. | Fair
Rosenberg, 2010^223^ | ER-/PR- receptor status [underlined: Cases]: 46 | ER/PR receptor status breast cancers | IRR=1.11 IRR=0.97 IRR=1.65 | 0.86 to 1.42 0.61 to 1.54 1.19 to 2.30 | U.S. | Fair
Rosenberg, 2010^223^ | Recruitment period: 1995 | ER/PR receptor status breast cancers | IRR=1.11 IRR=0.97 IRR=1.65 | 0.86 to 1.42 0.61 to 1.54 1.19 to 2.30 | U.S. | Fair
Pooled
Dolle, 2009^184^ | Women aged 21–45 yr in Seattle-Puget Sound [underlined: Cases:] 187 [underlined: Controls:] 1569 Recruitment periods: 1983–1990; 1990–1992 | Triple-negative breast cancers | 2.5 | 1.4 to 4.3 | U.S. | Fair

CI = confidence interval; ER = estrogen receptor; HER = human epidermal growth factor receptor; IRR = incidence rate ratio; OC = oral contraceptive; OR = odds ratio; PR = progesterone receptor; U.S. = United States; yr=year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

Three studies184,214,223 assessed the risk of breast cancer subtypes defined by tumor hormone receptor protein expression status; i.e., estrogen receptor (ER), progesterone receptor, (PR) and human epidermal growth factor (HER2) protein expression or gene amplification. Differences in populations and methods precluded pooling studies. Overall, the two case-control studied did not demonstrate a statistically significant increase in the risk of these cancers associated with OC use. However, pooled analyses reported a significantly higher odds of triple-negative breast cancer associated with OC use. Doole also reported that fewer years since last use and longer use of OCs significantly increased the risk of triple-negative breast cancers.

Two other studies204,207 assessed the association of OC use and breast cancer subtypes not categorized by ER, PR, or HER2 status. One study207 compared women in the United States with asynchronous bilateral breast cancer (cases) to women with unilateral breast cancer (controls) and found no significant association. One study204 compared healthy community-based controls to women with cancer in situ 20 to 74 years of age. Similar to population studies of invasive breast cancer, this study found a small and significant increase in breast cancer in situ.

### OC Use and Breast Cancer Mortality

We identified six studies;33,164-166,229-232 all six were cohort studies, and of these, three were rated good quality and three fair quality (Table 24). Three studies were based in the United States,229,231,232 and the remaining studies were conducted in the United Kingdom.33,165,230

Table 24 Study characteristics and association between OC use and breast cancer mortality

Study^a^ | Study Details | OR^b^ | 95% CI | Covariates | Region | Study Quality
Cohort
Postdiagnosis Survival
Trivers, 2007^231^ | Women aged 20–54 yr with invasive breast cancer [underlined: Exposed]: 897 [underlined: Unexposed]: 367 Recruitment period: 1990–1992 | 1.00 | 0.77 to 1.29 | Age, income | U.S. | Good
Wingo, 2007^229^ | Women aged 20–54 yr in Cancer and Steroid Hormone Study [underlined: Exposed]: 2237 [underlined: Unexposed]: 1679 Recruitment period: 1980–1982 | 0.94 | 0.83 to 1.06 | Age, race, menopausal status, BMI, education, income, time since last birth, use of HRT, radiation therapy | U.S. | Good
Barnett, 2008^230^ | Women <55 yr in Studies of Epidemiology and Risk Factors in Cancer Heredity [underlined: Exposed]: 3069 [underlined: Unexposed]: 1357 Recruitment period: 1991–1996 | 0.93 | 0.78 to 1.1 | Crude | UK | Fair
Population-Level Mortality
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–1970 | 0.9 | 0.74 to 1.08 | Age, parity, smoking, social class, HRT | UK | Fair
Vessey, 2010^165^ | Oxford Family Planning Association Contraceptive Study (age NR) 602,700 person-years (total for exposed and unexposed) Recruitment period: 1968–1974 | 1 | 0.8 to 1.2 | Age, parity, BMI, smoking, social class | UK | Fair
Lu, 2011^232^ | Women in the Women's Contraceptive and Reproductive Study (CARE) and the California Teachers Study (CTS) | | | Age, race, BMI, age at menarche, smoking, study site, ER status, tumor stage, education, alcohol consumption, number of comorbidities, number of mammograms | U.S. | Good
Lu, 2011^232^ | CARE [underlined: Exposed]: 3524 [underlined: Unexposed]: 1041 | 1.03 | 0.85 to 1.25 | Age, race, BMI, age at menarche, smoking, study site, ER status, tumor stage, education, alcohol consumption, number of comorbidities, number of mammograms | U.S. | Good
Lu, 2011^232^ | CTS [underlined: Exposed]: 2439 [underlined: Unexposed]: 1490 | 0.89 | 0.64 to 1.23 | Age, race, BMI, age at menarche, smoking, CARE breast cancer cases | U.S. | Good

BMI = body mass index; CI = confidence interval; HRT = hormone replacement therapy; NR = not reported; OC = oral contraceptive; OR = odds ratio; UK = United Kingdom; yr=year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Odds ratios for meta-analysis of ever versus never OC use.

As with ovarian cancer mortality, the studies evaluated two different populations and questions. Three studies33,165,232 evaluated population-level, cause-specific mortality from breast cancer (as well as other cancers, including ovarian cancer). The general question addressed was, “Are women who used OCs more likely to die from breast cancer than women who did not use OCs?” These studies did not find that OC use significantly increased risk.

Three other cohort studies229-231 addressed the question, “Among women who develop breast cancer, are women who used OCs more or less likely to die from breast cancer within a certain time period than those who did not use OCs?” Again, no studies detected significant differences. Because studies did not report comparable statistics (e.g., hazard ratios, odds ratios), we did not perform meta-analyses.

### Strength of Evidence for OC Use and Risk of Breast Cancer

As described in the Methods section, strength of evidence (SOE) assessments are based on consideration of four domains: risk of bias, consistency in direction of the effect, directness in measuring intended outcomes, and precision of effect. The degree of confidence that the observed effect of an intervention is unlikely to change is presented as SOE and can be insufficient, low, moderate, or high. Strength of evidence describes the adequacy of the current research, both quantity and quality, and whether the entire body of current research provides a consistent and precise estimate of effect. Interventions that have shown significant benefit in a small number of studies or have not yet been replicated using rigorous study designs will have insufficient or low strength of evidence, despite potentially offering clinically important benefits. Future research may find that the intervention is either effective or ineffective.

We rated the strength of evidence for the effect of ever use of OC on breast cancer incidence as moderate (Table 25). Future studies are not likely to impact the direction but may influence the magnitude of the effect toward a small but significant increase in the risk of breast cancer associated with having ever used OCs. Most studies were of good or fair quality and exhibited consistent findings. The overall confidence interval for the summary estimate demonstrates a high level of precision. However, all included studies were observational thus; some risk of bias due to limitations of the study designs may exist. The SOE for the duration of use on risk of breast cancer incidence is low; future studies may impact strength and direction of estimates. Results were inconsistent with high level of heterogeneity across studies. Furthermore, the quantitative synthesis of these studies was underpowered resulting in low precision and confidence in point estimates. As with the overall effect of OCs, there may be some risk of bias due to limitations of the observational study designs. The SOE for time since last use on the risk of breast cancer incidence was graded as low. It is likely that future studies may impact strength of estimates. There was significant heterogeneity of effects. Moreover, we were not able to assess the interaction of time since last use with other important time-dependent factors that could impact the overall estimate of effect (e.g., times since last use by age at first use).

Table 25 Strength of evidence domains for the effect of OC use on breast cancer

Comparison | Number of Studies (Women and/or Person-years) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Comparison | Number of Studies (Women and/or Person-years) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Incidence of Breast Cancer in Overall Population
Ever vs. never use | 23 (356,023 across 20 studies and 3,981,072 person-years across 3 studies) | Medium | Consistent | Direct | Precise | Moderate 1.08 (1.00 to 1.17)
Duration of use | 14 (291,407 across 12 studies and 2,898,072 person-years across 2 studies) | Medium | Inconsistent | Direct | Imprecise | Low No increase in risk for longer durations of use
Time since last use | 11 (200,258) | High | Inconsistent | Direct | Imprecise | Low Reduced risk over time since last use 0–5 yr: 1.21 (1.04 to 1.41) 5–10 yr: 1.17 (0.98 to 1.38) 10–20 yr: 1.13 (0.97 to 1.31) >20 yr: 1.02 (0.88 to 1.18)
Incidence in BRCA1- or BRCA2-Positive Women
Ever vs. never use | 5 (4555 across 4 studies, and 65,180 person-years in 1 study) | Medium | Inconsistent | Direct | Imprecise | Low Trend toward slight increase in risk 1.21 (0.93 to 1.58)
Incidence in Women With Family History
Ever vs. never use | 3 (9280) | High | Inconsistent | Direct | Imprecise | Insufficient Not performed
Incidence in Young Women
Ever vs. never use | 3 (5716) | Medium | Inconsistent | Direct | Imprecise | Insufficient Not performed
Mortality From Breast Cancer
Ever vs. never use | 3 (54,606 across 2 studies and 602,700 person-years in 1 study) | Medium | Consistent | Direct | Imprecise | Low No significant increase in risk 0.94 (0.87 to 1.02)
Survival After Diagnosis of Breast Cancer
Ever vs. never use | 3 (9606) | Medium | Consistent | Direct | Imprecise | Low No significant increase in risk

BRCA = breast cancer genetic mutation; CI = confidence interval; SOE = strength of evidence; yr = year/years

The SOE for the association of OC use on breast cancers among women with a family history of breast cancer and in younger women at time of diagnosis was graded as insufficient. Differences in studies designs, such as how family history was defined, precluded quantitative synthesis. Moreover, there were only a handful of studies in each of these special populations and results were heterogeneous and exhibited inconsistent and imprecise findings. We graded the evidence as low among BRCA1/2 carriers. We were able to conduct a meta-analysis, but with only three studies; thus, precision and consistence were not optimal.

We graded the SOE for the risk of breast cancer mortality as moderate. The summary estimate included six large cohort studies that contributed a high level of precision. Results were consistent across studies. It is unlikely that future studies will influence the direction of this effect.

### OC Use and Cervical Cancer Incidence

We identified 12 studies that evaluated the association between OC use and the incidence of cervical cancer.37,138,155,156,233-241 including two articles from an International Agency for Research on Cancer (IARC) study representing distinct populations.240,241 Of these, nine were case-control studies, three cohort studies, and one pooled analysis; five studies were rated good quality, four fair quality, and four poor quality. Of the two articles from the IARC study, one was a pooled analysis and one a case-control design. Only two studies were conducted with U.S.-based populations and three were conducted among women selected for HPV+ infection status (Table 26).

Table 26 Study characteristics and association between OC use and cervical cancer incidence

Study^a^ | Study Details | OR^b^ | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^c^
Case-Control
Madeleine, 2001^233^ | Women aged 18–70 yr in U.S. Surveillance, Epidemiology, and End Results (SEER) [underlined: Cases]: 150 cervical cancer, SEER registry [underlined: Controls]: 651, population Recruitment period: 1990–1996 | 2.7 | 1.2 to 5.8 | Age, lifetime number of sex partners, interval since last screening pap smea | U.S. | Good | 1
Santos, 2001^234^ | Women recruited from hospitals in Lima (age NR) [underlined: Cases]: 186 invasive cervical cancer, hospitals [underlined: Controls]: 31, hospitals Recruitment period: 1996–1997 | 2.7 | 0.9 to 8.4 | Age, screening history, age at first intercourse, ever pregnancy | Peru | Poor | 2
Green, 2003^235^ | White women aged 20–44 yr selected from 5 UK cancer registries [underlined: Cases]: 391 squamous cancer, registries [underlined: Controls]: 923, outpatients | 1.37 | 0.97 to 1.94 | Age, smoking, region, total number of sexual partners, age at first intercourse, duration of oral contraceptive use, number of negative screening results and education | UK | Good | 1
Green, 2003^235^ | [underlined: Cases]: 180 adenocarcinoma, registries [underlined: Controls]: 923, outpatients | 1.56 | 1.01 to 2.42 | Age, smoking, region, total number of sexual partners, age at first intercourse, duration of oral contraceptive use, number of negative screening results and education | UK | Good | 1
Green, 2003^235^ | Recruitment period: 1987–1989 | | | Age, smoking, region, total number of sexual partners, age at first intercourse, duration of oral contraceptive use, number of negative screening results and education | UK | Good | 1
Shapiro, 2003^236^ | Women <60 yr at gynecological oncology clinics at tertiary care hospitals in Cape Town [underlined: Cases]: 524, invasive cervical cancer, hospitals [underlined: Controls]: 1541, hospitals Recruitment period: 1998–2001 | 0.8 | 0.7 to 1.1 | Age, race, smoking, age at first sexual intercourse, lifetime sexual partners, number of pap smears, education, rural vs. urban | South Africa | Fair | 1
Shields, 2004^237^ | Patients aged 20–74 yr from hospitals in 5 U.S. cities [underlined: Cases]: 235 squamous cervical cancer, hospitals [underlined: Controls]: 209, community Recruitment period: 1982–1984 | NR | NR | NA | U.S. | Poor | 2
Hammouda, 2005^241^ | Women in Algeria [underlined: Cases]: 190, hospital [underlined: Controls]: 197, hospital Recruitment period: 1997–1999 | NR | NR | NA | Algeria | Good | 2
Nojomi, 2008^238^ | Patients >30 yr from 1 of 7 general hospitals in Tehran [underlined: Cases]: 300, invasive cervical cancer, hospitals [underlined: Controls]: 319, hospitals Recruitment period: 2005–2006 | 0.9 | 0.6 to 1.2 | NA (unadjusted) | Iran | Poor | 1
Vanakankovit, 2008^239^ | Patients aged 30–70 yr at a hospital in Bangkok [underlined: Cases]: 60 invasive cervical CA, hospital [underlined: Controls]: 180, hospital Recruitment period: 2006–2007 | 1.45 | 0.79 to 2.64 | NA (unadjusted) | Thailand | Fair | 1
Urban, 2012^155^ | Black South African women aged 18–79 yr [underlined: Cases]: 241, hospital [underlined: Controls]: 156, hospital Recruitment period: 1995–2006 | 0.97 | 0.76 to 1.24 | Age, parity, smoking, year of diagnosis, education, alcohol consumption, sexual partners, urban/rural residence, province of birth | South Africa | Good | 1
Cohort
Vessey, 2006^156^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study [underlined: Exposed]: 301,000 person-years [underlined: Unexposed]: 187,000 person-years Recruitment period: 1968–1974 | 4.2 | 1.8 to 12.0 | Age, parity, BMI, smoking, social class, height, age at first term pregnancy, age at first marriage | UK | Good | 1
Hannaford, 2007^37^ | Royal College of General Practitioner's Oral Contraception Study [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years Mean age at study entry: 29 yr (SD 6.6) Recruitment period: 1968–1970 | 1.33 | 0.92 to 1.94 | Age, parity, smoking, social status | UK | Fair | 1
Rosenblatt, 2009^138^ | Textile workers in Shanghai aged 30–64 yr [underlined: Exposed]: 352,695 person-years [underlined: Unexposed]: 2,057,377 person-years Recruitment period: 1989–1991 | 0.13 | 0.02 to 0.96 | Age, parity | China | Poor | 1
Pooled
Moreno, 2002^240^ | HPV-positive women in Europe, South America, and Asia Total sample [underlined: Cases]: 1,676 [underlined: Controls:] 255 | 1.42 | 0.99 to 2.04 | Age, parity, study site, education, screening history, age at first intercourse, number of partners | Europe, South America, Asia | Fair | 2
Moreno, 2002^240^ | [underlined: Cases]: 1,465 invasive cervical cancer [underlined: Controls]: 227 | 1.29 | 0.88 to 1.91 | Age, parity, study site, education, screening history, age at first intercourse, number of partners | Europe, South America, Asia | Fair | 2
Moreno, 2002^240^ | [underlined: Cases:] 211 cervical cancer in situ [underlined: Controls]: 28 | 2.54 | 0.95 to 6.78 | Age, parity, study site, education, screening history, age at first intercourse, number of partners | Europe, South America, Asia | Fair | 2
Moreno, 2002^240^ | Mean age of cases: 49 yr Recruitment period: NR | | | Age, parity, study site, education, screening history, age at first intercourse, number of partners | Europe, South America, Asia | Fair | 2

BMI = body mass index; CI = confidence interval; DMV = department of motor vehicles; ER = estrogen receptor; HRT = hormone replacement therapy; NA = not applicable; NR = not reported; NZ = New Zealand; OC = oral contraceptive; OR = odds ratio; PR = progesterone receptor; UK = United Kingdom; U.S. = United States; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Odds ratios for meta-analysis of ever versus never OC use.

c Meta-analysis code: 1 = Included in this meta-analysis; 2 = Excluded due to HPV-positive population

#### Ever Versus Never OC Use

##### HPV-Positive Populations

Persistent infection with one or more oncogenic HPV types is required for cervical carcinogenesis; thus, women with HPV represent the most relevant population to assess the risks associated of cervical cancer associated with OC use. Only three studies234,237,240 assessed the association between OC use and cervical cancers among women positive for HPV (HPV+). Limited studies across comparisons precluded quantitative synthesis. We summarize each study below.

One fair-quality study240 pooled data from eight case-control studies of HPV+ patients with cervical cancer. Ever use of OCs was associated with a statistically nonsignificant increase in the odds of invasive cervical cancer (OR 1.29; 95% CI, 0.88 to 1.91) and cervical cancer in situ (OR 2.54; CI, 0.95 to 6.78). However, duration of use was significantly associated with cancer incidence such that HPV+ women who used OCs for 5 to 9 years (OR 2.82; CI, 1.46 to 5.42) and 10 or more years (OR 4.03; CI, 2.09 to 8.02) experienced a significant increase in the risk of cervical cancers compared with never users. This estimate did not vary by time since first or last use. However, this trend was not observed for women who used OCs for less than 5 years.

Two case-control studies,234,237 both rated poor quality, also assessed the risk of cervical cancer associated with OC use among HPV+ women. One study234 recruited hospital based HPV+ cases and controls in Lima, Peru. Results of this study were included in the pooled analysis above, and thus, could not be combined again. Compared with HPV+ controls, HPV+ women who had ever used OCs were at elevated risk of cervical cancer compared with women who had never used OCs (OR 2.7; 95% CI, 0.90 to 8.4), but the contrast was not significant. This study did not compute any analysis by duration of use.

The other case-control study237 assessed the association between OC use and cervical cancer among hospital-based HPV+ cases and HPV+ community controls in the United States. This study assessed the effect of duration of use on cervical cancer; the effect of ever use compared with never use was not calculated. Increasing the duration of OC use—categorized as less than 5 years, 5 to 10 years, and greater than 10 years—was associated with a decrease in cervical cancers. This trend was significant only in women with less than 5 years of use compared with never users (OR 0.6; 95% CI, 0.4 to 0.9).

##### Populations Not Selected for HPV-Positive Status

Six case-control studies representing 5436 women155,233,235,236,238,239 and three cohort studies37,138,156 representing 3,981,072 person-years were included in this meta-analysis examining the effect of ever versus never OC use on cervical cancer incidence (Table 26). Of these studies, four were rated good quality, three fair quality, and two poor quality. We excluded datasets from this analysis for studies that were conducted among women who were HPV-positive or did not provide an estimate for ever versus never OC use.

Stratified by study type, pooled case-control studies (OR 1.11, 95% CI, 0.86 to 1.44) (Figure 27) and cohort studies (OR 1.20; CI, 0.33 to 4.34) (Figure 28) suggest an increased risk of cervical cancer among women who ever used OCs although these increases were not statistically significant. A meta-analysis of all nine included studies showed an increase in the odds of cervical cancer for women who had ever used OCs compared with women who never used OCs (OR 1.21; CI, 0.91 to 1.61), but the comparison again was not significant. There was a large amount of heterogeneity, with a Q-value of 25.52 for 7 degrees of freedom, p<0.001, possibly due to HPV status differences among case-control studies, making the estimates unstable.

Figure 27 Forest plot for ever versus never OC use (case-control studies, cervical cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 27 shows the odds ratio was 1.11 (95% CI, 0.86 to 1.44).

Figure 28 Forest plot for ever versus never OC use (cohort studies, cervical cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 28 shows the odds ratio was 1.20 (95% CI, 0.33 to 4.34).

###### Sensitivity Analyses

We conducted additional analyses with only studies of good or fair quality. The magnitude of the effect was larger, but confidence intervals still included 1.0 (OR 2.17; 95% CI, 0.71 to 6.61). Only one study was conducted within the United States; results from this case-control study233 show a similar quantitative increase in risk with ever use of OCs that was statistically significant (OR 2.7; CI, 1.2 to 5.8).

#### Duration of OC Use

Six studies156,233,235,236,239,241 were included in this meta-analysis examining the effect of duration of OC use on cervical cancer incidence (Table 27). Of these, five were case-control studies and one was a cohort study; three were rated good quality and three fair quality. We excluded three studies from the meta-analysis234,237,240 that presented duration data for a unique population (HPV+ women only).

Table 27 Data for outcomes on duration of OC use (cervical cancer incidence)

Study^a^ | Subgroup (if Applicable) | Duration | OR | 95% CI
Case-Control
Madeleine, 2001^233^ | | 1–71 mo | 2.1 | 1.0 to 4.8
Madeleine, 2001^233^ | | 72–143 mo | 3.4 | 1.5 to 8.0
Madeleine, 2001^233^ | | ≥144 mo | 5.5 | 2.1 to 14.6
Santos, 2001^234^ | | ≤ 3 yr | 1.0 | 0.3 to 2.9
Santos, 2001^234^ | | ≥ 4 yr | 1.9 | NR
Green, 2003^235^ | Adenocarcinoma | 1–5 yr | 1.06 | 0.63 to 1.78
Green, 2003^235^ | Adenocarcinoma | 5–10 yr | 1.90 | 1.16 to 3.11
Green, 2003^235^ | Adenocarcinoma | ≥ 10 yr | 2.06 | 1.19 to 3.57
Green, 2003^235^ | Squamous cell cancer | 1–5 yr | 1.01 | 0.67 to 1.50
Green, 2003^235^ | Squamous cell cancer | 5–10 yr | 1.55 | 1.05 to 2.29
Green, 2003^235^ | Squamous cell cancer | ≥ 10 yr | 1.89 | 1.22 to 2.93
Shapiro, 2003^236^ | | ≤ 1 yr | 0.8 | 0.6 to 1.1
Shapiro, 2003^236^ | | 1–4 yr | 0.8 | 0.6 to 1.2
Shapiro, 2003^236^ | | 5–9 yr | 0.5 | 0.3 to 1.0
Shapiro, 2003^236^ | | ≥ 10 yr | 1.7 | 0.9 to 3.1
Shields, 2004^237^ | | ≤ 5 yr | 0.6 | 0.4 to 0.9
Shields, 2004^237^ | | 5–10 yr | 0.7 | 0.4 to 1.3
Shields, 2004^237^ | | ≥ 10 yr | 0.5 | 0.3 to 1.0
Hammouda, 2005^241^ | | < 5 yr | 0.6 | 0.3 to 1.2
Hammouda, 2005^241^ | | 5-9 yr | 0.5 | 0.3 to 1.1
Hammouda, 2005^241^ | | ≥ 10 yr | 0.8 | 0.4 to 1.6
Vanakankovit, 2008^239^ | | ≤ 3 yr | 0.78 | 0.33 to 1.77
Vanakankovit, 2008^239^ | | ≥ 3 yr | 2.57 | 1.22 to 5.49
Cohort
Vessey, 2006^156^ | | ≤ 48 mo | 2.9 | 0.9 to 9.9
Vessey, 2006^156^ | | 49–96 mo | 3.3 | 1.2 to 10.4
Vessey, 2006^156^ | | ≥ 97 mo | 6.1 | 2.5 to 17.0
Pooled
Moreno, 2002^240^ | | ≤ 1 yr | 0.67 | 0.41 to1.08
Moreno, 2002^240^ | | 2–4 yr | 0.80 | 0.51 to1.24
Moreno, 2002^240^ | | 5–9 yr | 2.82 | 1.46 to5.42
Moreno, 2002^240^ | | > 10 yr | 4.03 | 2.09 to7.79

CI = confidence interval; mo = month/months; NR = not reported; OR = odds ratio; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

For the included studies we categorized duration of OC use into 2 intervals: (1) 1 to 60 months and (2) greater than 60 months. The results of this analysis, summarized in Table 28, show no time-dependent relationship as a function of duration. There was significant heterogeneity, with a t-value of 4.72 for 5 degrees of freedom, p=0.0033. The test was underpowered; there would have to be a 50-percent difference in risk of cervical cancer by time period in order to detect significant differences.

Table 28 Estimated odds ratios by duration of OC use (cervical cancer incidence)

Duration | Odds Ratio (95% Confidence Interval) | P-value
< 60 months | 0.99 (0.58 to 1.70) | 0.975
> 60 months | 1.47 (0.91 to 2.38) | 0.097

### OC Use and Cervical Cancer Mortality

We identified two studies that evaluated the association between OC use and cervical cancer mortality (Table 29).33,164-166 Both were cohort studies, rated fair quality, and were conducted in the United Kingdom. Vessey et al.165 found an increased risk of cervical cancer mortality associated with OC use, with a very wide confidence interval, with a risk ratio of 7.3 (95% CI, 1.2 to 305). Hannaford et al.33 found an increased risk of mortality among those exposed to OCs; however, these effects were not statistically significant, with a risk ratio of 1.52 (CI, 0.67 to 3.48). Both studies also assessed mortality as a function of duration of OC use; results showed a trend of increased risk of death with longer duration of use with a statistically significant increased risk of death for 8 or more years of use compared with never users.

Table 29 Study characteristics and association between OC use and cervical cancer mortality

Study | Study Details | Point Estimate (95% CI)^a^ | Duration of Use | Point Estimate (95% CI)^b^ | Covariates | Region | Study Quality | Meta-Analysis Code^c^
Cohort
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–1970 | 1.34 (0.74 to 2.44) | < 4 yr | 1.08 (0.35 to 3.31) | Age, parity, smoking, social class | UK | Fair | 1
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–1970 | 1.34 (0.74 to 2.44) | 4–8 yr | 1.60 (0.56 to 4.62) | Age, parity, smoking, social class | UK | Fair | 1
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–1970 | 1.34 (0.74 to 2.44) | ≥ 8+ yr | 2.97 (1.12 to 7.92) | Age, parity, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 7.3(1.2 to 305.0) | < 48 mo | 3.8 (0.30 to 1.98) | Age, parity, BMI, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 7.3(1.2 to 305.0) | 49–96 mo | 7.7 (0.9 to 3.56) | Age, parity, BMI, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 7.3(1.2 to 305.0) | ≥ 97 mo | 10.2 (1.40, to 4.47) | Age, parity, BMI, smoking, social class | UK | Fair | 1

BMI = body mass index; CI = confidence interval; DMV = department of motor vehicles; ER = estrogen receptor; HRT = hormone replacement therapy; IRR = incidence rate ratio; mo = month; NR = not reported; OC = oral contraceptive; SD = standard deviation; UK = United Kingdom; yr = year/years

a Point estimate for meta-analysis of ever versus never OC use.

b Point estimate for meta-analysis of duration of OC use.

c Meta-analysis code: 1 = Met inclusion criteria for possible meta-analysis.

### Strength of Evidence for OC Use and Risk of Cervical Cancer

We graded the SOE for the association of ever use of OC on the risk of cervical cancer among HPV+ women as insufficient (Table 30). We identified only three studies and most were of poor quality. Studies did not control for factors that may influence risk such as age at first use by duration or age at sexual debut, which is likely highly correlated with age at first use. Moreover, results were inconsistent; sensitivity analysis yielded qualitatively different estimates of effects; and confidence intervals were wide. Future studies will likely influence magnitude and, possibly, direction of effect.

Table 30 Strength of evidence domains for the effect of OC use on cervical cancer

Comparison | Number of Studies (Women and/or Person-Years) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Comparison | Number of Studies (Women and/or Person-Years) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Incidence of Cervical Cancer in HPV-Positive Population
Ever vs. never use | 3 (2592) | High | Inconsistent | Direct | Imprecise | Insufficient Unable to draw summary conclusion
Mortality From Cervical Cancer
Ever vs. never use | 2 (46,112 women in 1 study and 602,700 person-years in 1 study) | High | Consistent | Direct | Imprecise | Low Increased risk with ever use and longer duration of use

CI = confidence interval; HPV = human papillomaviruses; SOE = strength of evidence

The SOE for the risk of cervical cancer mortality associated with the use of OCs was graded as low. Though results were consistent and suggest increased risk of death associated with prolonged use, we identified only two studies. Results lacked precision; studies reported very wide confidence intervals. Risk of bias was graded as high; studies did not account for HPV status and both were rated only fair quality. Future research will likely moderate the magnitude and direction of effects.

### OC Use and Colorectal Cancer Incidence

We identified 11 studies that evaluated the association between OC use and the incidence of colorectal cancer.37,88,99,156,242-249 Of these, 3 were case-control studies, 7 cohort studies, and 1 pooled analysis; 4 studies were rated good quality, 6 fair quality and 1 poor quality (Table 31). Nine studies were conducted in Western countries and two in China.

Table 31 Study characteristics and association between OC use and colorectal cancer incidence

Study^a^ | Study Details | OR^b^ | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^c^
Case-Control
Levi, 2003^242^ | Women aged 28–74 yr in Canton of Vaud [underlined: Cases]: 131 colorectal cancer, hospital [underlined: Controls]: 373, hospital Recruitment period: 1992–2001 | 0.83 | 0.4 to 1.7 | Age, parity, family history, fiber intake, physical activity | Switzerland | Poor | 1
Campbell, 2007^243^ | Women aged 20–74 yr in Ontario, Newfoundland, Labrador [underlined: Cases]: 1404 colorectal cancer, registry [underlined: Controls]: 1203, property records Recruitment period: 2003–2006 | 0.77 | 0.65 to 0.91 | Age, province of residence, education, ever use postmenopausal hormones, colorectal cancer screening endoscopy, physical activity, BMI, menopausal status | Canada | Fair | 1
Long, 2010^244^ | Women aged 40–80 yr in North Carolina Colon Cancer Study-II [underlined: Cases]: 443 distal large bowel cancer, registry [underlined: Controls]: 405, community Recruitment period: 2001–2006 | 0.95 | 0.67 to 1.34 | Age, race, BMI, family history, smoking, family history of colorectal cancer, education, HRT use, physical activity | U.S. | Good | 1
Cohort
Rosenblatt, 2004^249^ | Textile workers in Shanghai aged 30–64 yr [underlined: Exposed]: 352,851 person-years [underlined: Unexposed]: 1,045,388 person-years Recruitment period: 1989–1991 | 1.09 | 0.86 to 1.37 | Age, parity | China | Fair | 1
Vessey, 2006^156^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study [underlined: Exposed]: 301,000 person-years [underlined: Unexposed]: 187,000 person-years Recruitment period: 1968–1974 | 0.8 | 0.6 to 1.2 | Age, parity, BMI, smoking, social class, height, age at first term pregnancy, age at first marriage | UK | Good | 1
Hannaford, 2007^37^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years Mean age at entry: 29 (SD6.6) Recruitment period: 1968–NR | 0.72 | 0.58 to 0.90 | Age, parity, smoking, social status | UK | Fair | 1
Lin, 2007^246^ | Women ≥45 yr in Women's Health Study [underlined: Exposed]: 27,440 [underlined: Unexposed]: 12,060 Recruitment period: 1992–NR | 0.67 | 0.50 to 0.89 | Age, BMI, family history, smoking, randomized treatment assignment, family history of colorectal cancer, previous history of benign colorectal polyps, physical activity, red meat intake, alcohol consumption, baseline aspirin use, multivitamin use, baseline postmenopausal hormone use | U.S. | Good | 1
Kabat, 2008^245^ | Women aged 40–59 yr in Canadian National Breast Screening Study [underlined: Exposed]: 1142 [underlined: Unexposed]: 88,655 Recruitment period: 1980–1985 | 0.83 | 0.73 to 0.94 | Age, parity, smoking, social status, ever use of HRT | Canada | Fair | 1
Dorjgochoo, 2009^88^ | Women aged 40–70 yr in Shanghai Women's Health Study [underlined: Exposed]: 12,957 [underlined: Unexposed]: 15,557 Recruitment period: 1997–2000 | 1.24 | 0.87 to 1.78 | Age, parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | China | Fair | 1
Tsilidis, 2010^247^ | Women aged 35–70 yr in European Prospective Investigation into Cancer and Nutrition [underlined: Exposed]: 196,862 [underlined: Unexposed]: 139,399 Recruitment period: 1990s | 0.92 | 0.83 to 1.02 | Age, BMI, smoking, diabetes mellitus, physical activity, alcohol use | 10 European countries | Good | 1
Pooled
Nichols, 2005^248^ | Women in Wisconsin aged 20–74 yr [underlined: Cases:] 1488 colorectal cancer, registry Controls: 4297, community Recruitment periods: 1988–1991; 1997–2001 | 0.89 | 0.75 to 1.06 | BMI, family history, smoking, conditional on age and study of enrollment; adjusted for family history of colorectal cancer, education, screening, hormone replacement therapy, age at first birth | U.S. | Fair | 1

BMI = body mass index; CI = confidence interval; DMV = department of motor vehicles; ER = estrogen receptor; HRT = hormone replacement therapy; NA = not applicable; NR = not reported; OC = oral contraceptive; OR = odds ratio; PR = progesterone receptor; UK = United Kingdom; U.S. = United States; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Odds ratio for meta-analysis of ever versus never OC use.

c Meta-analysis code: 1 = included in this meta-analysis.

#### Ever Versus Never OC Use

Three case-control studies,242-244 one pooled analysis,248 and seven cohort studies37,88,156,245-247,249 representing 503,816 women across 8 studies and 2,969,189 person-years across 3 studies were included in this meta-analysis examining the effect of ever versus never OC use on colorectal cancer incidence (Table 31). Of these studies, four were rated good quality, six fair quality and one poor quality.

Stratified by study type, both case-control studies (OR 0.84; 95% CI, 0.75 to 0.94) (Figure 29) and cohort studies (OR 0.87; CI, 0.77 to 0.98) (Figure 30) demonstrated a decrease in the risk of colorectal cancers among women who ever used OCs. The odds ratios for the two types of studies were similar; a test of differences was not significant (p=0.791). In a meta-analysis including the 11 studies of all designs, the odds of colorectal cancer were significantly decreased for women who had ever used OCs compared with women who never used OCs (OR 0.86; CI, 0.79 to 0.95; Q value of 17.17, p<0.046).

Figure 29 Forest plot for ever versus never OC use (case-control and pooled studies, colorectal cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 29 shows the odds ratios was 0.84 (95% CI, 0.75 to 0.94).

Figure 30 Forest plot for ever versus never OC use (cohort studies, colorectal cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 30 shows the odds ratio was 0.87 (95% CI, 0.77 to 0.98).

##### Sensitivity Analyses

We conducted additional analyses including only studies of good or fair quality. Results were similar to those including all studies (OR 0.86; 95% CI, 0.79 to 0.94). We also conducted sensitivity analyses of studies that only included patients from the United States; results were similar to those containing all studies but the confidence interval eclipsed 1 (OR 0.83; CI, 0.69 to 1.01).

#### Duration of OC Use

Ten studies37,88,156,242-246,248,249 were included in this meta-analysis examining the effect of duration of OC use on colorectal cancer incidence (Table 32). Of these, 3 were case-control studies, 6 cohort studies, and 1 pooled analysis; three were rated good quality, six fair quality and one poor quality. We excluded one study from the meta-analysis247 that used less than 1 year of use as the reference group.

Table 32 Data for outcomes on duration of OC use (colorectal cancer incidence)

Study^a^ | Duration | OR | 95% CI
Case-Control
Levi, 2003^242^ | < 5 yr | 0.74 | 0.2 to 2.4
Levi, 2003^242^ | > 5 yr | 0.87 | 0.4 to 2.0
Campbell, 2007^243^ | 1–4 yr | 0.77 | 0.62 to 0.97
Campbell, 2007^243^ | ≥ 5 yr | 0.77 | 0.62 to 0.95
Long, 2010^244^ | 0–2 yr | 0.63 | 0.38 to 1.03
Long, 2010^244^ | >2 to < 5 yr | 1.11 | 0.61 to 2.00
Long, 2010^244^ | 5 to < 10 yr | 1.18 | 0.70 to 2.00
Long, 2010^244^ | > 10 yr | 1.32 | 0.79 to 2.21
Cohort
Rosenblatt, 2004^249^ | < 6 mo | 0.97 | 0.64 to 1.47
Rosenblatt, 2004^249^ | 7–24 mo | 0.96 | 0.67 to 1.38
Rosenblatt, 2004^249^ | 25–36 mo | 1.13 | 0.65 to 1.97
Rosenblatt, 2004^249^ | ≥ 37 mo | 1.56 | 1.01 to 2.40
Vessey, 2006^156^ | < 48 mo | 1.1 | 0.6 to 1.7
Vessey, 2006^156^ | 49–96 mo | 0.8 | 0.4 to 1.2
Vessey, 2006^156^ | ≥ 97 mo | 0.8 | 0.5 to 1.2
Hannaford, 2007^37^ | <48 mo | 0.82 | 0.51 to 1.31
Hannaford, 2007^37^ | 49–96 mo | 0.72 | 0.43 to 1.21
Hannaford, 2007^37^ | ≥ 96 mo | 0.95 | 0.59 to 1.54
Lin, 2007^246^ | < 6 mo | 0.65 | 0.39 to 1.08
Lin, 2007^246^ | 6–35 mo | 0.61 | 0.40 to 0.94
Lin, 2007^246^ | 36–59 mo | 0.79 | 0.51 to 1.23
Lin, 2007^246^ | ≥ 60 mo | 0.68 | 0.47 to 0.99
Kabat, 2008^245^ | 1–11 mo | 0.86 | 0.70 to 1.06
Kabat, 2008^245^ | 12–25 mo | 0.89 | 0.73 to 1.09
Kabat, 2008^245^ | 26–71 mo | 0.75 | 0.63 to 0.90
Kabat, 2008^245^ | ≥ 72 mo | 0.84 | 0.69 to 1.03
Dorjgochoo, 2009^88^ | < 2 yr | 1.39 | 0.86 to 2.23
Dorjgochoo, 2009^88^ | ≥ 2 yr | 1.14 | 0.73 to 1.78
Tsilidis, 2010^247^ | 2–4 yr | 0.99 | 0.80 to 1.23
Tsilidis, 2010^247^ | 5–9 yr | 0.93 | 0.74 to 1.17
Tsilidis, 2010^247^ | ≥ 10 yr | 1.09 | 0.89 to 1.35
Pooled
Nichols, 2005^248^ | 1–23 mo | 0.88 | 0.67 to 1.15
Nichols, 2005^248^ | 24–53 mo | 0.96 | 0.74 to 1.25
Nichols, 2005^248^ | 54–107 mo | 0.90 | 0.69 to 1.17
Nichols, 2005^248^ | ≥ 108 mo | 0.84 | 0.64 to 1.09

CI = confidence interval; mo = month/months; OR = odds ratio; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

For the included studies, we categorized duration of use into 2 intervals: (1) 1 to 60 months and (2) greater than 60 months. The results of this analysis, summarized in Table 33, show no time-dependent relationship as a function of duration. There was no significant heterogeneity, with a t-value of 1.52 for 9 degrees of freedom, p=0.164. As with most of the other analyses of duration of exposure, the test was underpowered; there would have to be a 20-percent difference in risk of colorectal cancer by time period in order to detect significant differences.

Table 33 Estimated odds ratios by duration of OC use (colorectal cancer incidence)

Duration | Odds Ratio (95% Confidence Interval) | P-value
< 60 months | 0.88 (0.77 to 1.01) | 0.063
> 60 months | 0.88 (0.76 to 1.01) | 0.061

### OC Use and Colorectal Cancer Mortality

We identified two studies that evaluated the association between OC use and colorectal cancer mortality (Table 34).33,164-166 Both were cohort studies, rated fair quality, and were conducted in the United Kingdom. Results were mixed. One study33 found a decrease in the risk of mortality among those exposed to OCs; however, these effects were not statistically significant. The other study165 showed an increase in colorectal cancer mortality associated with having ever used OCs. Both studies also assessed mortality as a function of duration of OC use; results showed no clear trend of a greater protective effect associated with longer duration of use.

Table 34 Study characteristics and association between OC use and colorectal cancer mortality

Study | Study Details | Point Estimate (95% CI)^a^ | Duration of Use | Point Estimate (95% CI)^b^ | Covariates | Region | Study Quality | Meta-Analysis Code^c^
Cohort
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–NR | 0.62 (0.46 to 0.83) | < 4 yr | 1.02 (0.52 to 2.0) | Age, parity, smoking, social class | UK | Fair | 1
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–NR | 0.62 (0.46 to 0.83) | 4–8 yr | 0.65 (0.30 to 1.43) | Age, parity, smoking, social class | UK | Fair | 1
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–NR | 0.62 (0.46 to 0.83) | ≥ 8+ yr | 0.45 (0.16, 1.28) | Age, parity, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 1.2 (0.8 to 2.0) | < 48 mo | 1.2 (0.6 to 2.4) | Age, parity, BMI, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 1.2 (0.8 to 2.0) | 49–96 mo | 1.4 (0.7 to 2.5) | Age, parity, BMI, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 1.2 (0.8 to 2.0) | ≥ 97 mo | 1.1 (0.6 to 2.0 | Age, parity, BMI, smoking, social class | UK | Fair | 1

BMI = body mass index; CI = confidence interval; mo = month/months; NR = not reported; OC = oral contraceptive; OR = odds ratio; UK = United Kingdom; yr = year/years

a Point estimate for meta-analysis of ever versus never OC use.

b Point estimate for meta-analysis of duration of OC use.

c Meta-analysis code: 1=Met inclusion criteria for possible meta-analysis

### Strength of Evidence for OC Use and Risk of Colorectal Cancer

We graded the SOE for the association of OC use and incidence of colorectal cancer as moderate (Table 35). We were able to include all 11 studies in meta-analysis, results were consistent across studies and sensitivity analyses, and summary estimate demonstrated high precision with at tight confidence interval. Future studies will likely not impact direction of effect but may slightly influence magnitude of the effect. The SOE for duration was graded as insufficient. The test was underpowered and we found significant heterogeneity. Future studies will likely influence magnitude of effect across duration categories.

Table 35 Strength of evidence domains for the effect of OC use on colorectal cancer

Comparison | Number of Studies (Women and/or Person-Years) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Comparison | Number of Studies (Women and/or Person-Years) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Incidence of Colorectal Cancer in Overall Population
Ever vs. never use | 11 (503,816 across 8 studies and 2,969,189 person-years across 3 studies) | Medium | Consistent | Direct | Precise | Moderate 0.86 (0.79 to 0.95)
Duration of use | 10 (167,555 across 7 studies and 2,969,189 person-years across 3 studies) | Medium | Consistent | Direct | Imprecise | Low No increase in protective effect with prolonged use
Mortality From Colorectal Cancer
Ever vs. never use | 2 (46,112 in 1 study and 602,700 person-years in a second study) | Medium | Inconsistent | Direct | Imprecise | Insufficient Mixed results for risk of death with ever use and no trend toward increased protective effect with longer duration of use

CI = confidence interval; SOE = strength of evidence

We also graded the SOE at insufficient for the risk of death associated with ever use of OCs. We identified only two fair-quality studies with inconsistent effects for ever use and duration of use. It is likely that future studies will impact direction and magnitude of effects.

### OC Use and Endometrial Cancer Incidence

We identified nine studies that evaluated the association between OC use and the incidence of endometrial cancer.37,138,155,156,250-254 Of these, four were case-control studies and five cohort studies; six were rated good quality, two fair quality, and one poor quality. Only two studies were conducted in the United States (Table 36).

Table 36 Study characteristics and association between OC use and endometrial cancer incidence

Study^a^ | Study Details | OR^b^ | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^c^
Case-Control
Parslov, 2000^250^ | Danish women aged 25–49 yr [underlined: Cases]: 237 endometrial cancer, hospital [underlined: Controls]: 538, Central Person Register Recruitment period: 1987–1994 | NR | NR | NA | Denmark | Good | 2
Maxwell, 2006^251^ | Women aged 20–54 yr in Cancer and Steroid Hormone Study [underlined: Cases]: 434 endometrial cancer, SEER registry [underlined: Controls]: 2557, population | 0.21 | 0.10 to 0.43 | NA | U.S. | Good | 1
Maxwell, 2006^251^ | High progestin/high estrogen | 0.00 | 0.00 to 5.59 | NA | U.S. | Good | 1
Maxwell, 2006^251^ | High progestin/low estrogen | 0.39 | 0.25 to 0.60 | NA | U.S. | Good | 1
Maxwell, 2006^251^ | Low progestin/high estrogen | 0.40 | 0.21 to 0.76 | NA | U.S. | Good | 1
Maxwell, 2006^251^ | Low progestin/Low estrogen | | | NA | U.S. | Good | 1
Maxwell, 2006^251^ | Recruitment period: 1980–1982 | | | NA | U.S. | Good | 1
Tao, 2006^254^ | Women aged 30–69 yr in Shanghai Endometrial Cancer Study [underlined: Cases]: 1204 endometrial cancer, registry [underlined: Controls]: 1212 no history of hysterectomy, resident registry Recruitment period: 1997–2003 | 0.75 | 0.60 to 0.93 | Age, parity, menopausal status, BMI, family history, age at menarche, education, yr of menstruation, family history of breast, endometrial, and colon cancers, age at last live birth, physical activity, exogenous hormone use | China | Good | 1
Urban, 2012^155^ | Black South African women aged 18–79 yr [underlined: Cases]: 17, hospital [underlined: Controls]: 156, hospital Recruitment period: 1995–2006 | 1.01 | 0.55 to 1.85 | Age, parity, smoking, year of diagnosis, education, alcohol consumption, sexual partners, urban/rural residence, province of birth | South Africa | Good | 1
Cohort
Vessey, 2006^156^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study [underlined: Exposed]: 301,000 person-years [underlined: Unexposed]: 187,000 person-years Recruitment period: 1968–1974 | 0.3 | 0.2 to 0.6 | Age, parity, BMI, smoking, social class, height, age at first term pregnancy, age at first marriage | UK | Good | 1
Hannaford, 2007^37^ | Royal College of General Practitioner's Oral Contraception Study [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years Mean age at study entry: 29 (SD 6.6) Recruitment period: 1968–NR | 0.58 | 0.42 to 0.79 | Age, parity, smoking, social status | UK | Fair | 1
Setiawan, 2007^253^ | Women aged 45–75 yr in Multiethnic Cohort Study Hawaii and Los Angeles 46,933 (total population of exposed and unexposed, postmenopausal women) Recruitment period: 1993–1996 | NR | NR | NA | U.S. | Good | 2
Rosenblatt, 2009^138^ | Textile workers in Shanghai aged 30–64 yr [underlined: Exposed]: 352,695 person-years [underlined: Unexposed]: 2,057,377 person-years Recruitment period: 1989–1991 | 0.68 | 0.45 to 1.04 | Age, parity, tubal ligation | China | Poor | 1
Dossus, 2010^252^ | European Prospective Investigation into Cancer and Nutrition [underlined: Exposed]: 1017 [underlined: Unexposed]: 301,601 1017 Cases, 301601 Cases Mean age of cases at entry: 56.2 Recruitment period: 1992–NR | 0.65 | 0.56 to 0.75 | BMI, smoking, physical activity, alcohol, diabetes, education | 10 European countries | Fair | 1

BMI = body mass index; CI = confidence interval; NA = not applicable; NR = not reported; OC = oral contraceptive; OR = odds ratio; UK = United Kingdom; U.S. = United States; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Odds ratio for meta-analysis of ever versus never OC use.

c Meta-analysis code: 1 = Included in this meta-analysis; 2 = Excluded due to ever versus never OR not reported.

#### Ever Versus Never OC Use

Three case-control155,251,254 and 4 cohort studies37,138,156,252 representing 308,198 women (within 4 studies) and an additional 3,981,072 person-years (within the other 3 studies) were included in this meta-analysis examining the effect of ever versus never OC use on endometrial cancer incidence (Table 36). Of these studies, four were rated good quality, two fair quality, and 1 poor quality. We excluded two studies from the meta-analysis that did not report point estimates for ever versus never OC use.

Figure 31 indicates a protective effect for endometrial cancer associated with having ever used OCs (OR 0.57; 95% CI, 0.43 to 0.76). The test of heterogeneity was significant, with a Q-value of 26.11 for 6 degrees of freedom, p<0.001. However, test for a difference between the cohort and case-control studies was not significant, with a Q-value of 0.113 for 1 degree of freedom, p=0.736.

Figure 31 Forest plot for ever versus never OC use (case-control and cohort studies, endometrial cancer incidence)

CI = confidence interval; OC = oral contraceptive

##### Sensitivity Analyses

We conducted an additional analysis to assess the impact of study quality; results were similar when including only the four good- and two fair-quality studies (OR 0.56; 95% CI, 0.43 to 0.74). We also explored how our findings changed when including only U.S.-based studies in our quantitative synthesis. Only one study was conducted with patients from the United States; the results of this study reported a somewhat greater protective effect than summary estimates for all studies (OR 0.34; CI, 0.25 to 0.47).

#### Duration of OC Use

Eight studies37,138,155,156,250,252-254 were included in this meta-analysis examining the effect of duration of use on endometrial cancer incidence (Table 37). Of these, three were case-control studies and five cohort studies; five were rated good quality, two fair quality, and one poor quality. We excluded one study that did not report duration of use estimates.

Table 37 Data for outcomes on duration of OC use (endometrial cancer incidence)

Study | Duration | OR | 95% CI
Case-Control
Parslov, 2000^250^ | < 1 yr | 0.4 | 0.3 to 0.7
Parslov, 2000^250^ | 1–5 yr | 0.2 | 0.1 to 0.3
Parslov, 2000^250^ | > 5 yr | 0.2 | 0.1 to 0.4
Tao, 2006^254^ | < 6 mo | 0.94 | 0.64 to 1.38
Tao, 2006^254^ | 6–23 mo | 0.74 | 0.50 to 1.09
Tao, 2006^254^ | 24–72 mo | 0.75 | 0.52 to 1.07
Tao, 2006^254^ | > 72 mo | 0.50 | 0.30 to 0.85
Urban, 2012^155^ | < 5 yr | 1.57 | 0.72 to 3.41
Urban, 2012^155^ | ≥ 5 yr | 0.64 | 0.27 to 1.51
Cohort
Vessey, 2006^156^ | ≤ 48 mo | 0.6 | 0.3 to 1.1
Vessey, 2006^156^ | 49–96 mo | 0.4 | 0.2 to 0.8
Vessey, 2006^156^ | ≥ 97 mo | 0.1 | 0 to 0.4
Hannaford, 2007^37^ | < 48 mo | 0.60 | 0.30 to 1.21
Hannaford, 2007^37^ | 49–96 mo | 0.14 | 0.03 to 0.58
Hannaford, 2007^37^ | > 97 mo | 0.57 | 0.27 to 1.19
Setiawan, 2007^253^ | < 5 yr | 0.96 | 0.71 to 1.30
Setiawan, 2007^253^ | ≥ 5 yr | 0.60 | 0.39 to 0.91
Rosenblatt, 2009^138^ | 1–11 mo | 1.15 | 0.65 to 2.01
Rosenblatt, 2009^138^ | ≥ 12 mo | 0.48 | 0.27 to 0.85
Dossus, 2010^252^ | 2–4 yr | 1.06 | 0.79 to 1.41
Dossus, 2010^252^ | 5–9 yr | 0.66 | 0.47 to 0.91
Dossus, 2010^252^ | ≥ 10 yr | 0.58 | 0.42 to 0.79

CI = confidence interval; mo = month/months; OR = odds ratio; yr = year/years

For the included studies, we categorized duration of use into 2 intervals: (1) 1 to 60 months and (2) greater than 60 months. The results of this analysis, summarized in Table 38, show a time-dependent relationship as a function of duration. The duration trend was strong, and the two odds ratios were significantly different (p=0.007). There was significant heterogeneity, with a t-value of 4.39 for 7 degrees of freedom, p=0.003.

Table 38 Estimated odds ratios by duration of OC use (endometrial cancer incidence)

Duration | Odds Ratio (95% Confidence Interval) | P-value
< 60 months | 0.78 (0.54 to 1.15) | 0.162
> 60 months | 0.44 (0.29 to 0.65) | 0.002

### OC Use and Endometrial Cancer Mortality

We identified two studies that evaluated the association between OC use and endometrial cancer mortality (Table 39).33,165 Both were cohort studies, rated fair quality, and were conducted in the United Kingdom. Both studies demonstrated a strong, significant protective effect for endometrial cancer mortality associated with having ever used OCs. Results also showed a trend of a greater protective effect associated with longer duration of use; however, the number of subjects within each category was small and point estimates for some duration categories were not calculable.

Table 39 Study characteristics and association between OC use and endometrial cancer mortality

Study | Study Details | Point Estimate (95% CI)^a^ | Duration of Use | Point Estimate (95% CI)^b^ | Covariates | Region | Study Quality | Meta-Analysis Code^c^
Cohort
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–NR | 0.43 (0.21 to 0.88) | < 4 yr | 0.9 (0.3 to 2.5) | Age, parity, smoking, social class | UK | Fair | 1
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–NR | 0.43 (0.21 to 0.88) | 4–8 yr | Not calculable | Age, parity, smoking, social class | UK | Fair | 1
Hannaford, 2010^33^ | Royal College of General Practitioner's Oral Contraception study [underlined: Exposed]: 28,806 [underlined: Unexposed]: 17,306 Mean age at entry: 29 yr (SD 6.6) Recruitment period: 1968–NR | 0.43 (0.21 to 0.88) | ≥ 8+ yr | 0.2 (0.0 to 1.0) | Age, parity, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 0.3 (0.1 to 0.8) | < 48 mo | 0.42 (0.05 to 3.45) | Age, parity, BMI, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 0.3 (0.1 to 0.8) | 49–96 mo | Not calculable | Age, parity, BMI, smoking, social class | UK | Fair | 1
Vessey, 2010^165^ | Women aged 25–39 yr in Oxford Family Planning Association Contraceptive Study 602,700 person-yr (total for exposed and unexposed) Recruitment period: 1968–1974 | 0.3 (0.1 to 0.8) | ≥ 97 mo | Not calculable | Age, parity, BMI, smoking, social class | UK | Fair | 1

BMI = body mass index; CI = confidence interval; NA = not applicable; NR = not reported; OC = oral contraceptive; OR = odds ratio; UK = United Kingdom; U.S. = United States; yr = year/years

a Point estimate for meta-analysis of ever versus never OC use.

b Point estimate for meta-analysis of duration of OC use.

c Meta-analysis code: 1 = Met inclusion criteria for possible meta-analysis.

### Strength of Evidence for OC Use and Risk of Endometrial Cancer

We graded the SOE for the association of ever use of OCs and risk of endometrial cancer as moderate (Table 40). We were able to quantitatively synthesize results across six studies. Results consistently showed a protective effect for ever use of OCs and the majority of studies were of good or fair quality. Confidence intervals displayed a satisfactory level of precision. Future studies may further improve precision but the overall magnitude of effect is unlikely to shift significantly.

Table 40 Strength of evidence domains for the effect of OC use on endometrial cancer

Comparison | Number of Studies (Women and/or Person-Years) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Comparison | Number of Studies (Women and/or Person-Years) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Incidence of Endometrial Cancer in Overall Population
Ever vs. never use | 7 (308,198 across 4 studies and 3,981,072 person-years across 3 studies) | Medium | Consistent | Direct | Precise | Moderate 0.57 (0.43 to 0.76)
Duration of use | 8 (352,915 across 5 studies and 3,981,072 person-years across 3 studies) | Medium | Consistent | Direct | Imprecise | Low <60 months:0.78 (0.54 to 1.15) >60 months: 0.44 (0.29 to 0.65)
Mortality
Ever vs. never use | 2 (46,112 in 1 study and 602,700 person-years in 1 study) | Medium | Consistent | Direct | Precise | Moderate Overall protective effect for ever use which is greater for longer durations of use

CI = confidence interval; SOE = strength of evidence

We graded the SOE as low for the association between duration of OC us and endometrial cancer incidence. We found significant heterogeneity and confidence intervals were wide, decreasing precision. Future studies will likely impact the magnitude of effect but not the direction.

The SOE for endometrial cancer mortality and OC use was graded as moderate. We identified two large cohort studies that reported consistent results. Future studies may improve estimates of the magnitude of the effect but not the direction of effect.

## Discussion

Our study complements the prior literature by limiting the scope to studies conducted after 1999 in order to minimize the influence of older OC formulations that are no longer available on the U.S. market—thus potentially increasing generalizability for current clinical practice. In this systematic review and meta-analysis, we found that OC use is associated, to a varying degree, with breast, cervical, colorectal, and endometrial cancers. Below, we synthesize the main results for each cancer and compare to other contemporary reviews. We then highlight limitations of this review and areas for future research. Note that we found no evidence for publication bias in any of the meta-analyses (Appendix E).

### Breast Cancer

The role of reproductive factors on the risk of developing breast cancer has been a topic of much study and debate. Thus, we sought to synthesize the evidence on the role of OCs on breast cancer incidence and mortality. We were able to pool results from 23 studies involving 356,023 women across 20 studies and 3,981,072 person-years across 3 studies that examined the effect of ever versus never OC use on the incidence of breast cancer. We found that the risk of breast cancer was slightly—but significantly—elevated for women who ever used OCs compared with women who never used OCs (OR 1.08; 95% CI, 1.00 to 1.17). A similar effect was seen among BRCA mutation carriers, although the results were not statistically significant (OR 1.21; CI, 0.93 to 1.58). (Although the inclusion of 1.0 in the 95% CI is considered nonsignificant using traditional rules of statistical inference, it is worth noting that the likelihood of the risk truly being increased when the lower bound is 1.0 is approximately 97.5%, and at a lower bound of 0.99, it is above 95%). Thus, as with ovarian cancer, the qualitative effect of OC use on breast cancer risk appears similar whether or not a BRCA gene mutation is present.

We found no time-dependent relationship as a function of duration of OC use across 14 pooled studies. Our duration of use results should be interpreted with caution; there was significant heterogeneity and the test was underpowered—which is not surprising, given that breast cancer is relatively uncommon during the ages when women are most likely to be using OCs. We did find a significant relationship with time since last OC use: women with more recent use had an elevated risk of breast cancers, with decreasing risk over time, so that by 10 years since last use, the risk among users was equivalent to never users. We did not identify sufficient studies meeting our inclusion criteria to calculate risk by age at first use. One collaborative reanalysis demonstrated an elevated risk of breast cancer for women who initiated use before age 20, an effect that diminished over time since last use.182 We also found no evidence of increased breast cancer mortality associated with having used OCs compared with never use across four pooled studies.

Our results are consistent with the results of other meta-analyses and pooled analyses that identified a small increase in the relative risk of breast cancers associated with having ever used OCs, a risk that diminishes over time since last use.182,255 The Collaborative Group on Hormonal Factors in Breast Cancer, a collaborative reanalysis of individual data in 153,536 women, found a small significant increase in the relative risk of breast cancers (OR 1.07 ± 0.02).182 Similar to our results, the Collaborative Group did not identify an increase in risk with increasing duration of use or after discontinuation of use for 10 or more years. Another more recent meta-analysis of premenopausal breast cancers across 37 studies found a somewhat larger increase in the risk of breast cancer with the use of OCs (OR 1.19; CI, 1.09 to 1.29) with the greatest risk associated with use of OCs prior to first full-term pregnancy (OR 1.44; CI, 1.28 to 1.62).52 These results provide support for our finding that recent use (within 5 or fewer years) is associated with an increased risk of breast cancers. Women who delay first full-term pregnancies may also be more likely to be recent users of OCs relative to a breast cancer diagnosis. However, these results cannot be directly compared with ours, as this meta-analysis was restricted to premenopausal women or women younger than age 50 who may be at elevated risk due to other factors (e.g., genetic mutations) or represent cancer subtypes that differentially affect younger women. No pooled analyses or meta-analyses have assessed the excess risk of breast cancer mortality associated with OC use. However, our findings of an increased incidence, but no significant change in overall mortality, suggest that some of the increase in breast cancer incidence may be due to increased surveillance in women who use OCs. Women who use OCs must come in contact with the health care system on a regular basis, thus increasing their chances of receiving referrals for preventive screenings such as mammography. Another potential explanation would be an OC-induced change in the natural history of breast cancer or an increase in ER-positive breast cancers, which have higher survival, resulting in improved survival. Although the relative increase in breast cancer risk is small, the relative frequency of breast cancer diagnosis means that OC use may contribute to a substantial number of cases, an issue that is explored further in Section 5.

### Cervical Cancer

While persistent infection with oncogenic HPV types has been identified as the necessary cause for the overwhelming majority of cancers of the cervix, it is not sufficient; OC use may represent an important cofactor. We identified 12 studies that assessed the risk of cervical cancer associated with OC use. Pooled results across 9 studies (representing 5,436 women across 6 studies and 3,981,072 person-years across 3 studies) found no significant increase in the risk of cervical cancer among ever users of OCs compared with never users. We also did not find a time-dependent relationship as a function of duration of OC use on cervical cancer. It is important to note that this contrast was underpowered with only five included studies. However, women who had long-term use of OCs (5 or more years) were at an elevated risk of cervical cancer compared with never users. Three studies (with 2592 subjects) assessed OC use and cervical cancer incidence among HPV-positive women. Results were similar to those of women not selected for HPV status. We only identified two studies that assessed the risk of cervical cancer mortality; results were mixed. Many studies did not control for factors that may influence risk, such as age at first OC use by duration or age at sexual debut, which is likely highly correlated with age at first use. Future research is needed to assess the additional cervical cancer risk associated with OC use among HPV-positive women. However, both studies reported statistically significant increased risk of death with 8 or more years of OC use compared with never use.

Results of this review differ in some ways from other evidence syntheses published over the last 10 years. Smith et al.50 pooled study-level data across 28 studies and found an overall significant increase in the risk of cervical cancer when comparing ever versus never users of hormonal contraceptives (RR 1.2; 95% CI,1.1 to 1.3). We found a similar increase in the risk of cervical cancers, but our summary estimate was not significant. Both our review and the Smith et al. study found the risk of cervical cancer increased with prolonged exposure. This effect weakened but remained significant when stratifying duration by time since use. For our review, this effect was only significant for women who used OCs for 5 or more years compared with never users; we did not have sufficient studies to stratify by time since last use. The International Collaborative of Epidemiological Studies of Cervical Cancer undertook a collaborative patient-level reanalysis of 24 observational studies.49 Results expand the duration by recency effect. The collaborative analysis found that excess risk of cervical cancers increase with duration of use, but this effect declined after discontinuing OCs and was equivalent to the risk of nonusers after 10 years of nonuse.

There are key methodological differences between our study and the two recent syntheses that preclude drawing exact comparisons. First, we only included studies of invasive cervical cancers; the other studies also included carcinoma in situ and cervical intraepithelial neoplasia grade 3 (CIN 3). It is likely that effects differ between invasive cancers and cancer-precursor lesions. In fact, a case-case comparison in the collaborative reanalysis demonstrated significant differences in the risks for in situ and invasive cervical cancers for nearly every category of time since last use by duration of use.

Second, we only included studies assessing the effects of oral contraceptives or presented those data separately; the two other recent syntheses included all forms of hormonal contraceptive. It is also possible that formulation differences contribute to some of the differences we found between our results and their findings. However, the collaborative reanalysis reported separate findings for progestogen-only injectable contraceptives and found a similar pattern to those reported for OCs.

Third, we did not include the three identified studies conducted with women selected for HPV infection status. The effects of this decision appear to be negligible; both prior reviews noted similar patterns of findings when controlling for HPV status as a covariate50 compared with HPV uncontrolled studies or among the subset of women with a confirmed HPV infection compared with populations not selected for HPV status.49

Fourth, we data-limited our search from 2000 forward in order to minimize the effect of older formulations that are no longer on the market; the other studies had no such date restrictions. Despite these differences, we found similar patterns of increased risk by duration of use. There is no direct evidence to suggest that cervical cancer screening recommendations should be different based on duration of OC use.

### Colorectal Cancer

Many studies have suggested a protective effect of reproductive factors such as OCs on colorectal cancer risk. We identified 11 studies involving 503,816 women across 8 studies and 2,969,189 person-years across 3 studies that assessed the risk of colorectal cancers associated with the use of OCs. We found that the risk of colorectal cancer was significantly decreased for women who had ever used OCs compared with women who never used OCs (OR 0.86; CI, 0.79 to 0.95). However, we found no evidence of a time-dependent relationship as a function of duration. We found no significant heterogeneity. Duration results should be interpreted with caution; the test was underpowered. We had insufficient studies to assess a trend based on time since last use. We also identified two population cohort studies that assessed burden of colorectal cancer mortality associated with OC use. Results were mixed and neither study achieved statistically significant findings. The other study showed an increase in colorectal cancer mortality associated with having ever used OCs. Both studies also assessed mortality as a function of duration of OC use; results showed no clear trend of a greater protective effect associated with longer duration of use.

Our results are similar to two other evidence syntheses that also assessed the risk of colorectal cancers associated with OC use.55,56 These meta-analyses both found a pooled relative risk of approximately 0.82, which is comparable to our pooled findings. These reviews also found no increase in the protective effect by duration of use. The similarity between our finding and those of the other two reviews is noteworthy. We limited our studies from January 2000 forward so that we had a greater probability of capturing a set of studies with newer OC formulations that may confer differential effects. Thus, we shared no studies in common with the Fernandez et al. study,55 excluded 12 older or non-English studies, and included five newer studies88,156,244,247,249 compared with the systematic review by Bosetti et al.56 Similarity in our findings with these earlier evidence syntheses suggest that newer formulations of OCs still confer a significant protective effect for colorectal cancer and future research may be conducted to investigate its potential as a beneficial therapy for chemoprevention.

### Endometrial Cancer

Estrogen and progestin both influence cell proliferation of endometrial tissue. Thus, we summarized the evidence on the use of OCs and risk of endometrial cancer incidence and mortality. We identified nine studies that evaluated the association between OC use and the incidence of endometrial cancers; seven studies were included in our meta-analysis to assess the effects of ever versus never use of OCs and represented 308,198 women across 4 studies and 3,981,072 person-years across 3 studies We found a significant protective effect associated with having ever used OCs (OR 0.57, 95% CI, 0.43-0.76). We also found a time-dependent relationship as a function of duration categorized as less than 60 months and 60 months or greater of total use. The duration trend was strong; however, the comparison of the two odds ratios was not significant, and heterogeneity limits conclusion about this analysis.

Our study is one of the few systematic reviews and meta-analyses to summarize the evidence on the effects of OCs on endometrial cancers. Grimes et al.256 conducted a systematic review and qualitative synthesis of studies up to 1993. They identified 13 case-control studies with protective odds ratios ranging from 0.1 to 0.6, with most effects clustering around 0.5 (CI not reported). Two of the three cohort studies identified also found protective effects of OC use on endometrial cancer incidence. Schlesselman et al.257 conducted a meta-analysis of 11 case-control studies. A significant duration trend was reported such that longer durations of use conferred greater protection against endometrial cancers (RR 0.44 for 4 years of use; RR 0.33 for 8 years of use; RR 0.28 for 12 years of use; p<0.0001). We found a similar trend but used a different analytic approach; direct comparisons are difficult to draw. This meta-analysis also reported on time since last use and found that the protective effect of OCs is diminished after they are discontinued but still persists even 20 years after cessation of use. We did not have sufficient studies to assess the effect of time since last use. Protective effect of OCs may vary with formulation. However, our results are similar to other studies conducted in the 1990s that may have included different formulations based on market availability. Our results—in combination with other evidence reviews—confirm that OCs confer a significant and lasting protective effect on the risk of endometrial cancers.

#### Issues Related to Cancer Screening

Of the five cancers considered in this report, effective screening is available for three: breast, cervical, and colorectal cancers. Differential screening behaviors among OC users and nonusers may affect both incidence and mortality, depending on the cancer targeted by screening.

As previously discussed, there are no effective screening tests for ovarian cancer, and although screening is possible for endometrial cancer, screening is not recommended outside of certain high-risk groups. Thus, the observed decrease in incidence and mortality for both cancers cannot be related to screening. However, as shown in Table 41, there is potential for confounding by variations in screening behaviors for the other cancers. This may be particularly important in U.S.-based studies, where there is much greater variation in access to screening, and where reproductive health services, including contraceptive services, have traditionally been closely linked with preventive care. Breast cancer screening primarily detects early malignancies, rather than preinvasive disease. Screened women will have a higher incidence (particularly at younger ages), but lower mortality, since effective treatment is available for many of these early malignancies. This is similar to the pattern observed in OC users, suggesting that some of the effects may be related to differential screening.

Table 41 Variation in screening behaviors by cancer type and potential confounding on incidence and mortality estimates

Cancer Type | Screening Detects | | Predicted Effect if OC Users More Likely To Be Screened | | Observed Effect in OC Users
Cancer Type | Preinvasive Disease | Early Invasive Disease | Incidence | Mortality | Incidence | Mortality
Breast | No | Yes | Increased | Decreased | Increased | Uncertain
Cervical | Yes | Yes | Decreased | Decreased | Increased | Increased
Colorectal | Yes | Yes | Decreased | Decreased | Decreased | Uncertain
Endometrial | No screening | No screening | None | None | Decreased | Decreased
Ovarian | No screening | No screening | None | None | Decreased | Decreased

OC = oral contraceptive

Conversely, cervical and colorectal cancer screenings detect both premalignant lesions and early cancers, leading to both decreased incidence and mortality. The observed protective association between OC use and colorectal cancer is consistent with this effect. However, the increased incidence associated with cervical cancer is in the opposite direction from any potential screening bias.

### Limitations

While we performed a comprehensive systematic review and evidence synthesis of the current research on OCs and breast, cervical, colorectal, and endometrial cancer, there are limitations to our approach and findings. First, as expected, we identified no randomized trials. Such studies are likely not feasible. Thus, we only included case-control, cohort, and pooled observational studies in our meta-analyses. Even the highest quality observational studies are susceptible to multiple forms of bias. The majority of studies in this review were rated good quality or fair quality as observational studies. Sensitivity analyses restricted to only good and fair studies found similar patterns of results.

Second, confounding is also another major limitation of observational studies. Again, most included studies adjusted for multiple likely sources of cofounding. When possible, we used the most adjusted point estimates in our meta-analyses. However, these covariates were not consistent between studies. Recall bias is also a common source of diminished quality in observational studies. Our findings were remarkably similar across case-control studies and cohort studies, which suggests a lack of evidence for recall bias of OC use across study types.

Third, we found significant heterogeneity across many of our comparisons. There are multiple potential sources of this heterogeneity. We included a diverse group of studies conducted across the world; differences in study populations and geographic variability in other risk factors not routinely assessed (e.g., access to health care) likely contributed to this heterogeneity. This may be particularly true for cancers such as breast, cervical, and colorectal where screening can affect both incidence and mortality, and where there may be associations between OC use and screening behaviors. Sensitivity analyses with only U.S.-based studies (or with patients from the United States) showed similar patterns to unrestricted analyses. Other potential sources of heterogeneity include change in patterns of OC use associated with delayed parity over the last 30 year, variable date of diagnosis, and change in OC formulations available on the market. While date limiting our review from 2000 forward likely diminished some of these sources of heterogeneity, this approach may not be adequate to control for these effects. Also, studies varied considerably in the type and specification of covariates across studies, which may be a likely source of heterogeneity.

Fourth, we found limited data on special populations. For breast cancer, we identified only three studies on the effect of OCs on women with family histories, only seven studies with BRCA1/2 carriers, and five studies related to subtypes of cancers. Studies with special populations for cervical, colorectal, and endometrial cancers were even more limited. Underlying risk factors related to family history or genetic mutation carrier status, tumor type, or health behaviors (e.g., smoking, obesity) may interact with OC use to attenuate or enhance effects. Thus, we are not able to make specific recommendations for specific populations.

Last, we date-limited our search to studies after 1999 in order to minimize the influence of older OC formulations that are no longer available on the U.S. market and increase generalizability for current clinical practice. However, study publication date is a gross estimate of OC formulation exposure since observational studies published after 1999 may still represent cohorts exposed to earlier formulations of OCs. It may have been preferable to limit studies on the basis of year of diagnosis than date of publication. However, many of our findings are consistent with other meta-analyses without date restrictions. This suggests that current OC formulations may have similar carcinogenic or protective effects compared with older formulations. However, given the long latent period between exposure and tumor development, recent publications may not fully assess the effect of formulations introduced in the past 20 years.

### Future Research

This comprehensive review of the literature on the risk of breast, cervical, colorectal, and endometrial cancers associated with OC use identified several gaps in the current state of the evidence that warrant future investigation. We detail these gaps below.

#### Special Populations

Several subgroups deserve further attention. There are limited data on the effects of OCs on cancer risk in women at elevated risk due to behavioral risk factors such as smoking, heavy alcohol consumption, obesity, or physical inactivity. These factors are known to be associated with cancer development; therefore, behavioral risk factors may modify the association between OCs and cancers. Moreover, we found limited studies with women of known genetic predisposition. Either known gene mutations that predispose to cancer or a strong family history can increase women's chance of breast, endometrial and colon cancers. These subgroups deserve further study as to whether they have the same or different benefit from OC use. Also, cancer is not a homogeneous disease; thus, certain types of tumors may differently be affected by OC use. Futures studies should assess the effectiveness of OCs among cancer subtypes. While it is unlikely and unfeasible that large randomized trials on the effect of OC use will be conducted, long-term prospective studies of adequate size could be beneficial in disentangling the effects of OC and cancer among special populations.

#### Interactions by Patterns of Use

Our findings demonstrate a statistically significant increase in breast cancer and a statistically significant decrease in colorectal and endometrial cancers for ever OC use versus never OC use. We found that duration of use conferred a different pattern of risks; however, we found limited support of a time-dependent relationship. These analyses were underpowered; we found significant heterogeneity. We also found limited data to assess a trend in time since last use, age at first use or age at last use. As the benefits and risks associated with OC use differ by pattern of use, more research is needed on the interaction of different patterns of use (e.g., duration by time since last use, age at initiation by duration) on the risk of breast, cervical, colorectal, and endometrial cancers in order to optimize the risks and benefits of OC use.

#### Newer OC Formulations

Our analyses were based on more recently published data than previous evidence syntheses; however, we found similar estimates associated with ever use. This suggests that the lower dose OCs that would have been used more commonly by those women included in more recently published studies confer similar effects than higher dose OCs on the risk of breast, cervical, endometrial, and colorectal cancers. However, continued investigation is needed. The long lag time for cancer development, and the potential for significant discrepancy between dates in which cohorts were assembled relative to publication dates, make it difficult to assess if we were successful in limiting this review to more modern formulations of OCs than prior evidence synthesizes. Thus, prospective studies with continued evaluation of effects by dose of OCs are warranted.

#### Population-based Mortality Studies

We found relatively few population-based studies that assessed the risk of breast, cervical, colorectal, and endometrial cancer mortality associated with OC use. Future research should continue to assess this relationship. Findings from both incidence and mortality studies are needed to assess if associations are related to enhanced or obstructed cell proliferation or screening uptake and adherence among OC users.

#### Patient-level Meta-analyses

Given the high levels of heterogeneity across comparisons, variability in measurement related to patterns of use, and limited data on special populations who may be differentially affected by the use of OCs, we acknowledge that a study-level meta-analysis may be inadequate to answer important questions in this area. Thus, patient-level meta-analysis may provide critical information to assess gaps related to interactions between patterns of use, effects by subpopulations, and specific estrogen and progestin formulations.

#### Study Design and Reporting

One step that would facilitate future systematic reviews would be standardization of categories and descriptive statistics for reporting results. While categorization choices will vary for individual studies, reporting of standardized results, perhaps as an appendix to the main analysis, would greatly improve the ability to combine published results in meta-analysis.