# Oral Contraceptives and Ovarian Cancer

## Background

Ovarian cancer has a lifetime incidence of about 1.4 percent and kills over 15,000 women in the United States annually.1 While the concept of an early detection strategy is attractive for this disease, no screening strategy has yet been proven effective.10 The stage distribution is weighted heavily toward Stage III and IV disease, suggesting that most ovarian cancers progress rapidly; indeed, a growing body of evidence suggests that many epithelial ovarian cancers initially arise in the epithelium of the fallopian tube. Based on this and pathogenetic evidence, the underlying biology of the disease may limit the potential effectiveness of screening to reduce morbidity and mortality from ovarian cancer.12,71 Alternative strategies, including the use of novel therapies and primary prevention, need to be considered and evaluated.

### Primary Prevention Strategies

Prevention strategies, including surgical prophylaxis and chemoprevention, may be of particular interest to women who are at an elevated risk of ovarian cancer due to a strong family history or a known inherited genetic mutation. Women who are carriers of genetic mutations in BRCA1 or BRCA2 are at markedly increased risk for ovarian cancer. A pooled analysis of 22 studies estimated the average risk of developing ovarian cancer by age 70 is 39 percent (95% confidence interval [CI], 18% to 54%) for BRCA1 mutation carriers and 11 percent (CI, 2.4% to 19%) for BRCA2 mutation carriers.72 Likewise, women with Lynch syndrome–associated MLH1 and MSH2 mutations have 20 percent (CI, 1% to 65%) and 24 percent (CI, 3% to 52%) risk, respectively, of developing ovarian cancer by the same age.73 Although the prevalence of genetic mutations predisposing women to ovarian cancer in the general population is low (approximately 0.12% for BRCA1 and 0.2% for BRCA2),74 the high risk of cancer among women who are mutation carriers underscores the importance of understanding factors that may modify their likelihood of developing cancer.

Oral contraceptives (OCs) represent a potentially promising primary prevention strategy for ovarian cancer. Several large pooled analyses suggest that OCs confer a protective effect on ovarian cancer risk, with a reduction in risk of up to 50 percent with long-term use of OCs.21-24 The largest pooled analysis to date estimates that OC use has already prevented 200,000 cases of ovarian cancer and 100,000 deaths from this disease worldwide.21

In women at high risk of developing ovarian cancer due to family history or a known genetic mutation, the effect of OC use on ovarian cancer risk is relevant for multiple reasons. First, the incomplete penetrance of hereditary cancer genes suggests that there are other factors—either environmental or genetic—that affect whether or not women who are mutation carriers develop ovarian cancer. Thus, from an etiologic standpoint, it is important to understand whether a common environmental exposure such as OCs influences the risk of developing ovarian cancer among mutation carriers. Second, women who are at high genetic risk have a need to understand the options available for reducing morbidity and mortality from ovarian cancer.

The choice of a risk-reduction strategy for women at elevated risk is an individual choice and commonly includes screening strategies and prophylactic surgery. Unfortunately, screening high-risk women with available modalities has not yet proven successful.75-77 In a BRCA1/2 mutation–carrying population, bilateral salpingo-oophorectomy (BSO) has been demonstrated to reduce the risk of ovarian, tubal, or peritoneal cancers by 80 percent and the risk of breast cancer by 50 percent.14 In addition, several groups have used health-economic decision models to suggest that prophylactic surgery is both effective and cost-effective in the BRCA carrier population.15,16 However, surgical prophylaxis is accompanied both by potential harms and the certain premature loss of ovarian function. Despite the effectiveness of prophylactic BSO, some women at high risk prefer alternatives that are less invasive, do not result in early menopause, and preserve fertility. The Gynecologic Oncology Group is currently completing a nonrandomized prospective trial comparing longitudinal screening with CA-125 and ultrasound to risk-reducing BSO in a high genetic risk population.78 This trial includes both subsequent cancer diagnoses and quality-of-life assessments and may be informative from a comparative effectiveness standpoint.

Chemoprevention may be a viable option for ovarian cancer risk reduction, and particularly among women at high genetic risk. If OCs confer a comparable reduction in ovarian cancer risk in genetic mutation carriers as that observed in the general population, they could be a reasonable chemoprevention strategy for those who have not completed childbearing or who wish to avoid surgery.

In Section 2 of our systematic review and meta-analysis, we quantify the potential benefits of OC use in reducing the incidence of ovarian cancer. We address the effect of OCs on ovarian cancer risk, both in the general population and in specific populations of interest, as well as examining relationships between specific characteristics of OC use and ovarian cancer incidence and mortality.

## Relevant Key Questions

The seven KQs developed for the entire systematic review are listed in Section 1 (refer to Figure 7 for a roadmap of this report). For Section 2, we performed a systematic review and meta-analysis of three of the seven KQs that address the effectiveness of OCs in reducing the risk of developing ovarian cancer:

KQ 1: What is the effectiveness of combined (estrogen and progestin containing) and progestin-only OCs for reducing the risk of ovarian cancer?

KQ 2: Do specifics of OC use (e.g., dose/formulation, age at initiation, duration of use) affect the relative risk of developing ovarian cancer?

KQ 3: Does the use of OCs by specific populations of women (e.g., those defined by age, family history of breast and ovarian cancer, BRCA1/BRCA2 mutation status, parity) affect the relative risk of developing ovarian cancer?

### Analytic Framework

Figure 9 shows the analytic framework that guided this section of the review.

Figure 9 Analytic framework for OCs and ovarian cancer

BRCA = breast cancer genetic mutation; KQ = Key Question; OC = oral contraceptive

Description: Figure 9 depicts Key Questions 1-3 within the context of the PICO (population, interventions, comparators, and outcomes) that will be the focus of Section 2, Oral Contraceptives and Ovarian Cancer.

## Methods

### Inclusion and Exclusion by PICOTS

Table 4 describes the PICOTS criteria that guided the literature search for this section of the review.

Table 4 Summary of inclusion and exclusion criteria for OCs and ovarian cancer

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | - All KQs; ○ Women taking OCs for contraception or women taking OCs for primary prevention of ovarian cancer^a^; ○ Women who do not have a history of ovarian cancer and have not undergone bilateral oophorectomy; - KQ 3:; ○ Women with a strong family history of ovarian or premenopausal breast cancer; ○ Women with a known BRCA1/BRCA2 mutation | Nonhuman studies
Interventions | OC use (includes OC use for varying time periods and OC use with different formulations) | None
Comparators | No use of combination or progestin-only OCs, including either no contraceptive method at all or contraceptive methods other than combination or progestin-only OCs (e.g., natural family planning, barrier methods, sterilization, intrauterine devices, injectable or implantable hormonal contraception) | Study does not include controls; i.e., an estimate of outcomes in women not using OCs (population estimates are acceptable)
Outcomes | Study reports quantitative association between exposure to OCs and either ovarian cancer incidence or ovarian cancer mortality | Study only reports outcomes related to assisted reproductive technologies or abortion
Timing | Studies of any duration | None
Setting | All settings | None
Study design | - Controlled studies (randomized trials, cohort studies, case-control studies), pooled patient-level meta-analyses, or systematic reviews and study-level meta-analyses^b^; - Study sample size ≥ 100 subjects for nonrandomized studies^c^ | - Not a clinical study (e.g., editorial, non–systematic review, letter to the editor); - Exploratory study with inadequate sample size
Publications | - English-language only; - Peer-reviewed articles; - Study reports an ovarian cancer outcome of interest and was published on or after 01-Jan-1990^d^ | Non-English articles^e^

KQ = Key Question; OC = oral contraceptive

a If the purpose of OC use was unclear, it was assumed to be contraception.

b Systematic reviews and study-level meta-analyses were excluded from abstraction; those representing key sources were hand-searched as potential sources of additional material.

c Small nonrandomized studies <100 subjects were excluded as confidence intervals for outcomes of interest are generally quite wide if appropriate adjustment for confounding is performed, and variability in reporting of potential confounders makes meta-analysis problematic.

d We considered studies published from January 2000 to June 2012 for the primary ovarian cancer outcome analyses. Older data (with publication dates beginning January 1990) were used to conduct sensitivity analyses allowing us to compare the results from the January 2000 to June 2012 analyses with those from a longer date range (January 1990 to June 2012).

e Non-English articles were excluded (1) due to the high volume of literature available in English-language publications (including the majority of known important studies) and (2) due to concerns about the applicability of non-English publication studies to populations in the United States. The variability in OC formulations approved for use across countries increases the likelihood that non-English language studies would include OCs not available or not in use in the United States.

### Meta-Analytic Methods

To examine quantitatively the effect of OCs on the risk of ovarian cancer, we performed meta-analyses on the following relationships:

- Ever OC use
- Temporal relationships:
  ○ Duration of OC use
  ○ Age at first OC use
  ○ Time since last OC use
- OC formulation:
  ○ Estrogen
  ○ Progestin
- Special populations:
  ○ BRCA1 and BRCA2 genetic mutation carriers
  ○ Family history
  ○ Parity/gravidity

To perform a meta-analysis, we required that at least three individual studies address the relationship in question. Each included study must also report odds ratios and either report 95 percent confidence intervals (95% CIs) or provide sufficient data to allow us to calculate the 95% CI describing the relationship. We performed meta-analyses using Comprehensive Meta-Analysis Version 2 (Biostat; Englewood, NJ; 2005).68 All analyses were done using a random-effects model.

Confidence intervals from the included study publications were entered into the Comprehensive Meta-Analysis (CMA) program. However, many of these confidence intervals had been rounded to a single decimal place. The CMA program checks the intervals for symmetry in the logarithmic scale. In certain cases, the rounded limits were not accepted by CMA. In such cases, we kept the point estimate as given but changed the confidence limits so that they were symmetric. This resulted in slight differences in the confidence intervals in the forest plots when compared with the study publications.

#### Pooled Analyses

We included pooled analyses in our meta-analyses if all three of the following conditions were met:

1. None of the individual studies included in the pooled analysis had already been included for meta-analysis.
2. At least half of the studies in the pooled analysis were published on or after January 1, 2000.
3. Data in the pooled analyses were presented such that their inclusion in the current meta-analysis was feasible.

#### Ever OC Use

For the primary ever OC use meta-analysis, we excluded studies that reported effects for only a particular subpopulation (e.g., studies reporting odds ratios only for women with a BRCA mutation) but not the effects for the general population. (Separate analyses were performed for the subpopulations of BRCA mutation carriers and are described below.) Studies that reported ever OC use odds ratios for two or more mutually exclusive subpopulations (e.g., mucinous and nonmucinous tumors) were included in the meta-analysis, and results for the subpopulations were combined.

#### Temporal Relationships

Evaluation of clinical relationships for which multiple temporal stratifications were possible—such as duration of OC use, age at first OC use, and time since last OC use (recency)—required creation of several additional simplifying assumptions:

- To facilitate identification of any existing dose-response or duration-response effects, we included only studies that reported odds ratios for at least three different time intervals. Studies that had a median split often had that split in the first interval. Thus, the rate for the upper half would be used to help estimate the rate for all three intervals. It seemed as if this would dilute any dose-response relationship.
- We required that the odds ratios were reported relative to no OC use.

##### Duration of OC Use

The challenge of performing a meta-analysis on duration of OC use is that individual studies reported the odds ratios for different duration intervals. Simplifying assumptions for this analysis are listed above. We assumed that each odds ratio, OR_ij_, could be described by the following model:

Ln [ OR_ij_ ] = α_i_ + ∑_j = 1_^k^ X_ij_ β_j ,_

where i denotes the study, j denotes the specific time interval, and k is the number of time intervals used in the model. The α_i_ are assumed to be random and normal with mean 0 and variance (SE_ij_^2^ + σ^2^). SE_ij_ is the standard error of the j^th^ odds ratio from the i^th^ study. σ^2^ is the extra variation from the random effects model. The x_ij_ are the fixed terms that describe the time period covered by that particular odds ratio. The β_j_ (j=1, … , k) are the odds ratios to be estimated for each duration interval.

We originally assumed that there was a term for each year (up to 10) and a final term for greater than 10 years. However, the large number of terms resulted in very unstable estimates. For that reason, we broke the time points into 4 intervals: (1) 1 to 12 months, (2) 13 to 60 months, (3) 61 to 120 months, and (4) more than 120 months. We then used the x_ij_ to create the time period desired. For example, if the first interval were from 1 to 36 months, then the vector of x_ij_ would be (1/3, 2/3, 0, 0, 0). This would reflect that one-third of the patients in the interval were in the 1 to 12 month interval and two-thirds of the patients were in the 13 to 60 month interval. Using this methodology, any interval could be described.

The model was fitted using SAS PROC NLMIXED (SAS Institute Inc.; Cary, NC; 2009) with “subject” set to the particular study, i.

##### Age at First OC Use

Using the equation above, we assumed that there were only four different intervals for age at first use: (1) under 20 years of age, (2) 20 to 24 years of age, (3) 25 to 30 years of age, and (4) over 30 years of age. We then used the x_ij_ to create the time period desired. For example, if the second interval from a particular study were from 20 to 28 years of age, then the vector of x_ij_ would be (0, 1/2, 1/2, 0, 0). This would reflect that half the patients in the interval were in the 20 to 24 year interval and half the patients were in the 25 to 30 year interval. Using this methodology, any interval could be described.

##### Time Since Last OC Use

Using the equation above, we broke time since last OC use into 4 intervals: (1) 0 to 10 years, (2) 10 to 20 years, (3) 20 to 30 years, and (4) more than 30 years. We then used the x_ij_ to create the time period desired. For example, if the first interval were from 1 to 15 years, then the vector of x_ij_ would be (2/3, 1/3, 0, 0, 0). This would reflect that two-thirds of the patients in the interval were in the 0 to 10 year interval and one-third of the patients were in the 10 to 20 year interval. Using this methodology, any interval could be described.

#### OC Formulation

##### Estrogen

Studies were included in the meta-analysis if they reported the effect of low-dose and/or high-dose estrogen-containing OCs on ovarian cancer incidence and included methodology regarding the definition of low- and high-dose estrogen.79,80 For studies that presented estrogen dose results stratified by low or high progestin dose, odds ratios for groups with identical estrogen doses were combined across progestin arms using an inverse weighted meta-analysis. In order to compare high- to low-dose estrogen, we included those studies that had odds ratios for each with “never use” as a reference category and divided the high-dose odds ratio by the low-dose odds ratio. This has the effect of canceling out the never-use category. All analyses were made using a random-effects model.

##### Progestin

Studies were included in the meta-analysis if they reported the effect of low- and/or high-dose progestin on ovarian cancer incidence and presented an established reference for determination of progestin potency. For studies that stratified these results based on low or high estrogen dose, odds ratios for identical progestin dose groups were combined across estrogen arms using an inverse weighted meta-analysis. In order to compare high- to low-dose progestin, we included those studies that had odds ratios for each with “never use” as a reference category and divided the high-dose odds ratio by the low-dose odds ratio. This has the effect of canceling out the never-use category. All analyses were made using a random-effects model.

#### Special Populations

##### BRCA Mutation Carriers

Studies were included in the meta-analyses of BRCA mutation carriers if they reported the effect of OCs on ovarian cancer risk comparing mutation carriers with ovarian cancer to unaffected mutation carriers. The analyses were restricted to these study populations because they address the most relevant clinical question: If a woman tests positive for mutations in BRCA1 or BRCA2, can she reduce her risk for ovarian cancer by taking OCs? Studies that compare cases who are mutation carriers with controls who are not mutation carriers do not provide a direct answer to the clinical question because the comparison involves both a genetic factor (BRCA1 or BRCA2 mutation) and an environmental factor (OC use)—this study design does not allow us to sort out the relative contributions of these factors to ovarian cancer risk. Separate meta-analyses were performed for studies reporting results for BRCA1 mutation carriers, BRCA2 mutation carriers, and BRCA1 and BRCA2 mutation carriers combined.

##### Family History of Ovarian Cancer

Studies were considered eligible for inclusion if they reported the effect of OCs on ovarian cancer risk stratified by family history.

##### Parity/Gravidity

Studies were included in the meta-analysis if they reported the effect of OCs on ovarian cancer risk stratified by parity or gravidity. We did not distinguish between parity and gravidity in our analyses. For studies that split parity into multiple categories (i.e., 0, 1, 2, 3+), the results were combined across parity categories using an inverse weighted meta-analysis, and these were labeled parity 1+. To compare parity 0 to parity 1+, we computed the ratio of the parity 0 odds ratio and the parity 1 odds ratio for each study. This has the effect of canceling out the never-use category, which is the reference. All analyses were performed using a random-effects model.

## Results

This section presents results of our detailed analysis of the relationship between OCs and ovarian cancer incidence and ovarian cancer mortality.

### OC Use and Ovarian Cancer Incidence

We identified 55 studies that evaluated the association between OC use and the incidence of ovarian cancer.21,23,24,29,37,81-162 In Table 5, we list the studies that reported odds ratios for ever versus never OC use. Of these studies, 28 were case-control studies, 10 were cohort studies, and the remaining 4 were pooled analyses. Of the case-control and cohort studies, 17 studies were rated good quality, 20 fair quality, and 5 poor quality. (As described in the Methods, studies represented by multiple articles and abstracted into more than one dataset may be counted in more than one quality category. Quality ratings specific to each of these datasets are provided in Table 5). Note that none of the pooled analyses met criteria for inclusion in the meta-analyses examining OC use and ovarian cancer incidence.

Table 5 Study characteristics and association between OC use and ovarian cancer incidence

Study^a^ | Study Details | OR | 95% CI | Covariates | Region | Study Quality | Meta-Analysis Code^b^
Case-Control
Gwinn, 1990^96^ | Women <55 yr enrolled in the Cancer and Steroid Hormone Study [underlined: Cases:] 436 epithelial ovarian cancers including borderline tumors [underlined: Controls]: 3833 population-based controls | 0.566 | 0.48 to 0.69 | Age, parity, breastfeeding | U.S. | Good | 8
Parazzini, 1991^128^ | Italian women <60 yr [underlined: Cases:] 505 epithelial ovarian cancers [underlined: Controls]: 1375 hospital-based controls | 0.7 | 0.5 to 1.0 | Age, parity, menopausal status, age at menarche, education, marital status, lifelong menstrual pattern, age at menopause | Europe | Good | 3^127^
Parazzini, 1991^128^ | Parity 0 [underlined: Cases:] 137 epithelial ovarian cancers [underlined: Controls]: 273 hospital-based controls | 0.6 | 0.3 to 1.3 | Age, parity, menopausal status, age at menarche, education, marital status, lifelong menstrual pattern, age at menopause | Europe | Good | 3^127^
Parazzini, 1991^128^ | Parity 1-2 [underlined: Cases:] 266 epithelial ovarian cancers [underlined: Controls]: 795 hospital-based controls | 0.5 | 0.3 to 0.9 | Age, parity, menopausal status, age at menarche, education, marital status, lifelong menstrual pattern, age at menopause | Europe | Good | 3^127^
Parazzini, 1991^128^ | Parity 3+ [underlined: Cases:] 102 epithelial ovarian cancers [underlined: Controls]: 307 hospital-based controls | 0.8 | 0.3 to 1.7 | Age, parity, menopausal status, age at menarche, education, marital status, lifelong menstrual pattern, age at menopause | Europe | Good | 3^127^
Parazzini, 1991^129^ | Italian women <65 yr with borderline tumors [underlined: Cases:] 91 borderline ovarian tumors [underlined: Controls]: 273 hospital-based controls | 0.3 | 0.2 to 0.6 | Age, parity, education, age at menopause | Europe | Good | 8
Thomas, 1991^150^ | WHO Collaborative Study of Neoplasia and Steroid Contraceptives [underlined: Cases:] 368 epithelial ovarian cancers [underlined: Controls]: 2397 hospital-based controls | 0.75 | 0.56 to 1.01 | Age, parity, hospital, year of interview | Europe, Asia, Africa, Australia/NZ, Israel, Mexico | Fair | 8
Thomas, 1991^150^ | Borderline tumors Cases and controls: NR | 0.81 | 0.45 to 1.47 | Age, parity, hospital, year of interview | Europe, Asia, Africa, Australia/NZ, Israel, Mexico | Fair | 8
Thomas, 1991^150^ | Invasive ovarian cancer Cases and controls: NR | 0.72 | 0.51 to 1.02 | Age, parity, hospital, year of interview | Europe, Asia, Africa, Australia/NZ, Israel, Mexico | Fair | 8
Thomas, 1991^150^ | Nulliparous women Cases and controls: NR | 0.16 | 0.05 to 0.54 | Age, parity, hospital, year of interview | Europe, Asia, Africa, Australia/NZ, Israel, Mexico | Fair | 8
Thomas, 1991^150^ | Parous women Cases and controls: NR | 0.85 | 0.63 to 1.16 | Age, parity, hospital, year of interview | Europe, Asia, Africa, Australia/NZ, Israel, Mexico | Fair | 8
Badawy, 1992^82^ | Saudi Arabian women [underlined: Cases:] 52 ovarian cancer cases [underlined: Controls]: 52 population-based controls | 0.4 | 0.2 to 0.8 | None | Saudi Arabia | Poor | 8
Poly-chronopoulou, 1993^131^ | Greek women age <75 yr [underlined: Cases:] 189 malignant epithelial ovarian tumors [underlined: Controls]: 200 population-based controls | 0.8 | 0.17 to 3.67 | Age, parity, menopausal status, age at menarche, smoking, education, weight, age at menopause, coffee, alcohol, age at first birth | Europe | Poor | 8
Rosenberg, 1994^137^ | Women age <65 yr [underlined: Cases:] 441 invasive ovarian cancer cases [underlined: Controls]: 2065 hospital-based controls | 0.8 | 0.6 to 1.0 | Age, race, parity, family history, hysterectomy, tubal ligation, removal of one ovary, geographic area, interview year | U.S. | Fair | 8
Narod, 1998^122^ | International consortium of women with BRCA1/2 mutations [underlined: Cases:] 207 invasive epithelial ovarian cancer [underlined: Controls]: 161 sisters of women with mutations and ovarian cancers | 0.5 | 0.3 to 0.8 | Age, parity, age at first birth, geographic area of residence | U.S., Canada, UK, Europe | Fair | 2
Narod, 1998^122^ | [underlined: Cases:] 207 invasive epithelial ovarian cancer [underlined: Controls]: 53 sisters of women with mutations and ovarian cancers who are also known mutation carriers without a personal history of ovarian cancer | 0.4 | 0.2 to 0.7 | Age, parity, age at first birth, geographic area of residence | U.S., Canada, UK, Europe | Fair | 2
Wittenberg, 1999^161^ | Mucinous ovarian cancers [underlined: Cases:] 43 mucinous epithelial ovarian cancers [underlined: Controls]: 426 population-based controls | 0.9 | 0.4 to 2.1 | Age, parity, duration of OC use | U.S. | Fair | 8
Wittenberg, 1999^161^ | Nonmucinous ovarian cancers [underlined: Cases:] 279 nonmucinous epithelial ovarian cancers [underlined: Controls]: 426 population-based controls | 0.8 | 0.6 to 1.3 | Age, parity, duration of OC use | U.S. | Fair | 8
Beard, 2000^83^ | Olmstead County women [underlined: Cases:] 103 women with invasive epithelial ovarian cancers [underlined: Controls]: 103 population-based controls | 1.1 | 0.6 to 2.3 | No adjustment, but matched by age | U.S. | Fair | 1
Greggi, 2000^93^ | Italian women [underlined: Cases:] 440 epithelial ovarian cancer [underlined: Controls]: 868 hospital-based controls | 0.4 | 0.3 to 0.6 | Age, parity, family history, breastfeeding , education, OC use, age at first birth, breast feeding, duration of use | Europe | Good | 1
Ness, 2000^125^ | SHARE Study participants age <70 yr [underlined: Cases:] 767 [underlined: Controls]: 1367 | 0.6 | 0.5 to 0.8 | Age, race, family history, number of pregnancies | U.S. | Good | 1
Parazzini, 2000^127^ | Italian women [underlined: Cases]: 971 epithelial ovarian cancer cases [underlined: Controls]: 2758 hospital-based controls | 1.2 | 1.0 to 1.7 | Age, parity, calendar year of interview, age at menopause, family history of breast or ovarian cancer, green vegetable consumption, fat-intake score | Europe | Good | 1
Sanderson, 2000^143^ | White women age <70 yr [underlined: Cases:] 276 epithelial ovarian cancer cases [underlined: Controls]: 388 population-based controls | 0.8 | 0.5 to 1.1 | Age, parity | U.S. | Good | 1
Siskind, 2000^145^ | Australian women Nonmucinous ovarian cancers [underlined: Cases:] 677 [underlined: Controls]: 853 | 0.64 | 0.48 to 0.85 | Age, parity, BMI, family history, breastfeeding , age squared, alcohol, hysterectomy, tubal, infertility, number of lifetime ovulation | Australia/NZ | Good | 1^144^
Siskind, 2000^145^ | Mucinous ovarian cancers [underlined: Cases:] 114 [underlined: Controls]: 853 | 0.61 | 0.36 to 1.04 | Age, parity, BMI, family history, breastfeeding , age squared, alcohol, hysterectomy, tubal, infertility, number of lifetime ovulation | Australia/NZ | Good | 1^144^
Chiaffarino, 2001^87^ | Italian women [underlined: Cases:] 1031 ovarian cancer cases [underlined: Controls]: 2411 hospital-based controls | 0.9 | 0.7 to 1.2 | Age, parity, family history, center, education | Europe | Fair | 1
Riman, 2001^133^ | Swedish women with borderline ovarian tumors [underlined: Cases:] 193 borderline cases [underlined: Controls]: 3899 population-based controls | 1.23 | 0.86 to 1.76 | Age, parity, BMI, age menopause, HRT | Europe | Fair | 1
Royar, 2001^141^ | German women [underlined: Cases:] 282 invasive ovarian cancer cases [underlined: Controls]: 533 population-based controls | 0.48 | 0.33 to 0.68 | Parity, Family History, Breastfeeding , tubal ligation, hysterectomy | Europe | Fair | 1
Riman, 2002^134^ | Swedish women with epithelial ovarian cancer [underlined: Cases:] 655 ovarian cancer cases [underlined: Controls]: 3899 population-based controls | 0.73 | 0.59 to 0.90 | Age, parity, BMI, age at menopause, HRT | Europe | Fair | 1
Tung, 2003^152^ | Residents of Hawaii or Los Angeles County [underlined: Cases:] 603 ovarian cancer cases [underlined: Controls]: 607 population-based controls | 0.6 | 0.4 to 0.8 | Age, race, parity, study site, education, tubal ligation | U.S. | Good | 3^114^
McGuire, 2004^115^ | Women in Northern California Women with BRCA1 mutations [underlined: Cases:] 36 epithelial ovarian cancer cases [underlined: Controls]: 568 population-based controls | 0.54 | 0.26 to 1.13 | Age, race, parity | U.S. | Good | 1
McGuire, 2004^115^ | Women without BRCA1 mutations [underlined: Cases:] 381 epithelial ovarian cancer cases [underlined: Controls]: 568 population-based controls | 0.55 | 0.41 to 0.73 | Age, race, parity | U.S. | Good | 1
Whittemore, 2004^159^ | International database of BRCA1/2 carriers [underlined: Cases:] 147 BRCA carriers with epithelial ovarian cancer [underlined: Controls]: 304 BRCA carriers without epithelial ovarian cancer | 0.85 | 0.53 to 1.4 | Age, parity, center | U.S., Canada, UK, Australia/NZ | Fair | 2
Quirk, 2004^132^ | Women from Roswell Park Cancer Institute, New York [underlined: Cases:] 418 invasive ovarian cancer cases [underlined: Controls]: 836 hospital-based controls | 1.22 | 0.88 to 1.68 | Age, parity, family history, history of tubal ligation, noncontraceptive estrogen use | U.S. | Poor | 1
Greer, 2005^91^ | Women from the Study of Health and Reproduction (SHARE) [underlined: Cases:] 405 [underlined: Controls]: 592 | 0.52 | 0.35 to 0.76 | Age, parity, family history, BTL | U.S. | Fair | 3^125^
Greer, 2005^91^ | Compared never users with nonandrogenic OC users [underlined: Cases:] 381 [underlined: Controls]: 761 | 0.59 | 0.45 to 0.78 | Age, parity, family history, BTL | U.S. | Fair | 3^125^
Greer, 2005^91^ | Compared never users with both androgenic and nonandrogenic OC users [underlined: Cases:] 364 [underlined: Controls]: 529 | 0.29 | 0.17 to 0.48 | Age, parity, family history, BTL | U.S. | Fair | 3^125^
Gronwald, 2006^94^ | Polish BRCA1 carriers [underlined: Cases:] 150 ovarian cancer cases [underlined: Controls]: 150 population-based controls | 0.4 | 0.2 to 1.0 | None | Europe | Fair | 2
Huusom, 2006^107^ | Women participating in the MALOVA study [underlined: Cases:] 202 ovarian borderline cases [underlined: Controls]: 1564 population-based controls | 0.81 | 0.56 to 1.16 | Age, parity, smoking, breastfeeding , age at first birth, duration of contraception use, intake of milk | Denmark | Fair | 1
Lurie, 2007^113^ | Residents of Hawaii or Los Angeles County [underlined: Cases:] 745 epithelial ovarian cancer cases [underlined: Controls]: 943 population-based controls | 0.51 | 0.26 to 0.98 | Unclear | U.S. | Good | 3^114^
McLaughlin, 2007^116^ | International consortium of women with BRCA1 and/or BRCA2 mutations [underlined: Cases:] 799 mutation carriers with ovarian cancer [underlined: Controls]: 2424 mutation carriers without ovarian cancer | 0.53 | 0.43 to 0.66 | Parity, breastfeeding , tubal ligation, ethnicity | U.S., Canada, UK, Europe, Asia | Good | 2
McLaughlin, 2007^116^ | BRCA1 carriers only [underlined: Cases:] 670 mutation carriers with ovarian cancer [underlined: Controls]: 2043 mutation carriers without ovarian cancer | 0.56 | 0.45 to 0.71 | Parity, breastfeeding , tubal ligation, ethnicity | U.S., Canada, UK, Europe, Asia | Good | 2
McLaughlin, 2007^116^ | BRCA2 carriers only [underlined: Cases:] 128 mutation carriers with ovarian cancer [underlined: Controls]: 380 mutation carriers without ovarian cancer | 0.39 | 0.23 to 0.66 | Parity, breastfeeding , tubal ligation, ethnicity | U.S., Canada, UK, Europe, Asia | Good | 2
Soegaard, 2007^146^ | Women participating in the MALOVA study [underlined: Cases:] 554 ovarian cancer cases [underlined: Controls]: 1564 population-based controls | 0.67 | 0.53 to 0.85 | Age, parity | Denmark | Good | 1
Soegaard, 2007^146^ | Mucinous ovarian cancers [underlined: Cases:] 50 ovarian cancer cases [underlined: Controls]: 1564 population-based controls | 0.49 | 0.25 to 0.97 | Age, parity | Denmark | Good | 1
Soegaard, 2007^146^ | Serous ovarian cancers [underlined: Cases:] 343 ovarian cancer cases [underlined: Controls]: 1564 population-based controls | 0.7 | 0.52 to 0.94 | Age, parity | Denmark | Good | 1
Soegaard, 2007^146^ | Endometrioid ovarian cancers [underlined: Cases:] 75 ovarian cancer cases [underlined: Controls]: 1564 population-based controls | 0.76 | 0.42 to 1.35 | Age, parity | Denmark | Good | 1
Soegaard, 2007^146^ | “Other” histologic types of ovarian cancer [underlined: Cases:] 86 ovarian cancer cases [underlined: Controls]: 1564 population-based controls | 0.62 | 0.36 to 1.06 | Age, parity | Denmark | Good | 1
Lurie, 2008^114^ | Residents of Hawaii or Los Angeles County [underlined: Cases:] 813 epithelial ovarian cancer cases [underlined: Controls]: 993 population-based controls | 0.59 | 0.42 to 0.84 | Age, race, menopausal status, family history, education, gravidity, age at last pregnancy, tubal ligation, OC potency, hysterectomy, age at menopause, use of menopausal hormones | U.S. | Good | 1
Moorman, 2008^121^ | Women in the North Carolina Ovarian Cancer Study Premenopausal [underlined: Cases:] 314 epithelial ovarian cancer cases [underlined: Controls]: 360 population-based controls | 0.5 | 0.3 to 0.8 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | U.S. | Good | 1
Moorman, 2008^121^ | Postmenopausal [underlined: Cases:] 582 epithelial ovarian cancer cases [underlined: Controls]: 607 population-based controls | 0.8 | 0.6 to 1.1 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | U.S. | Good | 1
Boyce, 2009^84^ | Granulosa cell tumors [underlined: Cases:] 72 GCT cases [underlined: Controls]: 1578 population-based controls | 0.32 | 0.17 to 0.63 | Age, race | U.S. | Fair | 4
Boyce, 2009^84^ | Granulosa cell tumors vs. epithelial ovarian cancer [underlined: Cases:] 72 GCT cases [underlined: Controls]: 1511 epithelial ovarian cancer cases | 0.6 | 0.32 to 1.14 | Age, race | U.S. | Fair | 4
Ness, 2011^123^ | HOPE study participants [underlined: Cases:] 869 women with invasive and borderline ovarian cancer [underlined: Controls]: 1779 population-based controls | 0.67 | 0.55 to 0.81 | Age, race, family history, gravidity, infertility, ever use of IUDs or barrier contraceptives, tubal ligation, and vasectomy | U.S. | Good | 1
Urban, 2012^155^ | Black South African women aged 18–79 yr [underlined: Cases]: 182 ovarian cancer cases [underlined: Controls]: 1492 women with cancers with no known relationship to oral or injectable contraception Recruitment period: 1995–2006 | 0.88 | 0.52 to 1.50 | Age, parity, smoking, year of diagnosis, education, alcohol consumption, number of sexual partners, urban/rural residence, province of birth | South Africa | Good | 1
Wilailak, 2012^160^ | Thai women [underlined: Cases]: 330 epithelial ovarian cancer cases [underlined: Controls]: 982 hospital-based controls | 0.71 | 0.51 to 0.98 | Parity, family history, breastfeeding, depot medroxyprogesterone acetate use | Thailand | Fair | 1
Cohort
Hankinson, 1995^98^ | Nurses' Health Study [underlined: Exposed]: 592,056 person-years OC exposed [underlined: Unexposed]: 599,301 person-years OC unexposed | 1.08 | 0.83 to 1.43 | Age, parity, menopausal status, age at menarche, smoking, BTL, Quetelet's Index | U.S. | Fair | 8
Vessey, 1995^157^ | Oxford Family Planning Association Contraceptive Study [underlined: Exposed]: 3520 women >8 years OC exposed [underlined: Unexposed]: 5881 women OC unexposed | 0.4 | 0.2 to 0.8 | Age, parity | UK | Poor | 3^156^
Kumle, 2004^110^ | Norwegian-Swedish Women's Lifestyle and Health cohort [underlined: Exposed:] 75,533 women OC exposed [underlined: Unexposed]: 28,019 women OC unexposed | 0.6 | 0.5 to 0.8 | Age, parity, menopausal status, HRT, country | Europe | Fair | 1
Kumle, 2004^110^ | Invasive ovarian cancers | 0.6 | 0.4 to 0.8 | Age, parity, menopausal status, HRT, country | Europe | Fair | 1
Kumle, 2004^110^ | Borderline ovarian tumors | 0.7 | 0.5 to 1.2 | Age, parity, menopausal status, HRT, country | Europe | Fair | 1
Vessey, 2006^156^ | Oxford Family Planning Association Contraceptive Study [underlined: Exposed]: 301,000 person-years OC exposed [underlined: Unexposed]: 187,000 person-years OC unexposed | 0.5 | 0.3 to 0.7 | Age, parity, BMI, smoking, social class, height, age at first term pregnancy, age at first marriage | UK | Good | 1
Hannaford, 2007^37^ | Royal College of General Practitioners Oral Contraception Study Main dataset [underlined: Exposed:] 744,000 person-years of observation [underlined: Unexposed]: 339,000 person-years of observation | 0.54 | 0.40 to 1.71 | Age, parity, smoking, social status | UK | Fair | 1
Hannaford, 2007^37^ | General practitioner dataset [underlined: Exposed]: 744,000 person-years of observation [underlined: Unexposed]: 339,000 person-years of observation | 0.51 | 0.33 to 0.78 | Age, parity, smoking, social status | UK | Fair | 1
Antoniou, 2009^81^ | International BRCA1/2 Carrier Cohort Study BRCA1/2 mutation carriers [underlined: Exposed]: 2415 women OC exposed [underlined: Unexposed]: 766 women OC unexposed | 0.55 | 0.40 to 0.76 | Parity | Canada, UK, Europe | Fair | 2
Antoniou, 2009^81^ | BRCA1 mutation carriers [underlined: Exposed]: 1655 women OC exposed [underlined: Unexposed]: 512 women OC unexposed | 0.52 | 0.37 to 0.73 | Parity | Canada, UK, Europe | Fair | 2
Antoniou, 2009^81^ | BRCA2 mutation carriers [underlined: Exposed:] 760 women OC exposed [underlined: Unexposed]: 245 women OC unexposed | 1.04 | 0.42 to 2.54 | Parity | Canada, UK, Europe | Fair | 2
Dorjgochoo, 2009^88^ | Shanghai Women's Health Study [underlined: Exposed]: 12,957 women OC exposed [underlined: Unexposed]:15,557 women OC unexposed | 1.19 | 0.66 to 1.84 | Age, parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | Asia | Fair | 1
Rosenblatt, 2009^138^ | Cohort of female textile workers in Shanghai [underlined: Exposed]: 352,695 person-years OC exposed [underlined: Unexposed]: 2,057,377 person-years OC unexposed | 1.17 | 0.86 to 1.60 | Age, parity, injectable contraceptive use | Asia | Poor | 1
Braem, 2010^85^ | Netherlands Cohort Study on Diet and Cancer [underlined: Exposed]: 8668 person-years OC exposed [underlined: Unexposed]: 25,916 person-years OC unexposed | 0.71 | 0.52 to 0.97 | Age, parity | UK, not multicenter | Fair | 5
Tsilidis, 2011^151^ | EPIC Cohort [underlined: Exposed]: 192,836 women OC exposed [underlined: Unexposed]: 132,923 women OC unexposed | 0.86 | 0.73 to 1.00 | Age, parity, menopausal status, BMI, smoking, center, unilateral oophorectomy, hysterectomy, menopausal hormones, age at menarche | Europe | Good | 1
Yang, 2012^162^ | NIH-AARP Diet and Health Study [underlined: Exposed]: 67,870 women OC exposed [underlined: Unexposed]: 100,304 women OC unexposed | 0.74 | 0.63 to 0.87 | Age, parity, menopausal hormone therapy | U.S. | Good | 1
Pooled
Franceschi, 1991^24^ | [underlined: Cases]: 971 women with epithelial ovarian cancer [underlined: Controls]: 2258 hospital controls | 0.6 | 0.4 to 0.8 | Study, age, marital status, socioeconomic status, parity, menopause, contraceptive habits | Europe | Fair | 7
Harris, 1992^101^ | Collaborative Ovarian Cancer Group [underlined: Cases]: 327 white women with ovarian borderline tumors [underlined: Controls]: 4144 white controls | 0.80 | 0.59 to 1.1 | Study, age, parity | U.S. | Good | 7
Horn-Ross, 1992^106^ | Collaborative Ovarian Cancer Group Germ cell tumors [underlined: Cases]: 38 [underlined: Controls]: 1142 general population controls | 2.0 | 0.77 to 5.1 | Study, age, year of birth | U.S. | Fair | 4, 7
Horn-Ross, 1992^106^ | Sex cord-stromal tumors [underlined: Cases]: 45 [underlined: Controls]: 2617 general population controls | 0.37 | 0.16 to 0.83 | Study, age, year of birth | U.S. | Fair | 4, 7
Bosetti, 2002^23^ | [underlined: Cases]: 2,768 women with epithelial ovarian cancer [underlined: Controls]: 6,274 hospital controls | 0.66 | 0.56 to 0.79 | Study, age, year, socioeconomic status, parity, menopause, age at menopause | Europe | Fair | 6
Beral, 2008^21^ | [underlined: Cases]: 23,257 women with malignant ovarian tumors [underlined: Controls]: 87,303 women without malignant ovarian tumors | 0.73 | 0.70 to 0.76 | Study, age, parity, hysterectomy | 21 countries | Good | 6

BMI = body mass index; BRCA = breast cancer genetic mutation; BSO = bilateral salpingo-oophorectomy; BTL = bilateral tubal ligation; CI = confidence interval; GCT = granulosa cell tumor; HRT = hormone replacement therapy; IUD = Intrauterine device; OC = oral contraceptive; OR = odds ratio; NR = not reported; NZ = New Zealand; UK = United Kingdom; U.S. = United States; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Meta-analysis code: 1 = Included in this meta-analysis; 2 = Excluded due to odds ratios reported for BRCA mutation carriers only; 3 = Excluded due to odds ratios for this population reported by another included article (primary abstraction ID given); 4 = Excluded due to epithelial ovarian cancers not included; 5 = Excluded due to case-cohort study reported hazard ratio only; 6 = Excluded pooled study due to inclusion of component studies; 7 = Excluded pooled study due to >50% of component studies published prior to 1990; 8 = Excluded in main analyses of studies from 2000 forward, included in sensitivity analyses of studies from 1990 forward.

#### Ever Versus Never OC Use

Seventeen case-control studies representing 10,031 cases and 21,025 controls83,87,93,107,114,115,121,123,125,127,132-134,141,143-146,155,160 and including two instances of paired articles from the same studies with distinct cases107,133,134,146 were included in this meta-analysis examining the effect of ever versus never OC use on ovarian cancer incidence. Of these studies, 11 were rated good quality, 6 fair quality, and 1 poor quality. Note that the articles from the MALOVA study are represented in two different quality categories based on varying characteristics of the two publications. Abstracted data not included in this analysis are specified (with rationale) in Table 5. Reasons for exclusion from the analysis included reporting ever versus never data from the same study as another article already included in the analysis; reporting only on BRCA mutation carriers; and including only women with nonepithelial ovarian cancers. Figure 10 shows that the odds ratio for the meta-analysis of ever versus never use of OCs was 0.72 (95% CI, 0.64 to 0.81), which demonstrates an almost 28-percent reduction in ovarian cancer risk in women who have ever used OCs.

Figure 10 Forest plot for ever versus never OC use (case-control studies, ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 10 shows that the odds ratio for the meta-analysis of ever versus never use of OCs was 0.72 (95% CI, 0.64 to 0.81), which demonstrates an almost 28-percent reduction in ovarian cancer risk in women who have ever used OCs.

Seven cohort studies37,88,110,138,151,156,162 were included in this meta-analysis. There was a total of 625,999 participants in four of these studies88,110,151,162 and a total of 3,981,072 person-years of followup in the other three.37,138,156 Of these studies, three were rated good quality, three fair quality, and one poor quality. Abstracted data not included in this analysis are specified (with rationale) in Table 5. Reasons for exclusion from this analysis included reporting only on BRCA mutation carriers; reporting ever versus never data from the same study as another article already included in the analysis; and for one case-cohort study, reporting hazard ratios rather than odds ratios. Figure 11 shows that the odds ratio for the meta-analysis of ever versus never use of OCs was 0.75 (95% CI, 0.62 to 0.92).

Figure 11 Forest plot for ever versus never OC use (cohort studies, ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 11 shows that the odds ratio for the meta-analysis of ever versus never use of OCs was 0.75 (95% CI, 0.62 to 0.92).

A combined meta-analysis of all 24 case-control and cohort studies resulted in an odds ratio for ever versus never use of 0.73 (95% CI, 0.66 to 0.81). Both groups of studies showed heterogeneity due to heterogeneous populations and varying durations of followup.

##### Sensitivity Analyses

Analyses were repeated excluding the studies rated as poor quality (1 case-control and 1 cohort). These exclusions had a minor effect on the odds ratio estimates. Estimates were 0.70 (95% CI, 0.63 to 0.78) for the case-control studies; 0.70 (CI, 0.58 to 0.85) for the cohort studies; and 0.70 (CI, 0.64 to 0.77) for all studies combined. We also repeated our analyses of the case-control studies excluding those without patients from the United States (9 studies). The meta-analysis of the remaining eight case-control studies revealed an odds ratio for ever OC use of 0.72 (CI, 0.61 to 0.85). A similar analysis was not performed for the cohort studies because only one of the seven studies was conducted in the United States.

Additional analyses were done including studies published from 1990 forward. Estimates were 0.70 (CI, 0.63 to 0.77) for the 26 case-control studies, 0.79 (CI, 0.65 to 0.96) for the 8 cohort studies and 0.72 (CI, 0.66 to 0.79) for a combined analysis of the case-control and cohort studies.

##### Pooled Analyses

Two pooled analyses that reported on ever versus never OC use but did not meet inclusion criteria for the meta-analysis are of particular note. One of these23 included only epithelial ovarian cancers as cases and reported odds ratios for ever versus never use of 0.66 (95% CI, 0.56 to 0.79). The other21 reported the largest pooled analysis of 45 studies (47 referenced publications) with 23,257 cases of epithelial or nonepithelial ovarian cancer and 87,303 controls—with a combined odds ratio of 0.73 (CI, 0.70 to 0.76). Our systematic review included 13 of the 47 studies referenced by Beral et al.21 Of the remaining 34 studies, 16 were not included due to publication prior to 2000; 16 were not identified by our literature search, and manual review of these confirmed that they were not relevant to our question of interest; and 2 were identified by the literature search but excluded at the abstract screening stage.

#### Temporal Relationships

##### Duration of OC Use

Fifteen studies37,87,109,110,114,117,118,125,133,134,138,141,145,152,154,160,162 were included in this meta-analysis examining the effect of duration of OC use on ovarian cancer incidence. Of these, 10 were case-control studies representing 6901 cases and 15,999 controls. Five were cohort studies, with 524,463 participants in 3 of the studies and 3,493,072 person-years in the other 2 studies. Seven studies were rated good quality, 7 fair quality, and 1 poor quality. Reasons for exclusion from this meta-analysis included reporting fewer than 3 duration categories; reporting odds ratios only for specific subpopulations of women; lacking a “never use” reference group; reporting duration data from the same study as another article already included in the analysis; and reporting duration odds ratios for only the year of OC use (Table 6).

Table 6 Data for outcomes on duration of OC use (ovarian cancer incidence)

Study^a^ | Sample Size | Comparisons | OR^b^ | 95% CI^b^ | Covariates | Special Population (if Applicable) | Meta- Analysis Code^c^
Case-Control
Harlow, 1991^100^ | [underlined: Cases]: 194 [underlined: Controls]: 193 | Used OC for <3 mo or never (reference) | 1.0 | NA (reference) | Age, parity, religion | | 3
Harlow, 1991^100^ | [underlined: Cases]: 194 [underlined: Controls]: 193 | 3 to 12 mo | 1.5 | 0.8 to 3.1 | Age, parity, religion | | 3
Harlow, 1991^100^ | [underlined: Cases]: 194 [underlined: Controls]: 193 | 13 to 48 mo | 0.7 | 0.3 to 1.4 | Age, parity, religion | | 3
Harlow, 1991^100^ | [underlined: Cases]: 194 [underlined: Controls]: 193 | >48 mo | 0.5 | 0.2 to 0.9 | Age, parity, religion | | 3
Parazzini, 1991^128^ | [underlined: Cases]: 505 [underlined: Controls]: 1375 | <2 yr | 0.9 | 0.5 to .5 | Age, parity, menopausal status, age at menarche, education, marital status, lifelong menstrual pattern, age at menopause | | 2
Parazzini, 1991^128^ | [underlined: Cases]: 505 [underlined: Controls]: 1375 | ≥2 yr | 0.5 | 0.3 to 0.9 | Age, parity, menopausal status, age at menarche, education, marital status, lifelong menstrual pattern, age at menopause | | 2
Parazzini, 1991^129^ | [underlined: Cases]: 91 [underlined: Controls]: 273 | <24 mo | 0.3 | 0.1 to 0.4 | Age, parity, education, age at menopause | | 2
Parazzini, 1991^129^ | [underlined: Cases]: 91 [underlined: Controls]: 273 | ≥24 mo | 0.2 | 0.1 to 0.6 | Age, parity, education, age at menopause | | 2
Thomas, 1991^150^ | [underlined: Cases]: 368 [underlined: Controls]: 2397 | 1 to 11 mo | 0.86 | 0.58 to 1.28 | Age, menopausal status, hospital, year of interview | | 2
Thomas, 1991^150^ | [underlined: Cases]: 368 [underlined: Controls]: 2397 | 12 to 59 mo | 0.69 | 0.45 to 1.10 | Age, menopausal status, hospital, year of interview | | 2
Thomas, 1991^150^ | [underlined: Cases]: 368 [underlined: Controls]: 2397 | 60+ mo | 0.50 | 0.26 to 0.98 | Age, menopausal status, hospital, year of interview | | 2
Badawy, 1992^82^ | [underlined: Cases]: 52 [underlined: Controls]: 52 | <5 yr | 0.9 | 0.3 to 2.5 | Crude | | 2
Badawy, 1992^82^ | [underlined: Cases]: 52 [underlined: Controls]: 52 | 5+ yr | 0.2 | 0.1 to 0.5 | Crude | | 2
Chen, 1992^86^ | [underlined: Cases]: 112 [underlined: Controls]: 224 | | | Reference | Parity, education | | 7
Chen, 1992^86^ | [underlined: Cases]: 112 [underlined: Controls]: 224 | <12 mo | 0.7 | 0.3 to 1.8 | Parity, education | | 7
Chen, 1992^86^ | [underlined: Cases]: 112 [underlined: Controls]: 224 | 12 to 35 mo | 1.4 | 0.5 to 3.4 | Parity, education | | 7
Chen, 1992^86^ | [underlined: Cases]: 112 [underlined: Controls]: 224 | 36+ mo | 1.1 | 0.4 to 2.9 | Parity, education | | 7
Gross, 1992^95^ | [underlined: Cases]: 225 [underlined: Controls]: 2252 | 3 to 11 mo | 0.6 | | Age, parity | Cases and controls with no family history of ovarian cancer | 4
Gross, 1992^95^ | [underlined: Cases]: 225 [underlined: Controls]: 2252 | 12 to 24 mo | 0.6 | | Age, parity | Cases and controls with no family history of ovarian cancer | 4
Gross, 1992^95^ | [underlined: Cases]: 225 [underlined: Controls]: 2252 | 25 to 36 | 0.7 | | Age, parity | Cases and controls with no family history of ovarian cancer | 4
Gross, 1992^95^ | [underlined: Cases]: 225 [underlined: Controls]: 2252 | 37 to 60 | 0.7 | | Age, parity | Cases and controls with no family history of ovarian cancer | 4
Gross, 1992^95^ | [underlined: Cases]: 225 [underlined: Controls]: 2252 | ≥61 | 0.3 | | Age, parity | Cases and controls with no family history of ovarian cancer | 4
Gross, 1992^95^
Gross, 1992^95^ | [underlined: Cases]: 31 [underlined: Controls]: 99 | 3 to 11 mo | 3.1 | | Age, parity | Women with a family history of ovarian cancer | 4
Gross, 1992^95^ | [underlined: Cases]: 31 [underlined: Controls]: 99 | 12 to 24 mo | 1.7 | | Age, parity | Women with a family history of ovarian cancer | 4
Gross, 1992^95^ | [underlined: Cases]: 31 [underlined: Controls]: 99 | 25 to 36 mo | 1.5 | | Age, parity | Women with a family history of ovarian cancer | 4
Gross, 1992^95^ | [underlined: Cases]: 31 [underlined: Controls]: 99 | 37 to 60 mo | 1.1 | | Age, parity | Women with a family history of ovarian cancer | 4
Gross, 1992^95^ | [underlined: Cases]: 31 [underlined: Controls]: 99 | ≥61 mo | 0.3 | | Age, parity | Women with a family history of ovarian cancer | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | High dose 1 to 6 mo | 0.60 | 0.28 to 1.28 | Age, parity, center, year of diagnosis | | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | High dose 7 to 18 mo | 1.07 | 0.50 to 2.29 | Age, parity, center, year of diagnosis | | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | High dose 19 to 60 mo | 0.48 | 0.20 to 1.18 | Age, parity, center, year of diagnosis | | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | High dose 61+ mo | 0.49 | 0.17 to 1.43 | Age, parity, center, year of diagnosis | | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | Low dose 1 to 6 mo | 0.45 | 0.18 to 1.10 | Age, parity, center, year of diagnosis | | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | Low dose 7 to 18 mo | 1.36 | 0.59 to 3.10 | Age, parity, center, year of diagnosis | | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | Low dose 19 to 60 mo | 1.47 | 0.68 to 3.18 | Age, parity, center, year of diagnosis | | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | Low dose 61+ mo | 0.75 | 0.26 to 2.19 | Age, parity, center, year of diagnosis | | 4
Tavani, 1993^148^ | [underlined: Cases]: 194 [underlined: Controls]: 710 | 2 yr or less | 0.9 | 0.5 to 1.4 | Age, parity, family history, education, abortions, OC use | Only women <45 yr | 7
Tavani, 1993^148^ | [underlined: Cases]: 194 [underlined: Controls]: 710 | 2 to <5 yr | 1.1 | 0.5 to 2.4 | Age, parity, family history, education, abortions, OC use | Only women <45 yr | 7
Tavani, 1993^148^ | [underlined: Cases]: 194 [underlined: Controls]: 710 | 5+ yr | 0.3 | 0.1 to 0.7 | Age, parity, family history, education, abortions, OC use | Only women <45 yr | 7
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 1 to 5 mo | 1.1 | 0.7 to 1.7 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refers only to use >3 yr | 7
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 6 to 11 mo | 0.9 | 0.5 to 1.7 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refers only to use >3 yr | 7
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 1 yr | 1.3 | 0.8 to 2.0 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refers only to use >3 yr | 7
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 2 yr | 1.2 | 0.7 to 2.0 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refers only to use >3 yr | 7
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 3 to 4 yr | 0.5 | 0.3 to 1.1 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refers only to use >3 yr | 7
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 5 to 9 yr | 0.7 | 0.4 to 1.1 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refers only to use >3 yr | 7
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | ≥10 yr | 0.5 | 0.2 to 0.9 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refers only to use >3 yr | 7
Risch, 1996^136^ | [underlined: Cases]: 367 [underlined: Controls]: 564 | OR per yr OC use | 0.89 | 0.84 to 0.94 | Age, parity, family history, breastfeeding, duration of OC use, BTL, HRT, hysterectomy | Invasive serous ovarian cancers | 5
Risch, 1996^136^
Risch, 1996^136^ | [underlined: Cases]: 83 [underlined: Controls]: 564 | OR per yr OC use | 0.95 | 0.9 to 1.01 | Age, parity, family history, breastfeeding, duration of OC use, BTL, HRT, hysterectomy | Borderline tumors | 5
Risch, 1996^136^
Risch, 1996^136^ | [underlined: Cases]: 40 [underlined: Controls]: 564 | OR per yr OC use | 0.97 | 0.89 to 1.05 | Age, parity, family history, breastfeeding, duration of OC use, tubal ligation, HRT, hysterectomy | Mucinous invasive cancers | 5
Risch, 1996^136^
Risch, 1996^136^ | [underlined: Cases]: 42 [underlined: Controls]: 564 | OR per yr OC use | 0.86 | 0.77 to 0.96 | Age, parity, family history, breastfeeding, duration OC use, HRT, BTL, hysterectomy | Borderline serous tumors | 5
Risch, 1996^136^
Risch, 1996^136^ | [underlined: Cases]: 40 [underlined: Controls]: 564 | OR per yr OC use | 1.00 | 0.93 to 1.07 | Age, parity, family history, breastfeeding, duration OC use, HRT, BTL, hysterectomy | Borderline mucinous tumors | 5
Risch, 1996^136^
Risch, 1996^136^ | [underlined: Cases]: 254 [underlined: Controls]: 564 | OR per yr OC use | 0.88 | 0.84 to 0.93 | Age, parity, family history, breastfeeding, duration OC use, HRT, BTL, hysterectomy | All serous tumors both borderline and invasive | 5
Risch, 1996^136^
Risch, 1996^136^ | [underlined: Cases]: 367 [underlined: Controls]: 564 | OR per yr of OC use | 0.9 | 0.86 to 0.94 | Age, parity, family history, breastfeeding, BTL, HRT, hysterectomy, duration of OC use | Invasive ovarian cancers | 5
Godard, 1998^89^ | [underlined: Cases]: 153 [underlined: Controls]: 152 | 0 to 1 yr | 1.0 | Reference 0.44 to 1.36 0.27 to 0.91 0.13 to 0.82 | Crude | | 3
Godard, 1998^89^ | [underlined: Cases]: 153 [underlined: Controls]: 152 | 1 to 5 yr | 0.77 | Reference 0.44 to 1.36 0.27 to 0.91 0.13 to 0.82 | Crude | | 3
Godard, 1998^89^ | [underlined: Cases]: 153 [underlined: Controls]: 152 | 6 to 10 yr | 0.49 | Reference 0.44 to 1.36 0.27 to 0.91 0.13 to 0.82 | Crude | | 3
Godard, 1998^89^ | [underlined: Cases]: 153 [underlined: Controls]: 152 | 11 to 25 yr | 0.33 | Reference 0.44 to 1.36 0.27 to 0.91 0.13 to 0.82 | Crude | | 3
Godard, 1998^89^ | [underlined: Cases]: 153 [underlined: Controls]: 152 | Per yr of use | 0.89 | Reference 0.44 to 1.36 0.27 to 0.91 0.13 to 0.82 | Crude | | 3
Narod, 1998^122^ | [underlined: Cases]: 207 [underlined: Controls]: 53 | <3 yr | 0.4 | 0.3 to 0.9 | Age, parity, age at first birth, geographic area of residence | Ovarian cancer cases with BRCA1 or BRCA2 mutations, controls are sisters of cases (53 of 161 controls had BRCA1 or BRCA2 mutations).Cases compared with controls with BRCA1/2 mutations | 4
Narod, 1998^122^ | [underlined: Cases]: 207 [underlined: Controls]: 53 | 3 to <6 yr | 0.4 | 0.1 to 1.0 | Age, parity, age at first birth, geographic area of residence | Ovarian cancer cases with BRCA1 or BRCA2 mutations, controls are sisters of cases (53 of 161 controls had BRCA1 or BRCA2 mutations).Cases compared with controls with BRCA1/2 mutations | 4
Narod, 1998^122^ | [underlined: Cases]: 207 [underlined: Controls]: 53 | ≥6 yr | 0.3 | 0.1 to 0.7 | Age, parity, age at first birth, geographic area of residence | Ovarian cancer cases with BRCA1 or BRCA2 mutations, controls are sisters of cases (53 of 161 controls had BRCA1 or BRCA2 mutations).Cases compared with controls with BRCA1/2 mutations | 4
Narod, 1998^122^
Narod, 1998^122^ | [underlined: Cases]: 207 [underlined: Controls]: 161 | <3 yr | 0.8 | 0.4 to 1.4 | Age, parity, age at first birth, geographic area of residence | Cases with BRCA1 or BRCA2 mutations, controls are sisters of cases (53 of 161 had BRCA1 or BRCA2 mutations) | 4
Narod, 1998^122^ | [underlined: Cases]: 207 [underlined: Controls]: 161 | 3 to <6 yr | 0.4 | 0.2 to 0.9 | Age, parity, age at first birth, geographic area of residence | Cases with BRCA1 or BRCA2 mutations, controls are sisters of cases (53 of 161 had BRCA1 or BRCA2 mutations) | 4
Narod, 1998^122^ | [underlined: Cases]: 207 [underlined: Controls]: 161 | ≥6 yr | 0.4 | 0.2 to 0.7 | Age, parity, age at first birth, geographic area of residence | Cases with BRCA1 or BRCA2 mutations, controls are sisters of cases (53 of 161 had BRCA1 or BRCA2 mutations) | 4
Salazar-Martinez, 1999^142^ | [underlined: Cases]: 84 [underlined: Controls]: 668 | 1 to 12 mo | 0.56 | 0.22 to 1.3 | Age, parity, BMI, smoking, breastfeeding , diabetes, hypertension, physical activity, menopausal status | | 2
Salazar-Martinez, 1999^142^ | [underlined: Cases]: 84 [underlined: Controls]: 668 | 13+ mo | 0.36 | 0.15 to 0.83 | Age, parity, BMI, smoking, breastfeeding , diabetes, hypertension, physical activity, menopausal status | | 2
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | <5 yr | 1.0 | 0.7 to 1.6 | Age, parity | Nonmucinous cases | 2
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | 5+ yr | 0.6 | 0.4 to 1.0 | Age, parity | Nonmucinous cases | 2
Wittenberg, 1999^161^
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | <5 yr | 1.2 | 0.5 to 3.0 | Age, parity | Mucinous ovarian cases | 2
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | 5+ yr | 0.4 | 0.1 to 1.4 | Age, parity | Mucinous ovarian cases | 2
Greggi, 2000^93^ | [underlined: Cases]: 440 [underlined: Controls]: 868 | < 24 mo | 0.5 | 0.3 to 0.9 | Age, parity, family history, breastfeeding, education, OC use, age at first birth, breast feeding, OC use | | 2
Greggi, 2000^93^ | [underlined: Cases]: 440 [underlined: Controls]: 868 | ≥24 mo | 0.3 | 0.2 to 0.5 | Age, parity, family history, breastfeeding, education, OC use, age at first birth, breast feeding, OC use | | 2
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | < 1 yr | 0.7 | 0.5 to 1.0 | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | 1 to 4 yr | 0.7 | 0.5 to 0.9 | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | 5 to 9 yr | 0.7 | 0.5 to 0.9 | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | ≥10 yr | 0.4 | 0.2 to 0.6 | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | < 1 yr | 0.7 | 0.6 to 1.0 | Age, race, family history, number of pregnancies | All cases combined | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | 1 to 4 yr | 0.7 | 0.5 to 0.9 | Age, race, family history, number of pregnancies | All cases combined | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | 5 to 9 yr | 0.6 | 0.5 to 0.9 | Age, race, family history, number of pregnancies | All cases combined | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | ≥10 yr | 0.3 | 0.2 to 0.5 | Age, race, family history, number of pregnancies | All cases combined | 1
Ness, 2000^125^
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | < 1 yr | 1.0 | 0.6 to 1.7 | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | 1 to 4 yr | 0.8 | 0.5 to 1.3 | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | 5 to 9 yr | 0.7 | 0.4 to 1.2 | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | ≥10 yr | 0.3 | 0.1 to 0.7 | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | <5 yr | 1.0 | 0.6 to 1.5 | Age, parity | | 2
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | >5 yr | 0.6 | 0.3 to 0.9 | Age, parity | | 2
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 1 to 12 mo | 0.57 | 0.40 to 0.82 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 13 to 60 mo | 0.73 | 0.52 to 1.03 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 61 to 120 mo | 0.50 | 0.34 to 0.73 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 120 to 180 mo | 0.35 | 0.21 to 0.56 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | >180 mo | 0.25 | 0.13 to 0.49 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 1 to 12 mo prior to first pregnancy | 1.01 | 0.57 to 1.80 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 13 to 36 mo prior to first pregnancy | 0.97 | 0.58 to 1.63 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 36 to 60 mo prior to first pregnancy | 0.89 | 0.47 to 1.68 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | >60 mo prior to first pregnancy | 0.54 | 0.26 to 1.11 | Parity, smoking, ovulatory life, tubal ligation, and hysterectomy | | 1
Siskind, 2000^145^
Siskind, 2000^145^ | [underlined: Cases]: 114 [underlined: Controls]: 853 | OR per year of OC use | 0.92 | 0.88 to 0.97 | Age, parity, BMI, family history, smoking, breastfeeding , alcohol, BTL, hysterectomy, infertility, number of lifetime ovulations | Mucinous ovarian cancers | 1
Siskind, 2000^145^
Siskind, 2000^145^ | [underlined: Cases]: 677 [underlined: Controls]: 853 | OR per year of OC use | 0.93 | 0.90 to 0.96 | Age, parity, BMI, smoking, age squared, alcohol, hysterectomy, tubal, infertility, number of lifetime ovulation | Nonmucinous ovarian cancer | 1
Chiaffarino, 2001^87^ | [underlined: Cases]: 1031 [underlined: Controls]: 2411 | <25 mo | 1.0 | 0.7 to 1.4 | Age, parity, family history, center, education | | 1
Chiaffarino, 2001^87^ | [underlined: Cases]: 1031 [underlined: Controls]: 2411 | 25 to 59 mo | 1.3 | 0.7 to 2.2 | Age, parity, family history, center, education | | 1
Chiaffarino, 2001^87^ | [underlined: Cases]: 1031 [underlined: Controls]: 2411 | ≥60 mo | 0.5 | 0.3 to 0.9 | Age, parity, family history, center, education | | 1
Modan, 2001^118^ | [underlined: Cases]: 240 [underlined: Controls]: 2257 | 0.1 to 1.9 yr | 1.14 | 0.67 to 1.94 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; cases with BRCA1 or 2 mutations (N=240) | 1
Modan, 2001^118^ | [underlined: Cases]: 240 [underlined: Controls]: 2257 | 2.0 to 4.9 yr | 0.77 | 0.41 to 1.44 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; cases with BRCA1 or 2 mutations (N=240) | 1
Modan, 2001^118^ | [underlined: Cases]: 240 [underlined: Controls]: 2257 | ≥5.0 yr | 1.07 | 0.63 to 1.83 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; cases with BRCA1 or 2 mutations (N=240) | 1
Modan, 2001^118^
Modan, 2001^118^ | [underlined: Cases]: 832 [underlined: Controls]: 2257 | 0.1 to 1.9 yr | 1.15 | 0.84 to 1.57 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; high prevalence of BRCA mutation carriers | 1
Modan, 2001^118^ | [underlined: Cases]: 832 [underlined: Controls]: 2257 | 2.0 to 4.9 yr | 0.77 | 0.53 to 1.12 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; high prevalence of BRCA mutation carriers | 1
Modan, 2001^118^ | [underlined: Cases]: 832 [underlined: Controls]: 2257 | ≥5.0 yr | 0.69 | 0.48 to 0.98 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; high prevalence of BRCA mutation carriers | 1
Modan, 2001^118^
Modan, 2001^118^ | [underlined: Cases]: 592 [underlined: Controls]: 2257 | 0.1 to 1.9 yr | 1.13 | 0.79 to 1.62 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; cases without BRCA mutations (N=592) | 1
Modan, 2001^118^ | [underlined: Cases]: 592 [underlined: Controls]: 2257 | 2.0 to 4.9 yr | 0.74 | 0.48 to 1.16 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; cases without BRCA mutations (N=592) | 1
Modan, 2001^118^ | [underlined: Cases]: 592 [underlined: Controls]: 2257 | ≥5.0 yr | 0.53 | 0.34 to 0.84 | Age, parity, family history, personal history of breast cancer, history of gynecologic surgery, ethnicity | Israeli population; cases without BRCA mutations (N=592) | 1
Modugno, 2001^119^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | Per one year of use | 0.94 | 0.92 to 0.97 | Age, race, parity, family history, breastfeeding , noncontraceptive estrogen use, tubal ligation, hysterectomy, family history of breast cancer | Invasive ovarian cancer (N=616) | 5
Modugno, 2001^119^
Modugno, 2001^119^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | Per one year of use | 0.92 | 0.85 to 0.98 | Age, race, parity, family history, breastfeeding , noncontraceptive estrogen use, tubal ligation, hysterectomy, family history of breast cancer | Borderline ovarian cancer (N=151) | 5
Modugno, 2001^119^
Modugno, 2001^119^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | Per year of use | 0.94 | 0.91 to 0.96 | Age, race, parity, family history, breastfeeding , noncontraceptive estrogen, tubal ligation, hysterectomy, family history of breast cancer | | 5
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for contraception ≤4 yr | 0.6 | 0.5 to 0.8 | Age, race, family history, pregnancies | | 4
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for contraception 5 to 9 yr | 0.5 | 0.4 to 0.8 | Age, race, family history, pregnancies | | 4
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for contraception ≥10 yr | 0.3 | 0.2 to 0.6 | Age, race, family history, pregnancies | | 4
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for noncontraception ≤4 yr | 0.7 | 0.4 to 1.0 | Age, race, family history, pregnancies | | 4
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for noncontraception 5 to 9 yr | NR | | Age, race, family history, pregnancies | | 4
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for noncontraception ≥10 yr | NR | | Age, race, family history, pregnancies | | 4
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for both ≤4 yr | 0.7 | 0.5 to 1.1 0.5 to 1.4 0.5 to 1.4 (Not plausible for reported OR) | Age, race, family history, pregnancies | | 4
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for both 5 to 9 yr | 0.8 | 0.5 to 1.1 0.5 to 1.4 0.5 to 1.4 (Not plausible for reported OR) | Age, race, family history, pregnancies | | 4
Ness, 2001^126^ | [underlined: Cases]: 727 [underlined: Controls]: 1359 | OCs for both ≥10 yr | 0.2 | 0.5 to 1.1 0.5 to 1.4 0.5 to 1.4 (Not plausible for reported OR) | Age, race, family history, pregnancies | | 4
Riman, 2001^133^ | [underlined: Cases]: 193 [underlined: Controls]: 3899 | <2 y | 0.96 | 0.55 to 1.66 | Age, parity, BMI, age menopause, HRT | Borderline ovarian tumors versus disease free controls | 1
Riman, 2001^133^ | [underlined: Cases]: 193 [underlined: Controls]: 3899 | 2 to 4 y | 1.34 | 0.73 to 2.43 | Age, parity, BMI, age menopause, HRT | Borderline ovarian tumors versus disease free controls | 1
Riman, 2001^133^ | [underlined: Cases]: 193 [underlined: Controls]: 3899 | 5 to 9 y | 1.29 | 0.68 to 2.43 | Age, parity, BMI, age menopause, HRT | Borderline ovarian tumors versus disease free controls | 1
Riman, 2001^133^ | [underlined: Cases]: 193 [underlined: Controls]: 3899 | ≥10 y | 1.16 | 0.61 to 2.18 | Age, parity, BMI, age menopause, HRT | Borderline ovarian tumors versus disease free controls | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 1 to 2 yr | 0.89 | 0.47 to 1.67 | Parity, family history, breastfeeding , tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 3 to 5 yr | 0.45 | 0.22 to 0.92 | Parity, family history, breastfeeding , tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 6 to 10 yr | 0.37 | 0.22 to 0.79 | Parity, family history, breastfeeding , tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 11 to 15 yr | 0.42 | 0.22 to 0.79 | Parity, family history, breastfeeding , tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 16 to 20 yr | 0.32 | 0.14 to 0.73 | Parity, family history, breastfeeding , tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 21+ yr | 0.12 | 0.03 to 0.53 | Parity, family history, breastfeeding , tubal ligation, hysterectomy | | 1
Riman, 2002^134^ | [underlined: Cases]: 655 [underlined: Controls]: 3899 | <2y | 0.95 | 0.71 to 1.26 | Age, parity, BMI, age menopause, HRT | | 1
Riman, 2002^134^ | [underlined: Cases]: 655 [underlined: Controls]: 3899 | 2 to 4 y | 0.88 | 0.61 to 1.25 | Age, parity, BMI, age menopause, HRT | | 1
Riman, 2002^134^ | [underlined: Cases]: 655 [underlined: Controls]: 3899 | 5 to 9 y | 0.5 | 0.32 to 0.80 | Age, parity, BMI, age menopause, HRT | | 1
Riman, 2002^134^ | [underlined: Cases]: 655 [underlined: Controls]: 3899 | ≥10 y | 0.36 | 0.22 to 0.59 | Age, parity, BMI, age menopause, HRT | | 1
Schildkraut, 2002^29^ | [underlined: Cases]: 22 [underlined: Controls]: 351 | 3 to 18 mo | 0.4 | 0.2 to 0.8 | Age | High progestin | 4
Schildkraut, 2002^29^ | [underlined: Cases]: 22 [underlined: Controls]: 351 | 19 to 59 mo | 0.3 | 0.2 to 0.7 | Age | High progestin | 4
Schildkraut, 2002^29^ | [underlined: Cases]: 22 [underlined: Controls]: 351 | >60 mo | 0.2 | 0.1 to 0.5 | Age | High progestin | 4
Schildkraut, 2002^29^
Schildkraut, 2002^29^ | [underlined: Cases]: 71 [underlined: Controls]: 831 | 3 to 18 mo | 0.6 | 0.4 to 0.9 | Age | High potency estrogen | 4
Schildkraut, 2002^29^ | [underlined: Cases]: 71 [underlined: Controls]: 831 | 19 to 59 mo | 0.5 | 0.3 to 0.7 | Age | High potency estrogen | 4
Schildkraut, 2002^29^ | [underlined: Cases]: 71 [underlined: Controls]: 831 | >60 mo | 0.4 | 0.2 to 0.6 | Age | High potency estrogen | 4
Schildkraut, 2002^29^
Schildkraut, 2002^29^ | [underlined: Cases]: 82 [underlined: Controls]: 803 | 3 to 18 mo | 0.7 | 0.4 to 1.0 | Age | Low potency progestins | 4
Schildkraut, 2002^29^ | [underlined: Cases]: 82 [underlined: Controls]: 803 | 19 to 59 mo | 0.7 | 0.4 to 1.0 | Age | Low potency progestins | 4
Schildkraut, 2002^29^ | [underlined: Cases]: 82 [underlined: Controls]: 803 | >60 mo | 0.4 | 0.2 to 0.6 | Age | Low potency progestins | 4
Schildkraut, 2002^29^
Schildkraut, 2002^29^ | [underlined: Cases]: 33 [underlined: Controls]: 323 | 3 to 18 mo | 0.5 | 0.3 to 1.0 | Age | Low potency estrogen | 4
Schildkraut, 2002^29^ | [underlined: Cases]: 33 [underlined: Controls]: 323 | 19 to 59 mo | 0.8 | 0.5 to 1.5 | Age | Low potency estrogen | 4
Schildkraut, 2002^29^ | [underlined: Cases]: 33 [underlined: Controls]: 323 | >60 mo | 0.3 | 0.1 to 0.6 | Age | Low potency estrogen | 4
Walker, 2002^158^ | [underlined: Cases]: 692 [underlined: Controls]: 1279 | ≤48 mo | 0.72 | 0.59 to 0.88 0.40 to 0.65 | Age, race, parity, BTL | No family history of ovarian cancer | 2
Walker, 2002^158^ | [underlined: Cases]: 692 [underlined: Controls]: 1279 | 49+ mo | 0.51 | 0.59 to 0.88 0.40 to 0.65 | Age, race, parity, BTL | No family history of ovarian cancer | 2
Walker, 2002^158^ | [underlined: Cases]: 692 [underlined: Controls]: 1279 | Never OC use | 1 | 0.59 to 0.88 0.40 to 0.65 | Age, race, parity, BTL | No family history of ovarian cancer | 2
Walker, 2002^158^
Walker, 2002^158^ | [underlined: Cases]: 33 [underlined: Controls]: 24 | ≤48 mo use | 0.34 | 0.08 to 1.55 0.01 to 0.44 | Age, race, parity, BTL | Positive family history of ovarian cancer | 2
Walker, 2002^158^ | [underlined: Cases]: 33 [underlined: Controls]: 24 | 49+ mo use | 0.07 | 0.08 to 1.55 0.01 to 0.44 | Age, race, parity, BTL | Positive family history of ovarian cancer | 2
Walker, 2002^158^ | [underlined: Cases]: 33 [underlined: Controls]: 24 | Never use | 1 | 0.08 to 1.55 0.01 to 0.44 | Age, race, parity, BTL | Positive family history of ovarian cancer | 2
Tung, 2003^152^ | [underlined: Cases]: 603 [underlined: Controls]: 607 | <1.5 yr | 0.8 | 0.5 to 1.1 | Age, race, parity, study site, education, tubal ligation | | 1
Tung, 2003^152^ | [underlined: Cases]: 603 [underlined: Controls]: 607 | 1.6 to 5 yr | 0.6 | 0.4 to 0.8 | Age, race, parity, study site, education, tubal ligation | | 1
Tung, 2003^152^ | [underlined: Cases]: 603 [underlined: Controls]: 607 | >5 yr | 0.4 | 0.3 to 0.6 | Age, race, parity, study site, education, tubal ligation | | 1
McGuire, 2004^115^ | [underlined: Cases]: 36 [underlined: Controls]: 568 | <1 year | 1.00 | Reference | Age, race, parity | Cases with BRCA1 mutations (N=36) | 4
McGuire, 2004^115^ | [underlined: Cases]: 36 [underlined: Controls]: 568 | 1 to 2 yr | 1.18 | 0.50 to 2.75 | Age, race, parity | Cases with BRCA1 mutations (N=36) | 4
McGuire, 2004^115^ | [underlined: Cases]: 36 [underlined: Controls]: 568 | 3 to 6 yr | 0.46 | 0.16 to 1.28 | Age, race, parity | Cases with BRCA1 mutations (N=36) | 4
McGuire, 2004^115^ | [underlined: Cases]: 36 [underlined: Controls]: 568 | ≥ yr | 0.22 | 0.07 to 0.71 | Age, race, parity | Cases with BRCA1 mutations (N=36) | 4
McGuire, 2004^115^
McGuire, 2004^115^ | [underlined: Cases]: 381 [underlined: Controls]: 568 | <1 year | 1.00 | Reference | Age, race, parity | Cases without BRCA1 mutations (N=381) | 4
McGuire, 2004^115^ | [underlined: Cases]: 381 [underlined: Controls]: 568 | 1 to 2 yr | 0.81 | 0.55 to 1.19 | Age, race, parity | Cases without BRCA1 mutations (N=381) | 4
McGuire, 2004^115^ | [underlined: Cases]: 381 [underlined: Controls]: 568 | 3 to 6 yr | 0.48 | 0.32 to 0.72 | Age, race, parity | Cases without BRCA1 mutations (N=381) | 4
McGuire, 2004^115^ | [underlined: Cases]: 381 [underlined: Controls]: 568 | ≥7 yr | 0.43 | 0.30 to 0.63 | Age, race, parity | Cases without BRCA1 mutations (N=381) | 4
Mills, 2004^117^ | [underlined: Cases]: 256 [underlined: Controls]: 1122 | ≤1 year | 0.89 | 0.59 to 1.36 | Age, race, breastfeeding | | 1
Mills, 2004^117^ | [underlined: Cases]: 256 [underlined: Controls]: 1122 | 2 to 5 yr | 0.82 | 0.55 to 1.21 | Age, race, breastfeeding | | 1
Mills, 2004^117^ | [underlined: Cases]: 256 [underlined: Controls]: 1122 | 6 to 10 yr | 0.62 | 0.38 to 1.00 | Age, race, breastfeeding | | 1
Mills, 2004^117^ | [underlined: Cases]: 256 [underlined: Controls]: 1122 | >10 yr | 0.37 | 0.20 to 0.68 | Age, race, breastfeeding | | 1
Mills, 2004^117^
Mills, 2004^117^ | [underlined: Cases]: 182 [underlined: Controls]: 1122 | ≤1 year | 0.90 | 0.56 to 1.46 | Age, race, breastfeeding | Invasive ovarian cancer (N=182) | 1
Mills, 2004^117^ | [underlined: Cases]: 182 [underlined: Controls]: 1122 | 2 to 5 yr | 0.74 | 0.46 to 1.18 | Age, race, breastfeeding | Invasive ovarian cancer (N=182) | 1
Mills, 2004^117^ | [underlined: Cases]: 182 [underlined: Controls]: 1122 | 6 to 10 yr | 0.67 | 0.39 to 1.15 | Age, race, breastfeeding | Invasive ovarian cancer (N=182) | 1
Mills, 2004^117^ | [underlined: Cases]: 182 [underlined: Controls]: 1122 | >10 yr | 0.26 | 0.12 to 0.60 | Age, race, breastfeeding | Invasive ovarian cancer (N=182) | 1
Mills, 2004^117^
Mills, 2004^117^ | [underlined: Cases]: 74 [underlined: Controls]: 1122 | ≤1 year | 0.93 | 0.45 to 1.93 | Age, race, breastfeeding | Borderline ovarian cancer (N=74) | 1
Mills, 2004^117^ | [underlined: Cases]: 74 [underlined: Controls]: 1122 | 2 to 5 yr | 1.00 | 0.57 to 2.07 | Age, race, breastfeeding | Borderline ovarian cancer (N=74) | 1
Mills, 2004^117^ | [underlined: Cases]: 74 [underlined: Controls]: 1122 | 6 to 10 yr | 0.57 | 0.23 to 1.42 | Age, race, breastfeeding | Borderline ovarian cancer (N=74) | 1
Mills, 2004^117^ | [underlined: Cases]: 74 [underlined: Controls]: 1122 | >10 yr | 0.67 | 0.27 to 1.68 | Age, race, breastfeeding | Borderline ovarian cancer (N=74) | 1
Pike, 2004^130^ | [underlined: Cases]: 477 [underlined: Controls]: 660 | <5 yr | 1.0 | 0.72 to 1.39 | Age, race, parity, menopausal status, BMI, family history, SES, education, age at last birth, gravidity, OC use | | 2
Pike, 2004^130^ | [underlined: Cases]: 477 [underlined: Controls]: 660 | 5 to 9 yr | 0.72 | 0.46 to 1.13 | Age, race, parity, menopausal status, BMI, family history, SES, education, age at last birth, gravidity, OC use | | 2
Pike, 2004^130^ | [underlined: Cases]: 477 [underlined: Controls]: 660 | 10+ yr | 0.48 | 0.29 to 0.78 | Age, race, parity, menopausal status, BMI, family history, SES, education, age at last birth, gravidity, OC use | | 2
Quirk, 2004^132^ | [underlined: Cases]: 418 [underlined: Controls]: 836 | ≤5 yr | 1.22 | 0.84 to 1.79 | Age, parity, family history, history of tubal ligation, noncontraceptive estrogen use | | 2
Quirk, 2004^132^ | [underlined: Cases]: 418 [underlined: Controls]: 836 | >5 yr | 1.18 | 0.78 to 1.79 | Age, parity, family history, history of tubal ligation, noncontraceptive estrogen use | | 2
Tavani, 2004^147^ | [underlined: Cases]: 1031 [underlined: Controls]: 2411 | 60+ mo | 1 | Reference | Age, center, year at interview, education | | 2
Tavani, 2004^147^ | [underlined: Cases]: 1031 [underlined: Controls]: 2411 | <60 mo or never | 2.01 | 1.11 to 3.66 | Age, center, year at interview, education | | 2
Whittemore, 2004^159^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | <1 year | 1.0 | Reference | Age, parity, study center | BRCA1 and BRCA2 carriers | 4
Whittemore, 2004^159^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | 1 to 2 yr | 1.5 | 0.82 to 2.9 | Age, parity, study center | BRCA1 and BRCA2 carriers | 4
Whittemore, 2004^159^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | 3 to 5 yr | 0.69 | 0.33 to 1.4 | Age, parity, study center | BRCA1 and BRCA2 carriers | 4
Whittemore, 2004^159^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | 6+ yr | 0.62 | 0.35 to 1.1 | Age, parity, study center | BRCA1 and BRCA2 carriers | 4
Greer, 2005^91^ | [underlined: Cases]: 364 [underlined: Controls]: 529 | < 5 yr | 0.39 | 0.18 to 0.85 | Age, parity, family history, tubal ligation | Compared never users to both androgenic and nonandrogenic OC users | 2
Greer, 2005^91^ | [underlined: Cases]: 364 [underlined: Controls]: 529 | 5+ yr | 0.22 | 0.12 to 0.43 | Age, parity, family history, tubal ligation | Compared never users to both androgenic and nonandrogenic OC users | 2
Greer, 2005^91^
Greer, 2005^91^ | [underlined: Cases]: 405 [underlined: Controls]: 592 | < 5 yr | 0.58 | 0.37 to 0.93 | Age, parity, family history, tubal ligation | Compared never users to androgenic only OC users | 2
Greer, 2005^91^ | [underlined: Cases]: 405 [underlined: Controls]: 592 | 5+ yr | 0.35 | 0.2 to 0.61 | Age, parity, family history, tubal ligation | Compared never users to androgenic only OC users | 2
Greer, 2005^91^
Greer, 2005^91^ | [underlined: Cases]: 381 [underlined: Controls]: 761 | < 5 yr | 0.56 | 0.41 to 0.76 | Age, parity, family history, BTL | Compared never users to nonandrogenic only OC users | 2
Greer, 2005^91^ | [underlined: Cases]: 381 [underlined: Controls]: 761 | 5+ yr | 0.73 | 0.5 to 1.07 | Age, parity, family history, BTL | Compared never users to nonandrogenic only OC users | 2
Greer, 2005^92^ | [underlined: Cases]: 715 [underlined: Controls]: 1631 | Single episode; 1 to 6 mo | 0.71 | 0.50 to 0.99 | Age | Parous women | 4
Greer, 2005^92^ | [underlined: Cases]: 715 [underlined: Controls]: 1631 | Single episode; 7 to 12 mo | 1.04 | 0.66 to 1.63 | Age | Parous women | 4
Greer, 2005^92^ | [underlined: Cases]: 715 [underlined: Controls]: 1631 | Single episode; ≥13 mo | 0.66 | 0.48 to 0.90 | Age | Parous women | 4
Greer, 2005^92^ | [underlined: Cases]: 715 [underlined: Controls]: 1631 | ≥1 episode; 1 to 6 mo | 0.71 | 0.51 to 0.99 | Age | Parous women | 4
Greer, 2005^92^ | [underlined: Cases]: 715 [underlined: Controls]: 1631 | ≥1 episode; 7 to 12 mo | 0.97 | 0.64 to 1.47 | Age | Parous women | 4
Greer, 2005^92^ | [underlined: Cases]: 715 [underlined: Controls]: 1631 | ≥1 episode; ≥13 mo | 0.62 | 0.48 to 0.81 | Age | Parous women | 4
Greer, 2005^92^
Greer, 2005^92^ | [underlined: Cases]: 608 [underlined: Controls]: 926 | Single episode use: 1 to 6 mo | .73 | .54 to .99 | Age, parity | | 4
Greer, 2005^92^ | [underlined: Cases]: 608 [underlined: Controls]: 926 | Single episode use: 7 to 12 mo | 1.0 | .67 to 1.50 | Age, parity | | 4
Greer, 2005^92^ | [underlined: Cases]: 608 [underlined: Controls]: 926 | Single episode use: ≥13 mo | .63 | .48 to 82 | Age, parity | | 4
Greer, 2005^92^ | [underlined: Cases]: 608 [underlined: Controls]: 926 | >1 episode of use: 1 to 6 mo | .75 | .56 to 1.0 | Age, parity | | 4
Greer, 2005^92^ | [underlined: Cases]: 608 [underlined: Controls]: 926 | >1 episode of use: 7 to 12 mo | .96 | .66 to 1.38 | Age, parity | | 4
Greer, 2005^92^ | [underlined: Cases]: 608 [underlined: Controls]: 926 | >1 episode of use: ≥13 mo | .56 | .45 to .71 | Age, parity | | 4
Greer, 2005^92^
Greer, 2005^92^ | [underlined: Cases]: 216 [underlined: Controls]: 168 | Single episode; 1 to 6 mo | 1.04 | 0.52 to 2.08 | Age | Nulliparous women | 4
Greer, 2005^92^ | [underlined: Cases]: 216 [underlined: Controls]: 168 | Single episode; 7 to 12 mo | 1.08 | 0.42 to 2.78 | Age | Nulliparous women | 4
Greer, 2005^92^ | [underlined: Cases]: 216 [underlined: Controls]: 168 | Single episode; ≥13 mo | 0.84 | 0.46 to 1.56 | Age | Nulliparous women | 4
Greer, 2005^92^ | [underlined: Cases]: 216 [underlined: Controls]: 168 | ≥1 episode; 1 to 6 mo | 1.05 | 0.55 to 2.01 | Age | Nulliparous women | 4
Greer, 2005^92^ | [underlined: Cases]: 216 [underlined: Controls]: 168 | ≥1 episode; 7 to 12 mo | 1.08 | 0.49 to 2.34 | Age | Nulliparous women | 4
Greer, 2005^92^ | [underlined: Cases]: 216 [underlined: Controls]: 168 | ≥1 episode; ≥13 mo | 0.68 | 0.42 to 1.11 | Age | Nulliparous women | 4
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 0.1 to 1.8 yr (all women) | 0.74 | 0.50 to 1.07 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 1.9 to 5.3 yr (all women) | 0.60 | 0.41 to 0.88 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 5.4+ yr (all women) | 0.45 | 0.30 to 0.69 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 0.1 to 1.8 yr (premenopausal women) | 0.52 | 0.30 to 0.90 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 1.9 to 5.3 yr (premenopausal women) | 0.34 | 0.19 to 0.61 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 5.4+ yr (premenopausal women) | 0.28 | 0.15 to 0.52 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 0.1 to 1.8 yr (postmenopausal women) | 0.75 | 0.43 to 1.29 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 1.9 to 5.3 yr (postmenopausal women) | 0.86 | 0.51 to 1.45 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Tung, 2005^153^ | [underlined: Cases]: 558 [underlined: Controls]: 607 | 1.9 to 5.3 yr (postmenopausal women) | 0.58 | 0.31 to 1.08 | Age, race, parity, study center, education, BTL, HRT, ovulation variables | Data presented as whole sample and subgrouped by menopausal status (pre/post) | 6^152^
Gronwald, 2006^94^ | [underlined: Cases]: 150 [underlined: Controls]: 150 | ≤2 yr | 0.8 | 0.2 to 2.5 | NR | BRCA1 carriers | 2
Gronwald, 2006^94^ | [underlined: Cases]: 150 [underlined: Controls]: 150 | >2 yr | 0.2 | 0.1 to 0.7 | NR | BRCA1 carriers | 2
Huusom, 2006^107^ | [underlined: Cases]: 202 [underlined: Controls]: 1564 | <1 year | 1.39 | 0.77 to 2.54 | Age, parity, smoking, breastfeeding , age at first birth, duration of contraception use, intake of milk | | 2
Huusom, 2006^107^ | [underlined: Cases]: 202 [underlined: Controls]: 1564 | 1 to 4 yr | 1.00 | Reference | Age, parity, smoking, breastfeeding , age at first birth, duration of contraception use, intake of milk | | 2
Huusom, 2006^107^ | [underlined: Cases]: 202 [underlined: Controls]: 1564 | 5 to 9 yr | 1.23 | 0.70 to 2.16 | Age, parity, smoking, breastfeeding , age at first birth, duration of contraception use, intake of milk | | 2
Huusom, 2006^107^ | [underlined: Cases]: 202 [underlined: Controls]: 1564 | 10+ yr | 0.77 | 0.45 to 1.34 | Age, parity, smoking, breastfeeding , age at first birth, duration of contraception use, intake of milk | | 2
McLaughlin, 2007^116^ | [underlined: Cases]: 128 [underlined: Controls]: 380 | 0 to 1.0 yr | 0.56 | 0.28 to 1.10 | Parity, breastfeeding , tubal ligation, ethnicity | BRCA2 carriers only | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 128 [underlined: Controls]: 380 | 1.1 to 3.0 yr | 0.42 | 0.20 to 0.88 | Parity, breastfeeding , tubal ligation, ethnicity | BRCA2 carriers only | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 128 [underlined: Controls]: 380 | 3.1 to 5.0 yr | 0.14 | 0.05 to 0.46 | Parity, breastfeeding , tubal ligation, ethnicity | BRCA2 carriers only | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 128 [underlined: Controls]: 380 | >5.0 yr | 0.37 | 0.19 to 0.72 | Parity, breastfeeding , tubal ligation, ethnicity | BRCA2 carriers only | 4
McLaughlin, 2007^116^
McLaughlin, 2007^116^ | [underlined: Cases]: 799 [underlined: Controls]: 2424 | 0 to 1.0 yr | 0.67 | 0.50 to 0.89 | Parity, breastfeeding , tubal ligation, ethnicity | All cases and controls have BRCA1 and/or BRCA2 mutations | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 799 [underlined: Controls]: 2424 | 1.1 to 3.0 yr | 0.63 | 0.46 to 0.86 | Parity, breastfeeding , tubal ligation, ethnicity | All cases and controls have BRCA1 and/or BRCA2 mutations | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 799 [underlined: Controls]: 2424 | 3.1 to 5.0 yr | 0.36 | 0.25 to 0.53 | Parity, breastfeeding , tubal ligation, ethnicity | All cases and controls have BRCA1 and/or BRCA2 mutations | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 799 [underlined: Controls]: 2424 | >5.0 yr | 0.47 | 0.35 to 0.62 | Parity, breastfeeding , tubal ligation, ethnicity | All cases and controls have BRCA1 and/or BRCA2 mutations | 4
McLaughlin, 2007^116^
McLaughlin, 2007^116^ | [underlined: Cases]: 670 [underlined: Controls]: 2043 | 0 to 1.0 yr | 0.69 | 0.50 to 0.95 | Parity, breastfeeding , tubal ligation, ethnicity | BRCA1 carriers only | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 670 [underlined: Controls]: 2043 | 1.1 to 3.0 yr | 0.67 | 0.47 to 0.96 | Parity, breastfeeding , tubal ligation, ethnicity | BRCA1 carriers only | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 670 [underlined: Controls]: 2043 | 3.1 to 5.0 yr | 0.41 | 0.27 to 0.63 | Parity, breastfeeding , tubal ligation, ethnicity | BRCA1 carriers only | 4
McLaughlin, 2007^116^ | [underlined: Cases]: 670 [underlined: Controls]: 2043 | >5.0 yr | 0.48 | 0.35 to 0.66 | Parity, breastfeeding , tubal ligation, ethnicity | BRCA1 carriers only | 4
Soegaard, 2007^146^ | [underlined: Cases]: 50 [underlined: Controls]: 1564 | <2 yr | 1.0 | Reference | Age, parity | Mucinous tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 50 [underlined: Controls]: 1564 | 2 to 5 yr | 1.60 | 0.45 to 5.65 | Age, parity | Mucinous tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 50 [underlined: Controls]: 1564 | 6 to 9 yr | 0.95 | 0.20 to 4.49 | Age, parity | Mucinous tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 50 [underlined: Controls]: 1564 | 10+ yr | 1.32 | 0.38 to 4.64 | Age, parity | Mucinous tumors | 3
Soegaard, 2007^146^
Soegaard, 2007^146^ | [underlined: Cases]: 86 [underlined: Controls]: 1564 | <2 yr | 1.0 | Reference | Age, parity | “Other” tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 86 [underlined: Controls]: 1564 | 2 to 5 yr | 0.88 | 0.38 to 2.03 | Age, parity | “Other” tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 86 [underlined: Controls]: 1564 | 6 to 9 yr | 0.36 | 0.10 to 1.29 | Age, parity | “Other” tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 86 [underlined: Controls]: 1564 | 10+ yr | 0.37 | 0.14 to 0.99 | Age, parity | “Other” tumors | 3
Soegaard, 2007^146^
Soegaard, 2007^146^ | [underlined: Cases]: 554 [underlined: Controls]: 1564 | <2 yr | 1.0 | Reference | Age, parity | | 3
Soegaard, 2007^146^ | [underlined: Cases]: 554 [underlined: Controls]: 1564 | 2 to 5 yr | 0.90 | 0.63 to 1.30 | Age, parity | | 3
Soegaard, 2007^146^ | [underlined: Cases]: 554 [underlined: Controls]: 1564 | 6 to 9 yr | 0.40 | 0.24 to 0.66 | Age, parity | | 3
Soegaard, 2007^146^ | [underlined: Cases]: 554 [underlined: Controls]: 1564 | 10+ yr | 0.40 | 0.26 to 0.60 | Age, parity | | 3
Soegaard, 2007^146^
Soegaard, 2007^146^ | [underlined: Cases]: 343 [underlined: Controls]: 1564 | <2 yr | 1.0 | Reference | Age, parity | Serous tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 343 [underlined: Controls]: 1564 | 2 to 5 yr | 0.80 | 0.52 to 1.23 | Age, parity | Serous tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 343 [underlined: Controls]: 1564 | 6 to 9 yr | 0.42 | 0.23 to 0.74 | Age, parity | Serous tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 343 [underlined: Controls]: 1564 | 10+ yr | 0.31 | 0.18 to 0.51 | Age, parity | Serous tumors | 3
Soegaard, 2007^146^
Soegaard, 2007^146^ | [underlined: Cases]: 75 [underlined: Controls]: 1564 | <2 yr | 1.0 | Reference | Age, parity | Endometrioid tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 75 [underlined: Controls]: 1564 | 2 to 5 yr | 1.27 | 0.53 to 3.05 | Age, parity | Endometrioid tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 75 [underlined: Controls]: 1564 | 6 to 9 yr | 0.15 | 0.02 to 1.18 | Age, parity | Endometrioid tumors | 3
Soegaard, 2007^146^ | [underlined: Cases]: 75 [underlined: Controls]: 1564 | 10+ yr | 0.62 | 0.24 to 1.62 | Age, parity | Endometrioid tumors | 3
Jordan, 2008^109^ | [underlined: Cases]: 627 [underlined: Controls]: 1508 | 1 to 12 mo | 1.02 | 0.72 to 1.44 0.53 to 0.95 0.38 to 0.70 0.36 to 0.73 0.23 to 0.58 0.12 to 0.42 | Parity, family history, BTL, OC use, hysterectomy, education | | 1
Jordan, 2008^109^ | [underlined: Cases]: 627 [underlined: Controls]: 1508 | 13 to 60 mo | 0.71 | 0.72 to 1.44 0.53 to 0.95 0.38 to 0.70 0.36 to 0.73 0.23 to 0.58 0.12 to 0.42 | Parity, family history, BTL, OC use, hysterectomy, education | | 1
Jordan, 2008^109^ | [underlined: Cases]: 627 [underlined: Controls]: 1508 | 61 to 120 mo | 0.52 | 0.72 to 1.44 0.53 to 0.95 0.38 to 0.70 0.36 to 0.73 0.23 to 0.58 0.12 to 0.42 | Parity, family history, BTL, OC use, hysterectomy, education | | 1
Jordan, 2008^109^ | [underlined: Cases]: 627 [underlined: Controls]: 1508 | 212 to 180 mo | 0.51 | 0.72 to 1.44 0.53 to 0.95 0.38 to 0.70 0.36 to 0.73 0.23 to 0.58 0.12 to 0.42 | Parity, family history, BTL, OC use, hysterectomy, education | | 1
Jordan, 2008^109^ | [underlined: Cases]: 627 [underlined: Controls]: 1508 | 181 to 240 mo | 0.36 | 0.72 to 1.44 0.53 to 0.95 0.38 to 0.70 0.36 to 0.73 0.23 to 0.58 0.12 to 0.42 | Parity, family history, BTL, OC use, hysterectomy, education | | 1
Jordan, 2008^109^ | [underlined: Cases]: 627 [underlined: Controls]: 1508 | >240 mo | 0.22 | 0.72 to 1.44 0.53 to 0.95 0.38 to 0.70 0.36 to 0.73 0.23 to 0.58 0.12 to 0.42 | Parity, family history, BTL, OC use, hysterectomy, education | | 1
Jordan, 2008^109^ | [underlined: Cases]: 627 [underlined: Controls]: 1508 | per year | 0.95 | 0.72 to 1.44 0.53 to 0.95 0.38 to 0.70 0.36 to 0.73 0.23 to 0.58 0.12 to 0.42 | Parity, family history, BTL, OC use, hysterectomy, education | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | <1 year | 0.74 | 0.53 to 1.01 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 1 to 2 yr | 0.47 | 0.33 to 0.67 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 3 to 6 yr | 0.59 | 0.42 to 0.81 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 7 to 9 yr | 0.49 | 0.31 to 0.78 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | ≥10 yr | 0.30 | 0.19 to 0.47 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | <1 year | 0.8 | 0.4 to 1.7 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women | 4
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | 1 to <5 yr | 0.6 | 0.4 to 1.0 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women | 4
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | 5 to 10 yr | 0.5 | 0.3 to 0.9 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women | 4
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | >10 yr | 0.3 | 0.2 to 0.6 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women | 4
Moorman, 2008^121^
Moorman, 2008^121^ | [underlined: Cases]: 582 [underlined: Controls]: 607 | <1 year | 1.1 | 0.7 to 1.6 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Postmenopausal women | 4
Moorman, 2008^121^ | [underlined: Cases]: 582 [underlined: Controls]: 607 | 1 to <5 yr | 0.7 | 0.5 to 1.0 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Postmenopausal women | 4
Moorman, 2008^121^ | [underlined: Cases]: 582 [underlined: Controls]: 607 | 5 to 10 yr | 0.8 | 0.6 to 1.2 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Postmenopausal women | 4
Moorman, 2008^121^ | [underlined: Cases]: 582 [underlined: Controls]: 607 | >10 yr | 0.9 | 0.6 to 1.5 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Postmenopausal women | 4
Grant, 2010^90^ | [underlined: Cases]: 62 [underlined: Controls]: 1086 | 0 to <1 yr | 0.63 | 0.24 to 1.71 | Age | Serous primary peritoneal cancer | 4
Grant, 2010^90^ | [underlined: Cases]: 62 [underlined: Controls]: 1086 | 1 to <5 yr | 0.80 | 0.38 to 1.70 | Age | Serous primary peritoneal cancer | 4
Grant, 2010^90^ | [underlined: Cases]: 62 [underlined: Controls]: 1086 | 5+ yr | 1.13 | 0.56 to 2.26 | Age | Serous primary peritoneal cancer | 4
Grant, 2010^90^
Grant, 2010^90^ | [underlined: Cases]: 495 [underlined: Controls]: 1086 | 0 to <1 yr | 1.14 | 0.79 to 1.65 | Age | Serous ovarian cancer | 4
Grant, 2010^90^ | [underlined: Cases]: 495 [underlined: Controls]: 1086 | 1 to <5 yr | 0.82 | 0.61 to 1.11 | Age | Serous ovarian cancer | 4
Grant, 2010^90^ | [underlined: Cases]: 495 [underlined: Controls]: 1086 | 5+ yr | 0.74 | 0.55 to 1.00 | Age | Serous ovarian cancer | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for contraception ≤4 yr | 0.91 | 0.75 to 1.10 | Age, race, family history, number of pregnancies, infertility | | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for contraception 5 to 9 yr | 0.78 | 0.59 to 1.05 | Age, race, family history, number of pregnancies, infertility | | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for contraception ≥10 yr | 0.52 | 0.35 to 0.76 | Age, race, family history, number of pregnancies, infertility | | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for noncontraception ≤4 yr | 0.93 | 0.64 to 1.36 | Age, race, family history, number of pregnancies, infertility | | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for noncontraception 5 to 9 yr | 1.60 | 0.58 to 4.47 | Age, race, family history, number of pregnancies, infertility | | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for noncontraception ≥10 yr | 0.53 | 0.11 to 2.62 | Age, race, family history, number of pregnancies, infertility | | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for both ≤4 yr | 1.22 | 0.87 to 1.73 | Age, race, family history, number of pregnancies, infertility | | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for both 5 to 9 yr | 0.72 | 0.46 to 1.12 | Age, race, family history, number of pregnancies, infertility | | 4
Ness, 2011^123^ | [underlined: Cases]: 869 [underlined: Controls]: 1779 | OCs for both ≥10 yr | 0.40 | 0.25 to 0.67 | Age, race, family history, number of pregnancies, infertility | | 4
Wilailak, 2012^160^ | [underlined: Cases]: 330 [underlined: Controls]: 982 | 1 to 12 months | 0.86 | 0.61 to 1.20 | | | 1
Wilailak, 2012^160^ | [underlined: Cases]: 330 [underlined: Controls]: 982 | 13 to 24 months | 0.84 | 0.47 to 1.51 | | | 1
Wilailak, 2012^160^ | [underlined: Cases]: 330 [underlined: Controls]: 982 | 25 to 26 months | 0.56 | 0.28 to 1.14 | | | 1
Wilailak, 2012^160^ | [underlined: Cases]: 330 [underlined: Controls]: 982 | >36 months | 0.43 | 0.29 to 0.64 | | | 1
Cohort
Hankinson, 1995^98^ | [underlined: Exposed:] 592,056 person-yr [underlined: Unexposed:] 599,301 person-yr | Past <1 yr | 1.21 | 0.8 to 1.86 | Age, parity, smoking, BTL, age at menopause, Quetelet's Index | | 7
Hankinson, 1995^98^ | [underlined: Exposed:] 592,056 person-yr [underlined: Unexposed:] 599,301 person-yr | Past 1 to <3 yr | 1.09 | 0.69 to 1.71 | Age, parity, smoking, BTL, age at menopause, Quetelet's Index | | 7
Hankinson, 1995^98^ | [underlined: Exposed:] 592,056 person-yr [underlined: Unexposed:] 599,301 person-yr | Past 3 to <5 yr | 0.8 | 0.42 to 1.52 | Age, parity, smoking, BTL, age at menopause, Quetelet's Index | | 7
Hankinson, 1995^98^ | [underlined: Exposed:] 592,056 person-yr [underlined: Unexposed:] 599,301 person-yr | Past ≥5 yr | 0.65 | 0.4 to 1.05 | Age, parity, smoking, BTL, age at menopause, Quetelet's Index | | 7
Hankinson, 1995^98^ | [underlined: Exposed:] 592,056 person-yr [underlined: Unexposed:] 599,301 person-yr | Current | 1.92 | 0.69 to 5.33 | Age, parity, smoking, BTL, age at menopause, Quetelet's Index | | 7
Vessey, 1995^157^ | [underlined: Exposed:] 3520 [underlined: Unexposed:] 5881 | Up to 48 total mo of use | 1.0 | 0.4 to 2.5 | Age, parity | | 7
Vessey, 1995^157^ | [underlined: Exposed:] 3520 [underlined: Unexposed:] 5881 | 49 to 96 total mo of use | 0.3 | 0.0 to 1.1 | Age, parity | | 7
Vessey, 1995^157^ | [underlined: Exposed:] 3520 [underlined: Unexposed:] 5881 | 97+ mo of use | 0.3 | 0.1 to 0.7 | Age, parity | | 7
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | <1 yr | 0.9 | 0.5 to 1.4 | Age, parity, menopausal status, HRT, country | | 1
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | 1 to 4 yr | 0.5 | 0.4 to 0.8 | Age, parity, menopausal status, HRT, country | | 1
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | 5 to 9 yr | 0.6 | 0.4 to 0.9 | Age, parity, menopausal status, HRT, country | | 1
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | 10 to 14 yr | 0.5 | 0.3 to 1.0 | Age, parity, menopausal status, HRT, country | | 1
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | 15+ yr | 0.1 | 0.01 to 0.6 | Age, parity, menopausal status, HRT, country | | 1
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | Current | 0.5 | 0.2 to 0.9 | Age, parity, menopausal status, HRT, country | | 1
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | Former | 0.6 | 0.5 to 0.8 | Age, parity, menopausal status, HRT, country | | 1
Kumle, 2004^110^
Kumle, 2004^110^ | | Current | 0.5 | 0.2 to 1.6 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | | Former | 0.7 | 0.5 to 1.2 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | | <1 year | 0.2 | 0.1 to 1.0 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | | 1 to 4 yr | 0.6 | 0.3 to 1.2 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | | 5 to 9 yr | 0.7 | 0.4 to 1.4 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | | 10 to 14 yr | 0.9 | 0.4 to 2.0 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | | 15+ yr | NR | NR | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | | per year | 0.96 | 0.91 to 1.0 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^
Kumle, 2004^110^ | | <1 yr | 1.2 | 0.7 to 2.0 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer only | 1
Kumle, 2004^110^ | | 1 to 4 yr | 0.5 | 0.3 to 0.8 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer only | 1
Kumle, 2004^110^ | | 5 to 9 yr | 0.6 | 0.3 to 0.9 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer only | 1
Kumle, 2004^110^ | | 10 to 14 yr | 0.3 | 0.1 to 0.8 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer only | 1
Kumle, 2004^110^ | | 15+ yr | 0.1 | 0.02 to 0.8 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer only | 1
Kumle, 2004^110^ | | Current | 0.4 | 0.2 to 1.0 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer only | 1
Kumle, 2004^110^ | | Former | 0.6 | 0.4 to 0.8 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer only | 1
Vessey, 2006^156^ | [underlined: Exposed:] 301,000 person-years [underlined: Unexposed:] 187,000 person-years | up to 48 mo | 1.0 | 0.6 to 1.7 | Age, parity, BMI, smoking, social class, height, age at first term pregnancy, age at first marriage | Ovarian cancer | 2
Vessey, 2006^156^ | [underlined: Exposed:] 301,000 person-years [underlined: Unexposed:] 187,000 person-years | 48 to 96 mo | 0.3 | 0.1 to 0.6 | Age, parity, BMI, smoking, social class, height, age at first term pregnancy, age at first marriage | Ovarian cancer | 2
Vessey, 2006^156^ | [underlined: Exposed:] 301,000 person-years [underlined: Unexposed:] 187,000 person-years | 97+ mo | 0.3 | 0.1 to 0.5 | Age, parity, BMI, smoking, social class, height, age at first term pregnancy, age at first marriage | Ovarian cancer | 2
Hannaford, 2007^37^ | [underlined: Exposed:] 744,000 person-years of observation [underlined: Unexposed:] 339,000 person-years of observation | <48 mo | 0.58 | 0.33 to 1.04 | Age, parity, smoking, social status, ever use of HRT | General practitioner dataset | 1
Hannaford, 2007^37^ | [underlined: Exposed:] 744,000 person-years of observation [underlined: Unexposed:] 339,000 person-years of observation | 49 to 96 mo | 0.57 | 0.30 to 1.07 | Age, parity, smoking, social status, ever use of HRT | General practitioner dataset | 1
Hannaford, 2007^37^ | [underlined: Exposed:] 744,000 person-years of observation [underlined: Unexposed:] 339,000 person-years of observation | >96 mo | 0.38 | 0.16 to 0.88 | Age, parity, smoking, social status, ever use of HRT | General practitioner dataset | 1
Tworoger, 2007^154^ | [underlined: Exposed:] 41,125 [underlined: Unexposed:] 54,027 | ≤3 yr | 1.12 | 0.90 to 1.38 | Age, parity, menopausal status, BMI, age at menarche, smoking, BTL and HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed:] 41,125 [underlined: Unexposed:] 54,027 | >3 to 5 yr | 0.97 | 0.66 to 1.41 | Age, parity, menopausal status, BMI, age at menarche, smoking, BTL and HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed:] 41,125 [underlined: Unexposed:] 54,027 | >5 to 10 yr | 0.75 | 0.54 to 1.05 | Age, parity, menopausal status, BMI, age at menarche, smoking, BTL and HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed:] 41,125 [underlined: Unexposed:] 54,027 | >10 yr | 0.62 | 0.37 to 1.04 | Age, parity, menopausal status, BMI, age at menarche, smoking, BTL and HRT use | | 1
Antoniou, 2009^81^ | [underlined: Exposed:] 2415 [underlined: Unexposed:] 766 | >0 to 1 yr | 1.04 | 0.66 to 1.62 | Parity | BRCA1 and BRCA2 mutation carriers | 4
Antoniou, 2009^81^ | [underlined: Exposed:] 2415 [underlined: Unexposed:] 766 | >1 to 3 yr | 0.60 | 0.35 to 1.03 | Parity | BRCA1 and BRCA2 mutation carriers | 4
Antoniou, 2009^81^ | [underlined: Exposed:] 2415 [underlined: Unexposed:] 766 | >3 to 5 yr | 0.41 | 0.19 to 0.87 | Parity | BRCA1 and BRCA2 mutation carriers | 4
Antoniou, 2009^81^ | [underlined: Exposed:] 2415 [underlined: Unexposed:] 766 | >5 yr | 0.35 | 0.22 to 0.55 | Parity | BRCA1 and BRCA2 mutation carriers | 4
Antoniou, 2009^81^
Antoniou, 2009^81^ | [underlined: Exposed:] 1655 [underlined: Unexposed:] 512 | >0 to 1 year | 1.03 | 0.64 to 1.65 | Parity | BRCA1 mutation carriers | 4
Antoniou, 2009^81^ | [underlined: Exposed:] 1655 [underlined: Unexposed:] 512 | >1 to 3 yr | 0.51 | 0.28 to 0.93 | Parity | BRCA1 mutation carriers | 4
Antoniou, 2009^81^ | [underlined: Exposed:] 1655 [underlined: Unexposed:] 512 | >3 to 5 yr | 0.40 | 0.17 to 0.91 | Parity | BRCA1 mutation carriers | 4
Antoniou, 2009^81^ | [underlined: Exposed:] 1655 [underlined: Unexposed:] 512 | >5 yr | 0.34 | 0.21 to 0.54 | Parity | BRCA1 mutation carriers | 4
Antoniou, 2009^81^
Antoniou, 2009^81^ | [underlined: Exposed:] 760 [underlined: Unexposed:] 245 | >0 to 5 yr | 1.33 | 0.52 to 3.39 | Parity | BRCA2 mutation carriers | 4
Antoniou, 2009^81^ | [underlined: Exposed:] 760 [underlined: Unexposed:] 245 | >5 yr | 0.59 | 0.16 to 2.24 | Parity | BRCA2 mutation carriers | 4
Dorjgochoo, 2009^88^ | [underlined: Exposed:] 12,957 [underlined: Unexposed:] 15,557 | <2 yr | 1.58 | 0.89 to 2.83 | Age, parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | Only reporting for women using OC as others in the cohort used other forms of contraception. | 2
Dorjgochoo, 2009^88^ | [underlined: Exposed:] 12,957 [underlined: Unexposed:] 15,557 | ≥2 yr | 0.65 | 0.29 to 1.44 | Age, parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | Only reporting for women using OC as others in the cohort used other forms of contraception. | 2
Rosenblatt, 2009^138^ | [underlined: Exposed:] 352,695 person-years [underlined: Unexposed:] 2,057,377 person-years | 1 to 11 mo | 1.36 | 0.87 to 2.13 | Age, parity, use of injectable contraceptives | | 1
Rosenblatt, 2009^138^ | [underlined: Exposed:] 352,695 person-years [underlined: Unexposed:] 2,057,377 person-years | 12 to 59 mo | 0.82 | 0.47 to 1.41 | Age, parity, use of injectable contraceptives | | 1
Rosenblatt, 2009^138^ | [underlined: Exposed:] 352,695 person-years [underlined: Unexposed:] 2,057,377 person-years | 60+ mo | 1.44 | 0.87 to 2.39 | Age, parity, use of injectable contraceptives | | 1
Braem, 2010^85^ | [underlined: Exposed:] 8,668 person-years [underlined: Unexposed:] 25,916 person-years | ≤5 yr | 0.92 | 0.61 to 1.38 | Age, parity | | 2
Braem, 2010^85^ | [underlined: Exposed:] 8,668 person-years [underlined: Unexposed:] 25,916 person-years | >5 yr | 0.47 | 0.30 to 0.76 | Age, parity | | 2
Braem, 2010^85^ | [underlined: Exposed:] 8,668 person-years [underlined: Unexposed:] 25,916 person-years | per year | 0.95 | 0.91 to 0.99 | Age, parity | | 2
Tsilidis, 2011^151^ | [underlined: Exposed]: 67,870 women OC exposed [underlined: Unexposed]: 100,304 women OC unexposed | ≤1 yr | 1.00 | Reference | Age, parity, menopausal status, BMI, smoking, center, unilateral oophorectomy, hysterectomy, menopausal hormones, age at menarche | | 3
Tsilidis, 2011^151^ | [underlined: Exposed]: 67,870 women OC exposed [underlined: Unexposed]: 100,304 women OC unexposed | 2 to 4 yr | 1.05 | 0.79 to 1.38 | Age, parity, menopausal status, BMI, smoking, center, unilateral oophorectomy, hysterectomy, menopausal hormones, age at menarche | | 3
Tsilidis, 2011^151^ | [underlined: Exposed]: 67,870 women OC exposed [underlined: Unexposed]: 100,304 women OC unexposed | 5 to 9 yr | 0.80 | 0.59 to 108 | Age, parity, menopausal status, BMI, smoking, center, unilateral oophorectomy, hysterectomy, menopausal hormones, age at menarche | | 3
Tsilidis, 2011^151^ | [underlined: Exposed]: 67,870 women OC exposed [underlined: Unexposed]: 100,304 women OC unexposed | ≥10 yr | 0.55 | 0.41 to 0.75 | Age, parity, menopausal status, BMI, smoking, center, unilateral oophorectomy, hysterectomy, menopausal hormones, age at menarche | | 3
Yang, 2012^162^ | [underlined: Exposed]: 192,836 women OC exposed [underlined: Unexposed]: 132,923 women OC unexposed | 1 to 4 yr | 0.82 | 0.67 to 1.00 | Age, parity, menopausal hormone therapy | | 1
Yang, 2012^162^ | [underlined: Exposed]: 192,836 women OC exposed [underlined: Unexposed]: 132,923 women OC unexposed | 5 to 9 yr | 0.78 | 0.62 to 0.98 | Age, parity, menopausal hormone therapy | | 1
Yang, 2012^162^ | [underlined: Exposed]: 192,836 women OC exposed [underlined: Unexposed]: 132,923 women OC unexposed | ≥10 yr | 0.56 | 0.42 to 0.75 | Age, parity, menopausal hormone therapy | | 1

BMI = body mass index; BRCA = breast cancer genetic mutation; BSO = bilateral salpingo-oophorectomy; BTL = bilateral tubal ligation; CI = confidence interval; GCT = granulosa cell tumor; HRT = hormone replacement therapy; IUD = intrauterine device; mo = month/months; OC = oral contraceptive; OR = odds ratio; NR = not reported; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Unless otherwise presented, never use is the reference category with an OR=1.0.

c Meta-analysis code:1=Included in this meta-analysis; 2=Excluded due to less than three duration categories; 3=Excluded due to never use is not the reference group; 4=Excluded due to odds ratios only provided for subpopulations; 5=Excluded due to odds ratios only provided per year of OC use; 6=Excluded due to study is grouped with another included article also reporting duration data; 7=Excluded in main analyses of studies from 2000 forward, included in sensitivity analyses of studies from 1990 forward.

Table 7 and Figure 12 show the odds ratios for the meta-analysis of duration of OC use. These findings indicate a significant duration-response relationship between OC use and ovarian cancer incidence, with higher levels of protection afforded to women who use OCs for longer duration. Women using oral contraceptives for 10 or more years show a reduction in ovarian cancer incidence of more than 50 percent. There is no evidence of heterogeneity. The estimated value of σ is 0.15.

Table 7 Estimated odds ratios by duration of OC use (ovarian cancer incidence)

Duration Interval | Odds Ratio (95% Confidence Interval) | P-Value
1–12 months | 0.91 (0.78 to 1.07) | 0.2504
13–60 months | 0.77 (0.66 to 0.89) | 0.0014
61–120 months | 0.65 (0.55 to 0.77) | <0.0001
>120 months | 0.43 (0.37 to 0.51) | <0.0001

Figure 12 Impact of duration of OC use on ovarian cancer incidence

Description: Figure 12 show the odds ratios for the meta-analysis of duration of OC use. These findings indicate a significant duration-response relationship between OC use and ovarian cancer incidence, with higher levels of protection afforded to women who use OCs for longer duration.

###### Pooled Analyses

Four pooled analyses21,23,105,120 reported on duration of OC use but did not meet criteria for inclusion in the meta-analysis. The three largest of these studies reported a significantly lower incidence of ovarian cancer following longer duration of OC use.21,23,120 The one remaining study105 examined only OC use of less than or greater than 1 year and did not identify a clear trend.

###### Sensitivity Analyses

We repeated our analyses excluding the 10 studies not conducted within the United States. The estimates for the remaining 5 studies (3 case-control and 2 cohort) were 0.84 (95% CI, 0.67 to 1.05) for <1 year duration, 0.72 (CI, 0.59 to 0.89) for 1 to 5 years' duration, 0.64 (CI, 0.51 to 0.81) for >5 to 10 years' duration, and 0.42 (CI, 0.32 to 0.56) for >10 years' duration.

We also performed analyses for studies published from 1990 forward (18 studies, 13 case-control and 5 cohort). The estimates were 0.93 (95% CI, 0.81 to 1.06) for <1 year duration, 0.81 (CI, 0.72 to 0.91) for 1 to 5 years' duration, 0.65 (CI, 0.56 to 0.75) for >5 to 10 years' duration, and 0.44 (CI, 0.39 to 0.51) for >10 years' duration.

We also conducted a sensitivity analysis in which we included the large pooled analysis by Beral et al.21 but excluded the individual studies from our meta-analysis that had been included in their pooled analysis.87,110,118,125,133,141 The estimates were 0.91 (95% CI, 0.75 to 1.09) for <1 year duration, 0.75 (CI, 0.63 to 0.91) for 1 to 5 years' duration, 0.57 (CI, 0.47 to 0.69) for >5 to 10 years' duration, and 0.43 (CI, 0.35 to 0.51) for >10 years' duration, similar to the estimates from the main meta-analysis.

##### Age at First OC Use

Six studies110,114,121,125,141,144,145 were included in the primary meta-analysis examining the effect of age at first OC use on ovarian cancer incidence. Of these, 5 were case-control studies representing 3,552 cases and 4,713 controls, and 1 was a cohort study representing 103,552 participants. Four studies were rated good quality and 2 fair quality. Abstracted data not included in this analysis are specified (with rationale) in Table 8. Reasons for exclusion from this analysis included the following: reporting data for fewer than three age categories; providing odds ratios for subpopulations only; or in one instance,100 not meeting publication date criteria to include in the primary meta-analysis.

Table 8 Data for outcomes on age at first OC use (ovarian cancer incidence)

Study^a^ | Sample Size | Comparisons (Age in Years) | OR^b^ | 95% CI^b^ | Covariates | Special Population (if Applicable) | Meta- Analysis Code^c^
Case-Control
Harlow, 1991^100^ | [underlined: Cases]: 194 [underlined: Controls]: 193 | <21 | 0.8 | 0.4 to 1.8 | Age, parity, religion | | 4
Harlow, 1991^100^ | [underlined: Cases]: 194 [underlined: Controls]: 193 | 22 to 26 | 0.7 | 0.3 to 1.4 | Age, parity, religion | | 4
Harlow, 1991^100^ | [underlined: Cases]: 194 [underlined: Controls]: 193 | >26 | 0.8 | 0.4 to 1.4 | Age, parity, religion | | 4
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | <20 | 0.6 | 0.4 to 0.8 | Age, race, family history, number of pregnancies | | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | 20 to 24 | 0.6 | 0.5 to 0.8 | Age, race, family history, number of pregnancies | | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | 25 to 29 | 0.5 | 0.4 to 0.8 | Age, race, family history, number of pregnancies | | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | 30 to 34 | 0.8 | 0.5 to 1.2 | Age, race, family history, number of pregnancies | | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | ≥35 | 0.8 | 0.4 to 1.3 | Age, race, family history, number of pregnancies | | 1
Ness, 2000^125^
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | <20 | 1.0 | Reference | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | 20 to 24 | 1.0 | 0.7 to 1.4 | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | 25 to 29 | 0.8 | 0.5 to 1.2 | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | 30 to 34 | 0.9 | 0.5 to 1.7 | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | ≥35 | 0.8 | 0.4 to 1.7 | Age, race, family history, number of pregnancies | Invasive ovarian cancer (N=616) | 1
Ness, 2000^125^
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | <20 | 1.0 | Reference | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | 20 to 24 | 1.0 | 0.6 to 1.6 | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | 25 to 29 | 0.5 | 0.2 to 1.2 | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | 30 to 34 | 0.8 | 0.3 to 2.5 | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | ≥35 | 0.7 | 0.2 to 2.7 | Age, race, family history, number of pregnancies | Borderline ovarian cancer (N=151) | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | <20 | 1.0 | Reference | Duration of use, overall and before 1st pregnancy, age at first use, time since last use | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 20 to 24 | 1.34 | 0.82 to 2.2 | Duration of use, overall and before 1st pregnancy, age at first use, time since last use | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 25 to 29 | 1.82 | 0.96 to 3.4 | Duration of use, overall and before 1st pregnancy, age at first use, time since last use | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 30 to 34 | 2.1 | 0.98 to 4.6 | Duration of use, overall and before 1st pregnancy, age at first use, time since last use | | 1
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | >35 | 1.66 | 0.68 to 4.0 | Duration of use, overall and before 1st pregnancy, age at first use, time since last use | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 14 to 16 | 0.31 | 0.12 to 0.80 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 17 to 19 | 0.18 | 0.08 to 0.40 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 20 to 24 | 0.20 | 0.10 to 0.45 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 25 to 29 | 0.40 | 0.21 to 0.76 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 30+ | 0.69 | 0.42 to 1.11 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Greer, 2005^91^ | [underlined: Cases]: 405 [underlined: Controls]: 592 | <20 | 0.42 | 0.23 to 0.75 | age, parity, family history, tubal ligation | Compared never users to androgenic only OC users | 2, 3
Greer, 2005^91^ | [underlined: Cases]: 405 [underlined: Controls]: 592 | >20 | 0.51 | 0.32 to 0.79 | age, parity, family history, tubal ligation | Compared never users to androgenic only OC users | 2, 3
Greer, 2005^91^
Greer, 2005^91^ | [underlined: Cases]: 381 [underlined: Controls]: 761 | <20 | 0.54 | 0.34 to 0.85 | Age, parity, family history, BTL | Compared never users to nonandrogenic only OC users | 2, 3
Greer, 2005^91^ | [underlined: Cases]: 381 [underlined: Controls]: 761 | ≥20 | 0.63 | 0.47 to 0.85 | Age, parity, family history, BTL | Compared never users to nonandrogenic only OC users | 2, 3
Greer, 2005^91^
Greer, 2005^91^ | [underlined: Cases]: 364 [underlined: Controls]: 529 | <20 | 0.26 | 0.13 to 0.52 | Age, parity, family history, tubal ligation | Compared never users to both androgenic and nonandrogenic OC users | 2, 3
Greer, 2005^91^ | [underlined: Cases]: 364 [underlined: Controls]: 529 | 20+ | 0.28 | 0.13 to 0.58 | Age, parity, family history, tubal ligation | Compared never users to both androgenic and nonandrogenic OC users | 2, 3
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | <20 | 0.39 | 0.27 to 0.56 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 20 to 24 | 0.59 | 0.44 to 0.79 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 25 to 29 | 0.54 | 0.37 to 0.79 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | ≥30 | 0.58 | 0.39 to 0.86 | Age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | <20 | 0.5 | 0.3 to 0.8 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | 20 to 24 | 0.5 | 0.3 to 0.9 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | 25 to 29 | 0.4 | 0.2 to 1.0 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | >29 | 1.2 | 0.3 to 4.4 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women | 1
Moorman, 2008^121^
Moorman, 2008^121^ | [underlined: Cases]: 582 [underlined: Controls]: 607 | <20 | 0.9 | 0.5 to 1.3 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Postmenopausal women | 1
Moorman, 2008^121^ | [underlined: Cases]: 582 [underlined: Controls]: 607 | 20 to 24 | 0.8 | 0.6 to 1.1 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Postmenopausal women | 1
Moorman, 2008^121^ | [underlined: Cases]: 582 [underlined: Controls]: 607 | 25 to 29 | 0.8 | 0.5 to 1.2 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Postmenopausal women | 1
Moorman, 2008^121^ | [underlined: Cases]: 582 [underlined: Controls]: 607 | >29 | 0.9 | 0.6 to 1.4 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Postmenopausal women | 1
Cohort
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 [underlined: Unexposed:] 28,019 | <20 | 0.5 | 0.3 to 1.0 | Age, parity, menopausal status, HRT, country | Invasive ovarian Cancer only | 1
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 [underlined: Unexposed:] 28,019 | 20 to 24 | 0.4 | 0.3 to 0.7 | Age, parity, menopausal status, HRT, country | Invasive ovarian Cancer only | 1
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 [underlined: Unexposed:] 28,019 | 25+ | 0.7 | 0.5 to 1.1 | Age, parity, menopausal status, HRT, country | Invasive ovarian Cancer only | 1
Kumle, 2004^110^
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | <20 | 0.4 | 0.2 to 0.9 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | 20 to 24 | 0.8 | 0.5 to 1.4 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed:] 28,019 | 25+ | 0.8 | 0.4 to 1.4 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer only | 1
Kumle, 2004^110^
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 women exposed [underlined: Unexposed:] 28,019 women unexposed | <20 yr | 0.6 | 0.3 to 1.0 | Age, parity, menopausal status, HRT, country, duration of use | | 1
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 women exposed [underlined: Unexposed:] 28,019 women unexposed | 20 to 24 | 0.7 | 0.5 to 1.1 | Age, parity, menopausal status, HRT, country, duration of use | | 1
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 women exposed [underlined: Unexposed:] 28,019 women unexposed | 25+ | 1.0 | 0.6 to 1.5 | Age, parity, menopausal status, HRT, country, duration of use | | 1
Antoniou, 2009^81^ | [underlined: Exposed]: 2415 [underlined: Unexposed:] 766 | Never | 1.72 | 1.05 to 2.82 | Parity | BRCA1 and BRCA2 mutation carriers | 2
Antoniou, 2009^81^ | [underlined: Exposed]: 2415 [underlined: Unexposed:] 766 | <20 | 1.00 | Reference | Parity | BRCA1 and BRCA2 mutation carriers | 2
Antoniou, 2009^81^ | [underlined: Exposed]: 2415 [underlined: Unexposed:] 766 | 20 to 24 | 0.88 | 0.51 to 1.50 | Parity | BRCA1 and BRCA2 mutation carriers | 2
Antoniou, 2009^81^ | [underlined: Exposed]: 2415 [underlined: Unexposed:] 766 | ≥25 | 0.96 | 0.53 to 1.73 | Parity | BRCA1 and BRCA2 mutation carriers | 2
Antoniou, 2009^81^
Antoniou, 2009^81^ | [underlined: Exposed:] 1655 [underlined: Unexposed:] 512 | Never | 1.75 | 1.05 to 2.90 | Parity | BRCA1 mutation carriers | 2
Antoniou, 2009^81^ | [underlined: Exposed:] 1655 [underlined: Unexposed:] 512 | <20 | 1.00 | Reference | Parity | BRCA1 mutation carriers | 2
Antoniou, 2009^81^ | [underlined: Exposed:] 1655 [underlined: Unexposed:] 512 | 20 to 24 | 0.86 | 0.49 to 1.50 | Parity | BRCA1 mutation carriers | 2
Antoniou, 2009^81^ | [underlined: Exposed:] 1655 [underlined: Unexposed:] 512 | ≥25 | 0.87 | 0.46 to 1.65 | Parity | BRCA1 mutation carriers | 2
Antoniou, 2009^81^
Antoniou, 2009^81^ | [underlined: Exposed]: 760 [underlined: Unexposed:] 245 | Never | 1.25 | 0.31 to 5.08 | Parity | BRCA2 mutation carriers | 2
Antoniou, 2009^81^ | [underlined: Exposed]: 760 [underlined: Unexposed:] 245 | <20 | 1.00 | Reference | Parity | BRCA2 mutation carriers | 2
Antoniou, 2009^81^ | [underlined: Exposed]: 760 [underlined: Unexposed:] 245 | >20 | 1.46 | 0.35 to 6.01 | Parity | BRCA2 mutation carriers | 2
Dorjgochoo, 2009^88^ | [underlined: Exposed]: 12,957 [underlined: Unexposed:] 15,557 | <29 | 1.26 | 0.64 to 2.46 | Parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | | 3
Dorjgochoo, 2009^88^ | [underlined: Exposed]: 12,957 [underlined: Unexposed:] 15,557 | ≥29 | 0.99 | 0.51 to 1.92 | Parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | | 3
Braem, 2010^85^ | [underlined: Exposed:] 8,668 person-years [underlined: Unexposed:] 25,916 person-years | ≤40 | 1.0 | Reference | Age, parity, duration of OC use | | 3
Braem, 2010^85^ | [underlined: Exposed:] 8,668 person-years [underlined: Unexposed:] 25,916 person-years | >40 | 1.28 | 0.68 to 2.43 | Age, parity, duration of OC use | | 3

BMI = body mass index; BRCA = breast cancer genetic mutation; BSO = bilateral salpingo-oophorectomy; BTL = bilateral tubal ligation; CI = confidence interval; GCT = granulosa cell tumor; HRT = hormone replacement therapy; IUD = intrauterine device; NR=not reported; OC = oral contraceptive; OR = odds ratio

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Unless otherwise presented, never use is the reference category with an OR=1.0.

c Meta-analysis code: 1=Included in this meta-analysis; 2=Excluded due to odds ratios provided for subpopulations only; 3=Excluded due to less than three age-at-first-use categories provided; 4=Excluded in main analyses of studies from 2000 forward, included in sensitivity analyses of studies from 1990 forward.

Table 9 lists the odds ratios for the meta-analysis of age at first OC use. The results show a relatively strong relationship between age at first use and ovarian cancer incidence, although confidence intervals overlap. If there is an effect of earlier age, it is unclear whether the relation is linear or whether there is a threshold effect (i.e., less protection in women who start OCs after age 30). Unfortunately, most studies did not control for duration of use. This potential confounder lessens the strength of this finding.

Table 9 Estimated odds ratios by age at first OC use (ovarian cancer incidence)

Age Interval | Odds Ratio (95% Confidence Interval) | P-Value
< 20 years | 0.63 (0.45 to 0.89) | 0.018
20–24 years | 0.71 (0.51 to 0.99) | 0.044
25–30 years | 0.67 (0.46 to 0.99) | 0.045
> 30 years | 0.89 (0.60 to 1.32) | 0.489

###### Pooled Analyses

Two pooled analyses21,23 reported on age at first use, with none reporting significant trends. One study21 reported that there was no heterogeneity in the decline in relative risk of ovarian cancer with increasing duration of use across women who started OCs at different ages.

###### Sensitivity Analyses

We repeated our analyses excluding the three studies not conducted within the United States. The estimates for the remaining three studies, all case-control, were 0.70 (95% CI, 0.27 to 1.75) for age <20 years, 0.86 (CI, 0.34 to 2.20) for age 20 to <24 years, 0.83 (CI, 0.30 to 2.27) for age 24 to <30 years, and 0.93 (CI, 0.33 to 1.67) for age ≥30 years.

We also performed analyses for studies published from 1990 forward (7 studies, 6 case-control and 1 cohort). The estimates were 0.64 (95% CI, 0.47 to 0.87) for age <20 years, 0.71 (CI, 0.53 to 0.96) for age 20 to <24 years, 0.67 (CI, 0.48 to 0.95) for age 24 to <30 years, and 0.89 (CI, 0.63 to 1.28) for age ≥30 years.

##### Time Since Last OC Use

Eight studies37,110,114,121,125,133,134,141,154 were included in this meta-analysis examining the effect of time since last OC use on ovarian cancer incidence. Of these, 5 were case-control studies representing 3606 cases and 7759 controls, and 3 were cohort studies representing 198,704 participants and 1,083,000 person years. Four studies were rated good quality and 4 fair quality. Abstracted data not included in this analysis are specified (with rationale) in Table 10. Reasons for exclusion from this analysis included the following: using fewer than three comparisons; presenting categories that were not amenable to a combined analysis; and reporting time since last use data from the same study as another article already included in the analysis (Table 10). None of the three pooled analyses reporting on time since last use met inclusion criteria for meta-analysis.

Table 10 Data for outcomes on time since last OC use (ovarian cancer incidence)

Study^a^ | Sample Size | Comparisons (Time Since Last Use) | OR^b^ | 95% CI^b^ | Covariates | Special Population (if Applicable) | Meta- Analysis Code^c^
Case-Control
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | 1 to 24 mo | 0.69 | 0.26 to 1.82 | Age, center, years of disease, live births | High dose | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | 25 to 84 mo | 0.76 | 0.35 to 1.68 | Age, center, years of disease, live births | High dose | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | 85 to 132 mo | 0.88 | 0.38 to 2.05 | Age, center, years of disease, live births | High dose | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | 133+ mo | 0.44 | 0.22 to 0.99 | Age, center, years of disease, live births | High dose | 4
Rosenblatt, 1992^140^
Rosenblatt, 1992^140^ | | 1 to 24 mo | 1.45 | 0.74 to 2.85 | Age, center, years of disease, live births | Low dose | 4
Rosenblatt, 1992^140^ | | 25 to 84 mo | 0.70 | 0.28 to 1.75 | Age, center, years of disease, live births | Low dose | 4
Rosenblatt, 1992^140^ | | 85 to 132 mo | 0.77 | 0.27 to 2.21 | Age, center, years of disease, live births | Low dose | 4
Rosenblatt, 1992^140^ | | 133+ mo | 0.48 | 0.16 to 1.39 | Age, center, years of disease, live births | Low dose | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | <15 yr | 0.4 | 0.2 to 0.8 | Parity, hysterectomy, BTL, removal of one ovary, race, family history, age, geographic area | | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 15 to 19 yr | 0.5 | 0.3 to 1.0 | Parity, hysterectomy, BTL, removal of one ovary, race, family history, age, geographic area | | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 20+ | 0.8 | 0.4 to 1.5 | Parity, hysterectomy, BTL, removal of one ovary, race, family history, age, geographic area | | 4
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | ≤5 yr | 0.6 | 0.2 to 2.2 | Age, parity, duration of use | Mucinous ovarian cases | 4
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | 6 to 15 yr | 0.6 | 0.2 to 1.7 | Age, parity, duration of use | Mucinous ovarian cases | 4
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | 15+ yr | 1.2 | 0.5 to 2.9 | Age, parity, duration of use | Mucinous ovarian cases | 4
Wittenberg, 1999^161^
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | ≤5 yr | 0.6 | 0.3 to 1.3 | Age, parity, duration of use | Nonmucinous cases | 4
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | 6 to 15 yr | 0.6 | 0.3 to 1.0 | Age, parity, duration of use | Nonmucinous cases | 4
Wittenberg, 1999^161^ | [underlined: Cases]: 322 [underlined: Controls]: 426 | 15+ yr | 1.1 | 0.7 to 1.7 | Age, parity, duration of use | Nonmucinous cases | 4
Huusom, 2000^107^ | [underlined: Cases]: 202 [underlined: Controls]: 1564 | 0 to 10 yr | 1 | Reference | Age, childbirth, additional births, first birth, breastfeeding, duration of use, smoking, intake of milk | Borderline ovarian cancer | 2
Huusom, 2000^107^ | [underlined: Cases]: 202 [underlined: Controls]: 1564 | 11 to 20 yr | 1.59 | 0.80 to 3.16 | Age, childbirth, additional births, first birth, breastfeeding, duration of use, smoking, intake of milk | Borderline ovarian cancer | 2
Huusom, 2000^107^ | [underlined: Cases]: 202 [underlined: Controls]: 1564 | 21+ yr | 1.63 | 0.72 to 3.70 | Age, childbirth, additional births, first birth, breastfeeding, duration of use, smoking, intake of milk | Borderline ovarian cancer | 2
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | <10 yr | 0.4 | 0.3 to 0.6 | Age, number of pregnancies, family history of ovarian cancer, race | | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | 10 to 19 yr | 0.6 | 0.4 to 0.8 | Age, number of pregnancies, family history of ovarian cancer, race | | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | 20 to 29 yr | 0.6 | 0.5 to 0.8 | Age, number of pregnancies, family history of ovarian cancer, race | | 1
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | ≥30 yr | 1.0 | 0.6 to 1.4 | Age, number of pregnancies, family history of ovarian cancer, race | | 1
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | Never or < 3 mo | 1 | Reference | Age, parity | | 2
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | <10 yr | 0.7 | 0.4 to 1.3 | Age, parity | | 2
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | 10+ yr | 0.8 | 0.5 to 1.2 | Age, parity | | 2
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | <1 yr | 0.78 | 0.30 to 2.0 | | | 3
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 1 to <5 yr | 1.46 | 0.58 to 3.6 | | | 3
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 5 to <10 yr | 1.02 | 0.48 to 2.2 | | | 3
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 10 to <20 yr | 1.4 | 0.91 to 2.1 | | | 3
Siskind, 2000^145^ | [underlined: Cases]: 794 [underlined: Controls]: 853 | 20+ yr | 1 | Reference | | | 3
Chiaffarino, 2001^87^ | [underlined: Cases]: 1031 [underlined: Controls]: 2411 | <10 yr | 0.5 | 0.2 to 1.1 | Age, parity, family history, center, education | | 2
Chiaffarino, 2001^87^ | [underlined: Cases]: 1031 [underlined: Controls]: 2411 | ≥10 yr | 0.5 | 0.2 to 1.2 | Age, parity, family history, center, education | | 2
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 0 yr | 0.17 | 0.07 to 0.43 | Parity, breastfeeding, family history, BTL, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 1 to 5 yr | 0.34 | 0.16 to 0.73 | Parity, breastfeeding, family history, BTL, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 6 to 10 yr | 0.49 | 0.23 to 1.03 | Parity, breastfeeding, family history, BTL, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 11 to 20 yr | 0.45 | 0.28 to 0.73 | Parity, breastfeeding, family history, BTL, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | 21+ yr | 0.52 | 0.28 to 0.96 | Parity, breastfeeding, family history, BTL, hysterectomy | | 1
Riman, 2002^134^ | [underlined: Cases]: 655 [underlined: Controls]: 3899 | <15 yr | 0.45 | 0.27 to 0.73 | Age, parity, BMI, age of menopause | | 1
Riman, 2002^134^ | [underlined: Cases]: 655 [underlined: Controls]: 3899 | 15 to 19 yr | 0.66 | 0.43 to 0.99 | Age, parity, BMI, age of menopause | | 1
Riman, 2002^134^ | [underlined: Cases]: 655 [underlined: Controls]: 3899 | 20 to 24 yr | 0.71 | 0.51 to 0.99 | Age, parity, BMI, age of menopause | | 1
Riman, 2002^134^ | [underlined: Cases]: 655 [underlined: Controls]: 3899 | 25+ yr | 0.9 | 0.27 to 1.22 | Age, parity, BMI, age of menopause | | 1
Riman, 2001^133^ | [underlined: Cases]: 193 [underlined: Controls]: 3899 | <15 yr | 1.16 | 0.45 to 3.02 | Age, parity, BMI, age of menopause, ever use of unopposed estrogen, estrogens with cyclic progestins, estrogens with continuous progestins | Borderline ovarian cancer | 1
Riman, 2001^133^ | [underlined: Cases]: 193 [underlined: Controls]: 3899 | 15 to 19 yr | 1.67 | 0.74 to 3.80 | Age, parity, BMI, age of menopause, ever use of unopposed estrogen, estrogens with cyclic progestins, estrogens with continuous progestins | Borderline ovarian cancer | 1
Riman, 2001^133^ | [underlined: Cases]: 193 [underlined: Controls]: 3899 | 20 to 24 yr | 0.92 | 0.43 to 1.94 | Age, parity, BMI, age of menopause, ever use of unopposed estrogen, estrogens with cyclic progestins, estrogens with continuous progestins | Borderline ovarian cancer | 1
Riman, 2001^133^ | [underlined: Cases]: 193 [underlined: Controls]: 3899 | 25+ yr | 1.14 | 0.62 to 2.10 | Age, parity, BMI, age of menopause, ever use of unopposed estrogen, estrogens with cyclic progestins, estrogens with continuous progestins | Borderline ovarian cancer | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | ≤5 yr | 0.19 | 0.12 to 0.30 | Formulation potency and duration of use, age, race, menopausal status, family history, education, tubal ligation, gravidity, age at last pregnancy, type of menopause, age at menopause, use of menopausal hormones | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 6 to 9 yr | 0.33 | 0.16 to 0.67 | | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 10 to 19 yr | 0.47 | 0.33 to 0.68 | | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 20 to 29 yr | 0.64 | 0.48 to 0.86 | | | 1
Lurie, 2008^114^ | [underlined: Cases]: 813 [underlined: Controls]: 993 | 30+yr | 0.72 | 0.49 to 1.06 | | | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | <5 yr | 0.3 | 0.2 to 0.6 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women only | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | 5+ to <10 yr | 0.4 | 0.2 to 0.9 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women only | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | 10 to 20 yr | 0.6 | 0.3 to 1.0 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women only | 1
Moorman, 2008^121^ | [underlined: Cases]: 314 [underlined: Controls]: 360 | >20 yr | 0.8 | 0.5 to 1.4 | Age, race, parity, BMI, family history, tubal ligation, infertility, age at last pregnancy | Premenopausal women only | 1
Cohort
Hankinson, 1995^98^ | [underlined: Exposed]: 592,056 person-years [underlined: Unexposed]: 599,301 person-years | Current | 1.86 | 0.67 to 5.19 | Age, parity, BTL, age at menarche, age at menopause, smoking, Quetelet's index | | 5
Hankinson, 1995^98^ | [underlined: Exposed]: 592,056 person-years [underlined: Unexposed]: 599,301 person-years | <5 yr | 0.86 | 0.48 to 1.56 | Age, parity, BTL, age at menarche, age at menopause, smoking, Quetelet's index | | 5
Hankinson, 1995^98^ | [underlined: Exposed]: 592,056 person-years [underlined: Unexposed]: 599,301 person-years | 5 to <10 yr | 0.77 | 0.48 to 1.26 | Age, parity, BTL, age at menarche, age at menopause, smoking, Quetelet's index | | 5
Hankinson, 1995^98^ | [underlined: Exposed]: 592,056 person-years [underlined: Unexposed]: 599,301 person-years | 10 to <15 yr | 1.01 | 0.66 to 1.54 | Age, parity, BTL, age at menarche, age at menopause, smoking, Quetelet's index | | 5
Hankinson, 1995^98^ | [underlined: Exposed]: 592,056 person-years [underlined: Unexposed]: 599,301 person-years | 15+ yr | 1.11 | 0.68 to 1.81 | Age, parity, BTL, age at menarche, age at menopause, smoking, Quetelet's index | | 5
Vessey, 1995^157^ | [underlined: Exposed]: 3520 [underlined: Unexposed]: 5881 | ≤48 mo | 0.1 | 0 to 0.5 | Age, parity | | 4
Vessey, 1995^157^ | [underlined: Exposed]: 3520 [underlined: Unexposed]: 5881 | 49 to 96 mo | 0.3 | 0 to 1.1 | Age, parity | | 4
Vessey, 1995^157^ | [underlined: Exposed]: 3520 [underlined: Unexposed]: 5881 | 97+ mo | 0.8 | 0.4 to 1.7 | Age, parity | | 4
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 [underlined: Unexposed]: 28,019 | 0 to 9 yr | 0.5 | 0.3 to .08 | Age, parity, use of HRT, menopause, country | Invasive ovarian cancer | 1
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 [underlined: Unexposed]: 28,019 | 10 to 14 yr | 0.5 | 0.2 to 0.9 | Age, parity, use of HRT, menopause, country | Invasive ovarian cancer | 1
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 [underlined: Unexposed]: 28,019 | 15 to 19 yr | 0.6 | 0.3 to 1.0 | Age, parity, use of HRT, menopause, country | Invasive ovarian cancer | 1
Kumle, 2004^110^ | [underlined: Exposed]: 75,533 [underlined: Unexposed]: 28,019 | 20+ | 0.6 | 0.3 to 1.0 | Age, parity, use of HRT, menopause, country | Invasive ovarian cancer | 1
Kumle, 2004^110^
Kumle, 2004^110^ | | 0 to 9 yr | 0.5 | 0.3 to 0.7 | | All ovarian cancers | 1
Kumle, 2004^110^ | | 10 to 14 yr | 0.7 | 0.4 to 1.1 | | All ovarian cancers | 1
Kumle, 2004^110^ | | 15 to 19 yr | 0.6 | 0.45 to 0.9 | | All ovarian cancers | 1
Kumle, 2004^110^ | | 20+ | 0.5 | 0.3 to 0.9 | | All ovarian cancers | 1
Kumle, 2004^110^
Kumle, 2004^110^ | | 0 to 9 yr | 0.4 | 0.2 to 0.9 | | Borderline ovarian cancer | 1
Kumle, 2004^110^ | | 10 to 14 yr | 1.1 | 0.6 to 2.1 | | Borderline ovarian cancer | 1
Kumle, 2004^110^ | | 15 to 19 yr | 0.6 | 0.3 to 1.3 | | Borderline ovarian cancer | 1
Kumle, 2004^110^ | | 20+ | 0.4 | 0.2 to 1.0 | | Borderline ovarian cancer | 1
Hannaford, 2007^37^ | [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years | Current and <60 mo | 0.5 | 0.24 to 1.01 | Age, parity, smoking, social class, HRT use | Main dataset | 1
Hannaford, 2007^37^ | [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years | 61 to 120 mo | 0.42 | 0.18 to 0.97 | Age, parity, smoking, social class, HRT use | Main dataset | 1
Hannaford, 2007^37^ | [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years | 121 to 180 mo | 0.28 | 0.11 to 0.71 | Age, parity, smoking, social class, HRT use | Main dataset | 1
Hannaford, 2007^37^ | [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years | 181 to 240 mo | 0.79 | 0.38 to 1.67 | Age, parity, smoking, social class, HRT use | Main dataset | 1
Hannaford, 2007^37^ | [underlined: Exposed]: 744,000 person-years [underlined: Unexposed]: 339,000 person-years | 241+ mo | 0.61 | 0.24 to 1.52 | Age, parity, smoking, social class, HRT use | Main dataset | 1
Tworoger, 2007^154^ | [underlined: Exposed]: 41,125 women years [underlined: Unexposed]: 54,027 women years | Current to <5 yr | 1.05 | 0.60 to 1.83 | Age, BMI, parity, BTL, smoking, age at menarche, age at menopause, duration of HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed]: 41,125 women years [underlined: Unexposed]: 54,027 women years | >5 yr to 10 yr | 0.53 | 0.30 to 0.94 | Age, BMI, parity, BTL, smoking, age at menarche, age at menopause, duration of HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed]: 41,125 women years [underlined: Unexposed]: 54,027 women years | >10 to 15 yr | 0.9 | 0.61 to 1.33 | Age, BMI, parity, BTL, smoking, age at menarche, age at menopause, duration of HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed]: 41,125 women years [underlined: Unexposed]: 54,027 women years | >15 to 20 yr | 0.88 | 0.61 to 1.27 | Age, BMI, parity, BTL, smoking, age at menarche, age at menopause, duration of HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed]: 41,125 women years [underlined: Unexposed]: 54,027 women years | >20 to 25 yr | 1.15 | 0.81 to 1.63 | Age, BMI, parity, BTL, smoking, age at menarche, age at menopause, duration of HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed]: 41,125 women years [underlined: Unexposed]: 54,027 women years | >25 to 30 yr | 1.24 | 0.86 to 1.80 | Age, BMI, parity, BTL, smoking, age at menarche, age at menopause, duration of HRT use | | 1
Tworoger, 2007^154^ | [underlined: Exposed]: 41,125 women years [underlined: Unexposed]: 54,027 women years | >30 yr | 1.13 | 0.71 to 1.80 | Age, BMI, parity, BTL, smoking, age at menarche, age at menopause, duration of HRT use | | 1
Dorjgochoo 2009^88^ | [underlined: Exposed]: 12,957 [underlined: Unexposed]: 15,557 | Last used <19 yr ago | 0.99 | 0.48 to 2.01 | Age, parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | | 2
Dorjgochoo 2009^88^ | [underlined: Exposed]: 12,957 [underlined: Unexposed]: 15,557 | Last used 19+ yr ago | 1.21 | 0.64 to 2.29 | Age, parity, menopausal status, BMI, family history, age at menarche, smoking, breastfeeding , education, physical activity, other contraceptive methods | | 2

BMI = body mass index; BRCA = breast cancer genetic mutation; BSO = bilateral salpingo-oophorectomy; BTL = bilateral tubal ligation; CI = confidence interval; HRT = hormone replacement therapy; IUD = intrauterine device; mo = month/months; NR=not reported; OC = oral contraceptive; OR = odds ratio; yr=year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Unless otherwise presented, never use is the reference category with an OR=1.0.

c Meta-analysis code: 1=Included in this meta-analysis; 2=Excluded due to study used fewer than three comparisons; 3=Excluded due to categories presented are not amenable to combined analysis; 4=Excluded in main analyses of studies from 2000 forward, included in sensitivity analyses of studies from 1990 forward; 5=Excluded due to grouping with another included article from the same study also reporting duration data.

Table 11 lists the odds ratios for the meta-analysis of time since last OC use. The individual odds ratios show no evidence of a relationship as a function of time since last use. However, a test for differences between the four odds ratios gives a chi-square of 14.0 for 3 degrees of freedom, p=0.002.

Table 11 Estimated odds ratios by time since last OC use (ovarian cancer incidence)

Time Interval | Odds Ratio (95% Confidence Interval) | P-value
0–10 years | 0.41 (0.34 to 0.50) | <0.0001
10–20 years | 0.65 (0.56 to 0.74) | <0.0001
20–30 years | 0.92 (0.76 to 1.12) | 0.3692
>30 years | 0.79 (0.58 to 1.12) | 0.1036

We then ran an analysis using the midpoint of each interval as the estimate of the time for each subgroup. This resulted in the following model:

OR = Exp(-8729 + 0.0217 * years)

The slope was highly significant (p=0.0013). There is significant heterogeneity. The estimated value of σ is 0.25. The t-value is 4.81 for 8 degrees of freedom, p<0.0013. The value of σ is larger than many of the standard errors for the observed odds ratios.

###### Pooled Analyses

Among the three pooled analyses that reported time since last OC use, one study21 reported that the relative risk of developing ovarian cancer was lower with more recent OC use. Women who had used OCs less than 10 years previously had a 29-percent decline in the risk of ovarian cancer for every 5 years of OC use, while those who last used OCs 20 to 29 years previously had a 15-percent reduction in risk. A second study23 reported on the time since last OC use but found no clear trend in ovarian cancer risk, while a third study24 found that risk reduction associated with OC use persisted regardless of the time elapsed since last use.

###### Sensitivity Analyses

We repeated our analyses excluding the five studies without patients from the United States. The estimates for the remaining four studies, three case-control and one cohort, were 0.40 (95% CI, 0.26 to 0.62 for use within the last 10 years, 0.66 (CI, 0.45 to 0.98) for use 10 to 20 years ago, 0.95 (CI, 0.58 to 1.56) for use 20 to 30 years ago, and 0.83 (CI, 0.46 to 1.50) for use >30 years ago.

We also performed analyses for studies published from 1990 forward (12 studies, 8 case-control and 4 cohort). The estimates were 0.45 (95% CI, 0.37 to 0.56 for use within the last 10 years, 0.70 (CI, 0.57 to 0.86) for use 10 to 20 years ago, 0.85 (CI, 0.63 to 1.14) for use 20 to 30 years ago and 0.88 (CI, 0.61 to 1.27) for use >30 years ago.

#### OC Formulations

##### Estrogen

Six studies29,113,125,130,141,143 were included in this meta-analysis examining the effect of estrogen formulation on ovarian cancer incidence. All were case-control studies, and represented 2607 cases and 6400 controls. Five studies were rated good quality and one fair quality. We excluded one cohort study from the analysis110 that did not contain dose information (Table 12).

Table 12 Data for outcomes on OC formulation (ovarian cancer incidence)

Study^a^ | Sample Size | Comparisons | OR^b^ | 95% CI^b^ | Covariates | Special Population (if Applicable) | Meta- Analysis Code^c^
Case-Control (continued)
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | High dose | 0.68 | 0.44 to 1.05 | Age, parity, center, year of diagnosis | | 4
Rosenblatt, 1992^140^ | [underlined: Cases]: 393 [underlined: Controls]: 2561 | Low dose | 0.81 | 0.051 to 1.29 | Age, parity, center, year of diagnosis | | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | Norethindrone | 0.5 | 0.3 to 0.9 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | Norethindrone acetate | 0.7 | 0.2 to 3.2 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | Norethynodrel | 0.9 | 0.2 to 3.2 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | Ethynodiol diacetate | 1.3 | 0.5 to 3.1 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | Norgestrel | 0.2 | 0.1 to 0.7 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | Any mestranol | 0.6 | 0.4 to 1.0 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | >50mcg mestranol | 0.9 | 0.5 to 1.8 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | 50mcg mestranol | 0.7 | 0.2 to 2.0 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | Any ethinyl estradiol | 0.5 | 0.2 to 1.0 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Rosenberg, 1994^137^ | [underlined: Cases]: 441 [underlined: Controls]: 2065 | ≥50mcg ethinyl estradiol | 0.4 | 0.1 to 1.0 | Age, race, parity, family history, hysterectomy, removal of one ovary, geographic area, interview year | Formulation data refer only to use for >3 yr | 4
Beard, 2000^83^ | [underlined: Cases]: 103 [underlined: Controls]: 103 | Any oral OC (as reported above) | 1.1 | 0.6 to 2.3 | Crude | | 3
Beard, 2000^83^ | [underlined: Cases]: 103 [underlined: Controls]: 103 | Substantial OC | 0.8 | 0.4 to 1.7 | Crude | | 3
Beard, 2000^83^ | [underlined: Cases]: 103 [underlined: Controls]: 103 | Any steroidal estrogen | 0.9 | 0.5 to 1.7 | Crude | | 3
Beard, 2000^83^ | [underlined: Cases]: 103 [underlined: Controls]: 103 | Substantial steroidal estrogen | 1.0 | 0.4 to 2.3 | Crude | | 3
Beard, 2000^83^ | [underlined: Cases]: 103 [underlined: Controls]: 103 | Any nonsteroidal estrogen | 0.5 | 0.2 to 0.9 | Crude | | 3
Beard, 2000^83^ | [underlined: Cases]: 103 [underlined: Controls]: 103 | Any progesterone | 1.2 | 0.5 to 2.8 | Crude | | 3
Beard, 2000^83^ | [underlined: Cases]: 103 [underlined: Controls]: 103 | Substantial progesterone | 4.0 | 0.4 to 36 | Crude | | 3
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | High estrogen/high progestin | 0.5 | 0.3 to 0.7 | Age, race, family history, number of pregnancies | | 1, 2
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | High estrogen/low progestin | 0.7 | 0.3 to 1.8 | Age, race, family history, number of pregnancies | | 1, 2
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | Low estrogen/high progestin | 0.6 | 0.3 to 1.3 | Age, race, family history, number of pregnancies | | 1, 2
Ness, 2000^125^ | [underlined: Cases]: 767 [underlined: Controls]: 1367 | Low estrogen/low progestin | 0.5 | 0.3 to 0.6 | Age, race, family history, number of pregnancies | | 1, 2
Ness, 2000^125^
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | High estrogen/high progestin | 1.0 | Reference | Age, race, family history, number of pregnancies | Invasive ovarian cancer N=616 | 1, 2
Ness, 2000^125^ | [underlined: Cases]: 616 [underlined: Controls]: 1367 | Low estrogen/low progestin | 1.2 | 0.8 to 1.9 | Age, race, family history, number of pregnancies | Invasive ovarian cancer N=616 | 1, 2
Ness, 2000^125^
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | High estrogen/high progestin | 1.0 | Reference | Age, race, family history, number of pregnancies | Borderline ovarian cancer N=151 | 1, 2
Ness, 2000^125^ | [underlined: Cases]: 151 [underlined: Controls]: 1367 | Low estrogen/low progestin | 0.7 | 0.3 to 1.3 | Age, race, family history, number of pregnancies | Borderline ovarian cancer N=151 | 1, 2
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | Low dose estrogen | 0.6 | 0.3 to 1.1 | Age, parity | | 1
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | Low and high dose estrogen | 0.6 | 0.3 to 1.3 | Age, parity | | 1
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | High dose estrogen | 0.8 | 0.5 to 1.2 | Age, parity | | 1
Sanderson, 2000^143^ | [underlined: Cases]: 276 [underlined: Controls]: 388 | Unknown | 0.9 | 0.6 to 1.5 | Age, parity | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | Low dose ≤35mcg ethinyl estradiol | 0.20 | 0.08 to 0.47 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | High dose >35mcg ethinyl estradiol | 0.65 | 0.40 to 1.05 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | Different formulations | 0.46 | 0.30 to 0.71 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | Avg daily ethinyl estradiol 20 to 34mcg | 0.14 | 0.06 to 0.36 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | Avg daily ethinyl estradiol 35 to 44 mcg | 0.33 | 0.15 to 0.72 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | Avg daily ethinyl estradiol 45 mcg or more | 0.57 | 0.36 to 0.90 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Royar, 2001^141^ | [underlined: Cases]: 282 [underlined: Controls]: 533 | No ethinyl estradiol or unknown ethinyl estradiol | 0.55 | 0.34 to 0.89 | Parity, family history, breastfeeding, tubal ligation, hysterectomy | | 1
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | High estrogen | 1.0 | Reference | | | 1, 2
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | Low estrogen | .07 | 0.4 to 1.2 | | | 1, 2
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | Nonuser | 2.0 | 1.5 to 2.7 | | | 1, 2
Schildkraut, 2002^29^
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | High progesterone | 1.0 | Reference | Age, parity, duration in months of use, latency, estrogen level | | 1, 2
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | Low progesterone | 2.2 | 1.3 to 3.9 | Age, parity, duration in months of use, latency, estrogen level | | 1, 2
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | Nonuser | 3.0 | 1.9 to 4.7 | Age, parity, duration in months of use, latency, estrogen level | | 1, 2
Schildkraut, 2002^29^
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | High/high | 1.0 | Reference | Age, parity, latency, duration of use in months | | 1, 2
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | High/low | 0.0 | 0.0 to not estimable | Age, parity, latency, duration of use in months | | 1, 2
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | Low/high | 2.1 | 1.2 to 3.7 | Age, parity, latency, duration of use in months | | 1, 2
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | Low/low | 1.6 | 0.9 to 3.0 | Age, parity, latency, duration of use in months | | 1, 2
Schildkraut, 2002^29^ | [underlined: Cases]: 390 [underlined: Controls]: 2865 | Nonusers | 2.9 | 1.8 to 4.5 | Age, parity, latency, duration of use in months | | 1, 2
Pike, 2004^130^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | High estrogen + high progestin | 0.88 | 0.81 to 0.97 | Age, race, parity, menopausal status, BMI, family history, SES, education, age at last birth, gravidity, OC use | | 1, 2
Pike, 2004^130^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | High estrogen + low progestin | 0.94 | 0.88 to 1.0 | Age, race, parity, menopausal status, BMI, family history, SES, education, age at last birth, gravidity, OC use | | 1, 2
Pike, 2004^130^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | Low estrogen + high progestin | 0.66 | 0.36 to 1.21 | Age, race, parity, menopausal status, BMI, family history, SES, education, age at last birth, gravidity, OC use | | 1, 2
Pike, 2004^130^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | Low estrogen + low progestin | 0.95 | 0.92 to 0.99 | Age, race, parity, menopausal status, BMI, family history, SES, education, age at last birth, gravidity, OC use | | 1, 2
Pike, 2004^130^ | [underlined: Cases]: 147 [underlined: Controls]: 304 | Unknown | 0.96 | 0.90 to 1.02 | Age, race, parity, menopausal status, BMI, family history, SES, education, age at last birth, gravidity, OC use | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Any estrogen and high progestin | 0.54 | 0.38 to 0.75 | Age, race, menopausal status, family history, center, education, gravidity, age at last pregnancy, tubal ligation, type of menopause, age at menopause, use of menopausal hormones, duration of OC use, time since first OC use | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Any estrogen and low progestin | 0.41 | 0.18 to 0.94 | | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Various potency | 0.22 | 0.12 to 0.41 | | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Never use | 1.00 | Reference | | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | High estrogen and any progestin | 0.61 | 0.42 to 0.89 | | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Low estrogen and any progestin | 0.33 | 0.21 to 0.52 | | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Various potency | 0.45 | 0.24 to 0.85 | | | 1, 2
Lurie, 2007^113^
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | High estrogen and high progestin | 0.62 | 0.43 to 0.92 | Age, race, menopausal status, center, education, gravidity, age at last pregnancy, tubal ligation, type of menopause, use of menopausal hormones, duration of OC use, time since first OC use | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | High estrogen and low progestin | 0.55 | 0.19 to 1.59 | Age, race, menopausal status, center, education, gravidity, age at last pregnancy, tubal ligation, type of menopause, use of menopausal hormones, duration of OC use, time since first OC use | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Low estrogen and high progestin | 0.45 | 0.28 to 0.72 | Age, race, menopausal status, center, education, gravidity, age at last pregnancy, tubal ligation, type of menopause, use of menopausal hormones, duration of OC use, time since first OC use | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Low estrogen and low progestin | 0.19 | 0.05 to 0.75 | Age, race, menopausal status, center, education, gravidity, age at last pregnancy, tubal ligation, type of menopause, use of menopausal hormones, duration of OC use, time since first OC use | | 1, 2
Lurie, 2007^113^ | [underlined: Cases]: 745 [underlined: Controls]: 943 | Various potencies | 0.26 | 0.15 to 0.44 | Age, race, menopausal status, center, education, gravidity, age at last pregnancy, tubal ligation, type of menopause, use of menopausal hormones, duration of OC use, time since first OC use | | 1, 2
Cohort
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed]: 28,019 | Progestin only | 0.3 | 0.1 to 1.1 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer | 3
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed]: 28,019 | Combination OCs | 0.5 | 0.3 to 0.8 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer | 3
Kumle, 2004^110^ | [underlined: Exposed:] 75,533 [underlined: Unexposed]: 28,019 | Progestin only and combination OCs | 0.7 | 0.4 to 1.0 | Age, parity, menopausal status, HRT, country | Invasive ovarian cancer | 3
Kumle, 2004^110^
Kumle, 2004^110^ | | Progestin only | 0.5 | 0.2 to 1.2 | Age, parity, menopausal status, HRT, country | All | 3
Kumle, 2004^110^ | | Combination OCs | 0.5 | 0.4 to 0.7 | Age, parity, menopausal status, HRT, country | All | 3
Kumle, 2004^110^ | | Progestin only and combination OCs | 0.7 | 0.5 to 1.0 | Age, parity, menopausal status, HRT, country | All | 3
Kumle, 2004^110^
Kumle, 2004^110^ | | Progestin only | 1.0 | 0.4 to 2.9 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer | 3
Kumle, 2004^110^ | | Combination OCs | 0.6 | 0.3 to 1.0 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer | 3
Kumle, 2004^110^ | | Progestin only and combination OCs | 0.9 | 0.5 to 1.5 | Age, parity, menopausal status, HRT, country | Borderline ovarian cancer | 3

Avg = average; BMI = body mass index; BRCA = breast cancer genetic mutation; BSO = bilateral salpingo-oophorectomy; BTL = bilateral tubal ligation; CI = confidence interval; EE = ethinyl estradiol; HRT = hormone replacement therapy; IUD = intrauterine device; NR=not reported; OC = oral contraceptive; OR = odds ratio; yr=year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Unless otherwise presented, never use is the reference category with an OR=1.0.

c Meta-analysis code: 1=Included in estrogen formulation meta-analysis; 2=Included in progestin formulation meta-analysis; 3=Excluded due to study contained no dose information; 4=Excluded in main analyses of studies from 2000 forward, included in sensitivity analyses of studies from 1990 forward.

The definition of a low-estrogen OC formulation varied among the six studies included in the meta-analysis, with three studies using a cutoff of 35 mcg estradiol,29,113,130 two studies using a cutoff of 50 mcg estradiol,125,143 and one study141 reporting results for three separate doses of estradiol (20–34 mcg, 35–44 mcg, and ≥45 mcg).

Five studies113,125,130,141,143 calculated odds ratios separately for high-dose or low-dose estrogen-containing OCs compared with never use. Of these, two studies125,130 presented estrogen dose results stratified by low or high progestin dose.

Figures 13 to 15 show the odds ratios for the meta-analyses on estrogen formulation. Compared with never use, the odds ratio for high-dose estrogen-containing OCs was 0.69 (95% CI, 0.53 to 0.91) (Figure 13). There was significant heterogeneity, with a Q-value of 16.44 for 4 degrees of freedom, p=0.002. Compared with never use, the odds ratio for low-dose estrogen-containing OCs was 0.50 (CI, 0.30 to 0.85) (Figure 14). There was significant heterogeneity, with a Q-value of 51.243 for 3 degrees of freedom, p≤0.001. One additional study calculated a direct odds ratio comparing high-dose to low-dose estrogen OC use.29 When this was combined with the other five included studies, the odds ratio was 1.25 (CI, 0.95 to 1.64) (Figure 15). These results do not suggest a relationship between estrogen dose and ovarian cancer incidence. There was some evidence of heterogeneity, with a Q-value of 10.611 for 5 degrees of freedom, p=0.06.

Figure 13 Forest plot for high-dose estrogen (ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figures 13 show the odds ratios for the meta-analyses on estrogen formulation. Compared with never use, the odds ratio for high-dose estrogen-containing OCs was 0.69 (95% CI, 0.53 to 0.91)

Figure 14 Forest plot for low-dose estrogen (ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 14 shows the odds ratios for the meta-analyses on low-dose estrogen formulation. Compared with never use, the odds ratio for low-dose estrogen-containing OCs was 0.50 (95% CI, 0.30 to 0.85)

Figure 15 Forest plot for high-dose versus low-dose estrogen (ovarian cancer incidence)

CI = confidence interval

Description: Figure 15 shows the odds ratios for the meta-analyses on high-dose versus low-dose estrogen formulation. The odds ratio was 1.25 (95% CI, 0.95 to 1.64).

###### Sensitivity Analyses

Analyses were repeated excluding one case-control study that was not performed within the United States. After this exclusion, a meta-analysis of the remaining five case-control studies revealed an odds ratio for high-dose estrogen-containing OC use of 0.69 (95% CI, 0.53 to 0.91), and for low-dose estrogen-containing OC use, an odds ratio of 0.60 (CI, 0.37 to 0.98). The odds ratio comparing high-dose with low-dose estrogen-containing OCs was 1.04 (CI, 0.90 to 1.21).

We also conducted analyses of studies published from 1990 forward (eight case-control studies). The odds ratio for high-dose estrogen-containing OC use was 0.68 (95% CI, 0.53 to 0.87), and for low-dose estrogen-containing OC use, an odds ratio of 0.55 (CI, 0.37 to 0.83). The odds ratio comparing high-dose to low-dose estrogen-containing OCs was 1.19 (CI, 0.93 to 1.51).

##### Progestin

Four studies29,113,125,130 were included in this meta-analysis examining the effect of progestin formulation on ovarian cancer incidence (Table 12). Of these, all four were case-control studies representing 2049 cases and 5479 controls. All four studies were rated good quality. We excluded data from this analysis from reports that did not use progesterone-dosing terminology that facilitated a combined analysis.

The four included studies classified progesterone potency based on a subnuclear vacuolation assay and a delay of menses test. These methods have previously been described by Dickey and Stone,163 who classified low-dose progestin OCs as those containing a relative potency cutoff of 0.2 mg norgestrel or less. Three studies stratified progestin results based on low or high estrogen dose.113,125,130

Figures 16 to 18 show the odds ratios for the meta-analyses on progestin formulation. The odds ratio was 0.65 (95% CI, 0.44 to 0.95) for the three case-control studies of ovarian cancer incidence as a function of high-dose progestin (Figure 16). There was significant heterogeneity, with a Q-value of 14.97 for 2 degrees of freedom, p=0.001. The odds ratio was 0.62 (CI, 0.36 to 1.08) for the case-control studies of ovarian cancer incidence as a function of low-dose progestin (Figure 17). There was significant heterogeneity, with a Q-value of 17.80 for 2 degrees of freedom, p<0.001. One additional study calculated a direct odds ratio comparing high-dose with low-dose progestin OC use29 (Figure 18). The random-effects meta-analysis of all four case-control studies reveals an odds ratio of 0.86 (CI, 0.60 to 1.21) for ovarian cancer incidence as a function of the ratio of high-dose progestin to low-dose. These results do not support a relationship between OC progestin dose and ovarian cancer incidence. There was some evidence of heterogeneity, with a Q-value of 7.52 for 3 degrees of freedom, p=0.057.

Figure 16 Forest plot for high-dose progestin (ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figures 16 show the odds ratios for the meta-analyses on progestin formulation. The odds ratio was 0.65 (95% CI, 0.44 to 0.95) for the three case-control studies of ovarian cancer incidence as a function of high-dose progestin.

Figure 17 Forest plot for low-dose progestin (ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 17 shows the odds ratios for the meta-analyses on low-dose progestin formulation. The odds ratio was 0.62 (95% CI, 0.36 to 1.08) for the case-control studies of ovarian cancer incidence as a function of low-dose progestin

Figure 18 Forest plot for high- versus low-dose progestin (ovarian cancer incidence)

CI = confidence interval

Description: Figure 18 shows the odds ratios for the meta-analyses on high- versus low-dose progestin formulation. The random-effects meta-analysis of all four case-control studies reveals an odds ratio of 0.86 (95% CI, 0.60 to 1.21) for ovarian cancer incidence as a function of the ratio of high-dose progestin to low-dose.

###### Sensitivity Analyses

There were no poor-quality studies performed outside of the United States or studies published before 2000 addressing progestin dose. Therefore, sensitivity analyses were not performed.

#### Special Populations

##### BRCA Mutation Carriers

Four studies81,94,116,159 were included in the meta-analyses examining the relationship between carriers of BRCA1 and BRCA2 genetic mutations and ovarian cancer incidence. Of these, three were case-control studies representing 1096 cases and 2878 controls and 1 cohort study representing 3181 participants. One study was rated good quality and three fair quality (Table 5).

Data were available to compare affected and unaffected BRCA1 mutation carriers; affected and unaffected BRCA2 mutation carriers; and a combined group of affected and unaffected BRCA1 or BRCA2 carriers. We excluded studies115,118 from the analyses that compared mutation carriers with ovarian cancer to control groups who were predominantly noncarriers or who were not tested for BRCA1 or BRCA2.

Figures 19 to 21 show the odds ratios for the meta-analyses on BRCA1 mutation carriers. The odds ratio was 0.55 (95% CI, 0.47 to 0.66) for the four studies of ovarian cancer incidence in patients with the BRCA1 gene as a function of OC use (Figure 19). There was no significant heterogeneity, with a Q-value of 1.24 for 3 degrees of freedom, p=0.743. The odds ratio was 0.65 (CI, 0.34 to 1.24) for the three studies of ovarian cancer incidence in patients with the BRCA2 gene as a function of OC use (Figure 20). There was no significant heterogeneity, with a Q-value of 4.68 for 2 degrees of freedom, p=0.096. The odds ratio was 0.58 (CI, 0.46 to 0.73) for the three studies of ovarian cancer incidence that combined women with either the BRCA1 gene or BRCA2 gene (Figure 21). There was no significant heterogeneity, with a Q-value of 3.12 for 2 degrees of freedom, p=0.210. These analyses suggest that OCs reduce ovarian cancer incidence in all three gene categories. The odds ratios for the three groups were quite similar, and a test for a difference results in a p-value of 0.975.

Figure 19 Forest plot for BRCA1 carriers (ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 19 shows the odds ratios for the meta-analyses on BRCA1 carriers. The odds ratio was 0.55 (95% CI, 0.47 to 0.66) for the four studies of ovarian cancer incidence in patients with the BRCA1 gene as a function of OC use.

Figure 20 Forest plot for BRCA2 carriers (ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 20 shows the odds ratios for the meta-analyses on BRCA2 carriers. The odds ratio was 0.65 (95% CI, 0.34 to 1.24) for the three studies of ovarian cancer incidence in patients with the BRCA2 gene as a function of OC use.

Figure 21 Forest plot for BRCA1 or BRCA2 carriers (ovarian cancer incidence)

CI = confidence interval; OC = oral contraceptive

Description: Figure 21 show the odds ratios for the meta-analyses on BRCA1 or BRCA2 carriers. The odds ratio was 0.58 (95% CI, 0.46 to 0.73) for the three studies of ovarian cancer incidence that combined women with either the BRCA1 gene or BRCA2 gene.

###### Sensitivity Analyses

Analyses were repeated for the combined group of BRCA1 or BRCA2 mutation carriers including one additional study published in 1998. The odds ratio was 0.56 (CI, 0.45 to 0.69).

Sensitivity analyses were not done for study quality because no studies were rated as poor quality, and none were done comparing U.S. with non-U.S. studies because excluding non-U.S. studies left only two studies.

##### Family History of Ovarian Cancer

Three studies87,149,158 were identified that examined the effect of family history on ovarian cancer incidence. All three were case-control studies: one was rated good quality and two fair quality. We excluded one pooled analysis23 because it included some of the individual studies that were identified (Table 13).

Table 13 Data for outcomes on family history (ovarian cancer incidence)

Study^a^ | Sample Size | Comparisons | OR^b^ | 95% CI^b^ | Covariates | Special Population (if Applicable) | Meta- Analysis Code^c^
Case-Control
Gross, 1992^95^ | With family history [underlined: Cases]: 31 [underlined: Controls]: 99 | Never use | 1.0 | | Age, parity | Family history of ovarian cancer in mother, grandmother, sister, daughter or aunt | 2
Gross, 1992^95^ | With family history [underlined: Cases]: 31 [underlined: Controls]: 99 | 3 to 11 mo | 3.1 | | Age, parity | Family history of ovarian cancer in mother, grandmother, sister, daughter or aunt | 2
Gross, 1992^95^ | With family history [underlined: Cases]: 31 [underlined: Controls]: 99 | 12 to 24 mo | 1.7 | | Age, parity | Family history of ovarian cancer in mother, grandmother, sister, daughter or aunt | 2
Gross, 1992^95^ | With family history [underlined: Cases]: 31 [underlined: Controls]: 99 | 25 to 36 mo | 1.5 | | Age, parity | Family history of ovarian cancer in mother, grandmother, sister, daughter or aunt | 2
Gross, 1992^95^ | With family history [underlined: Cases]: 31 [underlined: Controls]: 99 | 37 to 60 mo | 1.1 | | Age, parity | Family history of ovarian cancer in mother, grandmother, sister, daughter or aunt | 2
Gross, 1992^95^ | With family history [underlined: Cases]: 31 [underlined: Controls]: 99 | ≥61 mo | 0.3 | | Age, parity | Family history of ovarian cancer in mother, grandmother, sister, daughter or aunt | 2
Gross, 1992^95^
Gross, 1992^95^ | No family history [underlined: Cases]: 225 [underlined: Controls]: 2351 | Never use | 1.0 | | Age, parity | No family history | 2
Gross, 1992^95^ | No family history [underlined: Cases]: 225 [underlined: Controls]: 2351 | 3 to 11 mo | 0.6 | | Age, parity | No family history | 2
Gross, 1992^95^ | No family history [underlined: Cases]: 225 [underlined: Controls]: 2351 | 12 to 24 mo | 0.6 | | Age, parity | No family history | 2
Gross, 1992^95^ | No family history [underlined: Cases]: 225 [underlined: Controls]: 2351 | 25 to 36 mo | 0.7 | | Age, parity | No family history | 2
Gross, 1992^95^ | No family history [underlined: Cases]: 225 [underlined: Controls]: 2351 | 37 to 60 mo | 0.7 | | Age, parity | No family history | 2
Gross, 1992^95^ | No family history [underlined: Cases]: 225 [underlined: Controls]: 2351 | ≥61 mo | 0.3 | | Age, parity | No family history | 2
Godard, 1998^89^ | Familial Cases [underlined: Cases]: 51 [underlined: Controls]: 152 | Age at last OC use | | | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | Family history of ≥1 person with breast cancer diagnosed <55 years or ovarian cancer | 2
Godard, 1998^89^ | Familial Cases [underlined: Cases]: 51 [underlined: Controls]: 152 | Never use | 1.0 | Reference | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | Family history of ≥1 person with breast cancer diagnosed <55 years or ovarian cancer | 2
Godard, 1998^89^ | Familial Cases [underlined: Cases]: 51 [underlined: Controls]: 152 | 17 to 25 yr | 0.99 | 0.28 to 3.51 | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | Family history of ≥1 person with breast cancer diagnosed <55 years or ovarian cancer | 2
Godard, 1998^89^ | Familial Cases [underlined: Cases]: 51 [underlined: Controls]: 152 | 25 to 35 yr | 0.26 | 0.08 to 0.79 | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | Family history of ≥1 person with breast cancer diagnosed <55 years or ovarian cancer | 2
Godard, 1998^89^ | Familial Cases [underlined: Cases]: 51 [underlined: Controls]: 152 | 35 to 43 yr | 0.17 | 0.036 to 0.83 | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | Family history of ≥1 person with breast cancer diagnosed <55 years or ovarian cancer | 2
Godard, 1998^89^
Godard, 1998^89^ | Sporadic Cases [underlined: Cases]: 101 [underlined: Controls]: 152 | Age at last OC use | | | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | No family history | 2
Godard, 1998^89^ | Sporadic Cases [underlined: Cases]: 101 [underlined: Controls]: 152 | Never use | 1.0 | Reference | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | No family history | 2
Godard, 1998^89^ | Sporadic Cases [underlined: Cases]: 101 [underlined: Controls]: 152 | 17 to 25 yr | 0.84 | 0.28 to 2.55 | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | No family history | 2
Godard, 1998^89^ | Sporadic Cases [underlined: Cases]: 101 [underlined: Controls]: 152 | 25 to 35 yr | 0.25 | 0.10 to 0.62 | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | No family history | 2
Godard, 1998^89^ | Sporadic Cases [underlined: Cases]: 101 [underlined: Controls]: 152 | 35 to 43 yr | 0.25 | 0.10 to 0.64 | Age at menarche, age at diagnosis, age at last childbirth, tubal ligation or hysterectomy, talc use, alcohol use | No family history | 2
Tavani, 2000^149^ | With family history [underlined: Cases]: 93 [underlined: Controls]: 139 | Ever use | 1 | Reference | Age, area of residence | Family history of breast and/or ovarian cancer in first-degree relatives | 2
Tavani, 2000^149^ | With family history [underlined: Cases]: 93 [underlined: Controls]: 139 | Never use | 1.4 | 0.4 to 4.4 | Age, area of residence | Family history of breast and/or ovarian cancer in first-degree relatives | 2
Tavani, 2000^149^
Tavani, 2000^149^ | No family history [underlined: Cases]: 878 [underlined: Controls]: 2619 | Ever use | 1 | Reference | Age, area of residence | No family history | 2
Tavani, 2000^149^ | No family history [underlined: Cases]: 878 [underlined: Controls]: 2619 | Never use | 1.2 | 0.9 to 1.7 | Age, area of residence | No family history | 2
Chiaffarino, 2001^87^ | With family history [underlined: Cases]: 129 [underlined: Controls]: 120 | Never used or <60 mo | 1 | Reference | Age, parity, family history, center, education | Family history of breast and/or ovarian cancer in first degree relatives | 2
Chiaffarino, 2001^87^ | With family history [underlined: Cases]: 129 [underlined: Controls]: 120 | ≥60 mo | 1.0 | 0.2 to 4.2 | Age, parity, family history, center, education | Family history of breast and/or ovarian cancer in first degree relatives | 2
Chiaffarino, 2001^87^
Chiaffarino, 2001^87^ | No family history [underlined: Cases]: 901 [underlined: Controls]: 2286 | Never used or <60 mo | 1 | Reference | Age, parity, family history, center, education | No family history | 2
Chiaffarino, 2001^87^ | No family history [underlined: Cases]: 901 [underlined: Controls]: 2286 | ≥60 mo | 0.5 | 0.2 to 0.9 | Age, parity, family history, center, education | No family history | 2
Walker, 2002^158^ | With family history [underlined: Cases]: 33 [underlined: Controls]: 24 | ≤48 mo use | 0.34 | 0.08 to 1.55 | Age, race, parity, tubal ligation | Family history of ovarian cancer in first-degree relative | 2
Walker, 2002^158^ | With family history [underlined: Cases]: 33 [underlined: Controls]: 24 | 49+ mo use | 0.07 | 0.01 to 0.44 | Age, race, parity, tubal ligation | Family history of ovarian cancer in first-degree relative | 2
Walker, 2002^158^ | With family history [underlined: Cases]: 33 [underlined: Controls]: 24 | Never use | 1 | Reference | Age, race, parity, tubal ligation | Family history of ovarian cancer in first-degree relative | 2
Walker, 2002^158^
Walker, 2002^158^ | No family history [underlined: Cases]: 692 [underlined: Controls]: 1279 | ≤48 mo | 0.72 | 0.59 to 0.88 | Age, race, parity, tubal ligation | No family history | 2
Walker, 2002^158^ | No family history [underlined: Cases]: 692 [underlined: Controls]: 1279 | 49+ mo | 0.51 | 0.40 to 0.65 | Age, race, parity, tubal ligation | No family history | 2
Walker, 2002^158^ | No family history [underlined: Cases]: 692 [underlined: Controls]: 1279 | Never OC use | 1 | Reference | Age, race, parity, tubal ligation | No family history | 2

BMI = body mass index; BRCA = breast cancer genetic mutation; BSO = bilateral salpingo-oophorectomy; BTL = bilateral tubal ligation; CI = confidence interval; HRT = hormone replacement therapy; IUD = intrauterine device; mo = month/months; NR = not reported; OC = oral contraceptive; OR = odds ratio; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Unless otherwise presented, never use is the reference category with an OR = 1.0.

c Meta-analysis code: 2 = Meta-analysis was not performed due to differences in definitions of positive family history and nonusers of OCs.

Among these studies, two different definitions of a positive family history were used: (1) breast or ovarian cancer in a first-degree relative,87,149 and (2) history of ovarian cancer in a sister or mother.158 The studies also used two different categorizations of the referent group for OC use: (1) no OC use149,158 or (2) use for less than 60 months.87 The lack of consistency across studies precluded performing a meaningful meta-analysis by family history subgroups.

##### Parity and Gravidity

Two studies123,126 were identified that examined the effect of gravidity on ovarian cancer incidence (Table 14). Both were case-control studies; in total they represented 1595 cases and 3137 controls. Both studies were rated good quality. When determining possible meta-analysis, we excluded one set of data from consideration92 due to representation of that data in another included report and therefore did not have sufficient studies to warrant a formal meta-analysis.

Table 14 Data for outcomes on parity/gravidity (ovarian cancer incidence)

Study^a^ | Sample Size | Comparisons | OR^b^ | 95% CI^b^ | Covariates | Special Population (if Applicable) | Meta- Analysis Code^c^
Case-Control
Parazzini, 1991^128^ | Parity=0 [underlined: Cases]: 137 [underlined: Controls]: 273 | Never | 1.0 | Reference | Age | Nulliparous women | 4
Parazzini, 1991^128^ | Parity=0 [underlined: Cases]: 137 [underlined: Controls]: 273 | Ever | 0.6 | 0.3 to 1.3 | Age | Nulliparous women | 4
Parazzini, 1991^128^
Parazzini, 1991^128^ | Parity=1-2 [underlined: Cases]: 266 [underlined: Controls]: 795 | Never | 1.0 | Reference | Age | Women with parity 1-2 | 4
Parazzini, 1991^128^ | Parity=1-2 [underlined: Cases]: 266 [underlined: Controls]: 795 | Ever | 0.5 | 0.3 to 0.9 | Age | Women with parity 1-2 | 4
Parazzini, 1991^128^
Parazzini, 1991^128^ | Parity≥3 [underlined: Cases]: 102 [underlined: Controls]: 307 | Never | 1.0 | Reference | Age | Women with parity ≥3 | 4
Parazzini, 1991^128^ | Parity≥3 [underlined: Cases]: 102 [underlined: Controls]: 307 | Ever | 0.8 | 0.3 to 1.7 | Age | Women with parity ≥3 | 4
Thomas, 1991^150^ | Parity=0 Not reported | Never | 1.0 | Reference | | Nulliparous women | 4
Thomas, 1991^150^ | Parity=0 Not reported | Ever | 0.16 | 0.05 to 0.54 | | Nulliparous women | 4
Thomas, 1991^150^
Thomas, 1991^150^ | Parity ≥1 Not reported | Never | 1.0 | Reference | | Women with parity ≥1 | 4
Thomas, 1991^150^ | Parity ≥1 Not reported | Ever | 0.85 | 0.63 to 1.16 | | Women with parity ≥1 | 4
Ness, 2001^126^ | Gravidity=0 [underlined: Cases]: 137 [underlined: Controls]: 119 | Never | 1.0 | Reference | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=0 [underlined: Cases]: 137 [underlined: Controls]: 119 | OCs for contraception | 0.9 | 0.5 to 1.7 | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=0 [underlined: Cases]: 137 [underlined: Controls]: 119 | OCs for noncontraception | 1.3 | 0.6 to 3.2 | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=0 [underlined: Cases]: 137 [underlined: Controls]: 119 | OCs for both | 0.9 | 0.4 to 1.8 | Age, race, family history | | 1
Ness, 2001^126^
Ness, 2001^126^ | Gravidity=1 [underlined: Cases]: 107 [underlined: Controls]: 140 | Never | 1.0 | Reference | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=1 [underlined: Cases]: 107 [underlined: Controls]: 140 | OCs for contraception | 0.6 | 0.3 to 1.1 | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=1 [underlined: Cases]: 107 [underlined: Controls]: 140 | OCs for noncontraception | 0.5 | 0.2 to 1.7 | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=1 [underlined: Cases]: 107 [underlined: Controls]: 140 | OCs for both | 0.9 | 0.4 to 2.1 | Age, race, family history | | 1
Ness, 2001^126^
Ness, 2001^126^ | Gravidity=2 [underlined: Cases]: 177 [underlined: Controls]: 346 | Never | 1.0 | Reference | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=2 [underlined: Cases]: 177 [underlined: Controls]: 346 | OCs for contraception | 0.6 | 0.4 to 1.0 | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=2 [underlined: Cases]: 177 [underlined: Controls]: 346 | OCs for noncontraception | 0.7 | 0.3 to 1.6 | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity=2 [underlined: Cases]: 177 [underlined: Controls]: 346 | OCs for both | 1.0 | 0.5 to 2.0 | Age, race, family history | | 1
Ness, 2001^126^
Ness, 2001^126^ | Gravidity≥3 [underlined: Cases]: 306 [underlined: Controls]: 754 | Never | 1.0 | Reference | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity≥3 [underlined: Cases]: 306 [underlined: Controls]: 754 | OCs for contraception | 0.7 | 0.5 to 1.0 | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity≥3 [underlined: Cases]: 306 [underlined: Controls]: 754 | OCs for noncontraception | 0.9 | 0.5 to 1.6 | Age, race, family history | | 1
Ness, 2001^126^ | Gravidity≥3 [underlined: Cases]: 306 [underlined: Controls]: 754 | OCs for both | 0.5 | 0.3 to 0.9 | Age, race, family history | | 1
Greer, 2005^92^ | Parous women [underlined: Cases]: 715 [underlined: Controls]: 1631 | Never | 1.00 | Reference | Age | | 2
Greer, 2005^92^ | Parous women [underlined: Cases]: 715 [underlined: Controls]: 1631 | Single episode; 1 to 6 mo | 0.71 | 0.50 to 0.99 | Age | | 2
Greer, 2005^92^ | Parous women [underlined: Cases]: 715 [underlined: Controls]: 1631 | Single episode; 7 to 12 mo | 1.04 | 0.66 to 1.63 | Age | | 2
Greer, 2005^92^ | Parous women [underlined: Cases]: 715 [underlined: Controls]: 1631 | Single episode; ≥13 mo | 0.66 | 0.48 to 0.90 | Age | | 2
Greer, 2005^92^ | Parous women [underlined: Cases]: 715 [underlined: Controls]: 1631 | ≥1 episode; 1 to 6 mo | 0.71 | 0.51 to 0.99 | Age | | 2
Greer, 2005^92^ | Parous women [underlined: Cases]: 715 [underlined: Controls]: 1631 | ≥1 episode; 7 to 12 mo | 0.97 | 0.64 to 1.47 | Age | | 2
Greer, 2005^92^ | Parous women [underlined: Cases]: 715 [underlined: Controls]: 1631 | ≥1 episode; ≥13 mo | 0.62 | 0.48 to 0.81 | Age | | 2
Greer, 2005^92^
Greer, 2005^92^ | Nulliparous women [underlined: Cases]: 216 [underlined: Controls]: 168 | Never user | 1.00 | Reference | Age | | 2
Greer, 2005^92^ | Nulliparous women [underlined: Cases]: 216 [underlined: Controls]: 168 | Single episode; 1 to 6 mo | 1.04 | 0.52 to 2.08 | Age | | 2
Greer, 2005^92^ | Nulliparous women [underlined: Cases]: 216 [underlined: Controls]: 168 | Single episode; 7 to 12 mo | 1.08 | 0.42 to 2.78 | Age | | 2
Greer, 2005^92^ | Nulliparous women [underlined: Cases]: 216 [underlined: Controls]: 168 | Single episode; ≥13 mo | 0.84 | 0.46 to 1.56 | Age | | 2
Greer, 2005^92^ | Nulliparous women [underlined: Cases]: 216 [underlined: Controls]: 168 | ≥1 episode; 1 to 6 mo | 1.05 | 0.55 to 2.01 | Age | | 2
Greer, 2005^92^ | Nulliparous women [underlined: Cases]: 216 [underlined: Controls]: 168 | ≥1 episode; 7 to 12 mo | 1.08 | 0.49 to 2.34 | Age | | 2
Greer, 2005^92^ | Nulliparous women [underlined: Cases]: 216 [underlined: Controls]: 168 | ≥1 episode; ≥13 mo | 0.68 | 0.42 to 1.11 | Age | | 2
Ness, 2011^123^ | Gravidity=0 [underlined: Cases]: 134 [underlined: Controls]: 143 | Never | 1.00 | Reference | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=0 [underlined: Cases]: 134 [underlined: Controls]: 143 | OCs for contraception | 0.46 | 0.25 to 0.86 | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=0 [underlined: Cases]: 134 [underlined: Controls]: 143 | OCs for noncontraception | 0.61 | 0.25 to 1.52 | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=0 [underlined: Cases]: 134 [underlined: Controls]: 143 | OCs for both | 0.31 | 0.15 to 0.67 | Age, race, family history, infertility | | 1
Ness, 2011^123^
Ness, 2011^123^ | Gravidity=1 [underlined: Cases]: 114 [underlined: Controls]: 188 | Never | 1.00 | Reference | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=1 [underlined: Cases]: 114 [underlined: Controls]: 188 | OCs for contraception | 0.99 | 0.58 to 2.02 | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=1 [underlined: Cases]: 114 [underlined: Controls]: 188 | OCs for noncontraception | 0.60 | 0.44 to 2.23 | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=1 [underlined: Cases]: 114 [underlined: Controls]: 188 | OCs for both | 0.99 | 0.22 to 1.69 | Age, race, family history, infertility | | 1
Ness, 2011^123^
Ness, 2011^123^ | Gravidity=2 [underlined: Cases]: 216 [underlined: Controls]: 458 | Never | 1.00 | Reference | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=2 [underlined: Cases]: 216 [underlined: Controls]: 458 | OCs for contraception | 0.51 | 0.34 to 0.77 | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=2 [underlined: Cases]: 216 [underlined: Controls]: 458 | OCs for noncontraception | 0.89 | 0.40 to 1.99 | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity=2 [underlined: Cases]: 216 [underlined: Controls]: 458 | OCs for both | 0.50 | 0.28 to 0.88 | Age, race, family history, infertility | | 1
Ness, 2011^123^
Ness, 2011^123^ | Gravidity≥3 [underlined: Cases]: 404 [underlined: Controls]: 989 | Never | 1.00 | Reference | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity≥3 [underlined: Cases]: 404 [underlined: Controls]: 989 | OCs for contraception | 0.85 | 0.64 to 1.14 | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity≥3 [underlined: Cases]: 404 [underlined: Controls]: 989 | OCs for noncontraception | 0.77 | 0.45 to 1.32 | Age, race, family history, infertility | | 1
Ness, 2011^123^ | Gravidity≥3 [underlined: Cases]: 404 [underlined: Controls]: 989 | OCs for both | 0.70 | 0.45 to 1.09 | Age, race, family history, infertility | | 1
Pooled
Hartge, 1994^104^ | Parity>=3 [underlined: Cases]: 333 [underlined: Controls]: 2466 | No OC | 1.0 | Reference | Tubal ligation, hysterectomy | | 3
Hartge, 1994^104^ | Parity>=3 [underlined: Cases]: 333 [underlined: Controls]: 2466 | OCs for 1-3 yr | 1.8 | 1.2 to 2.7 | Tubal ligation, hysterectomy | | 3
Hartge, 1994^104^ | Parity>=3 [underlined: Cases]: 333 [underlined: Controls]: 2466 | OCs for ≥4 yr | 2.2 | 1.6 to 3.2 | Tubal ligation, hysterectomy | | 3
Hartge, 1994^104^
Hartge, 1994^104^ | Parity=1-2 [underlined: Cases]: 448 [underlined: Controls]:2029 | No OC | 1.5 | 0.95 to 2.3 | | | 3
Hartge, 1994^104^ | Parity=1-2 [underlined: Cases]: 448 [underlined: Controls]:2029 | OCs for 1-3 yr | 2.6 | 1.7 to 3.9 | | | 3
Hartge, 1994^104^ | Parity=1-2 [underlined: Cases]: 448 [underlined: Controls]:2029 | OCs for ≥4 yr | 3.7 | 2.6 to 5.4 | | | 3
Hartge, 1994^104^
Hartge, 1994^104^ | Parity=0 [underlined: Cases]:295 [underlined: Control]: 816 | No OC | 2.2 | 1.3 to 3.9 | | | 3
Hartge, 1994^104^ | Parity=0 [underlined: Cases]:295 [underlined: Control]: 816 | OCs for 1-3 yr | 5.8 | 3.6 to 9.3 | | | 3
Hartge, 1994^104^ | Parity=0 [underlined: Cases]:295 [underlined: Control]: 816 | OCs for ≥4 yr | 5.5 | 3.7 to 8.0 | | | 3

BMI = body mass index; BRCA = breast cancer genetic mutation; BSO = bilateral salpingo-oophorectomy; BTL = bilateral tubal ligation; CI = confidence interval; mo = month/months; OC = oral contraceptive; OR = odds ratio; NR = not reported; yr = year/years

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Unless otherwise presented, never use is the reference category with an OR=1.0.

c Meta-analysis code: 1 = Study meets inclusion criteria for meta-analysis; 2 = Excluded from possible meta-analysis due to grouping with another included article also reporting results by gravidity; 3 = Excluded pooled analysis due to no other studies to combine it with; 4 = Excluded from possible meta-analysis in main analyses of studies from 2000 forward, included in sensitivity analyses of studies from 1990 forward.

Among nulliparous women, one study reported a significantly reduced risk of ovarian cancer among OC users (OR 0.43; 95% CI, 0.28 to 0.66),123 and the other found no difference (OR 0.98; CI, 0.65 to 1.49).126 Both studies reported a significantly reduced risk of ovarian cancer among parous women who were OC users (OR 0.72; CI, 0.61 to 0.85^123^ and OR 0.68; CI, 0.56 to 0.83).126 The odds ratios comparing gravidity 0 to gravidity 1+ were 0.60 (CI, 0.38 to 0.94)123 and 1.44 (CI, 0.91 to 2.27).126

###### Sensitivity Analyses

No sensitivity analyses were performed because there were too few studies.

### OC Use and Ovarian Cancer Mortality

Three studies33,164-167 were identified that examined the effect of OC use on ovarian cancer mortality. All three were cohort studies and were rated fair quality. Two of the included studies33,165 were large, population-based cohort studies representing 46,112 subjects and 602,700 reported person-years and assessed death from ovarian cancer as a primary outcome among ever versus never OC users. Both of these studies reported a significant reduction in ovarian cancer mortality among OC users that was similar in magnitude and direction as the reduction in incidence discussed above. The third study167 identified a cohort of women with ovarian cancer and subsequently compared survival outcomes between OC users (n=310) and nonusers (n=366), with nonsignificant findings (Table 15).

Table 15 Data for ovarian cancer mortality

Study^a^ | Study Details | OR | 95% CI | | Covariates | Region | Study Quality | Meta-Analysis Code^b^
Cohort
Survival After Diagnosis of Ovarian Cancer
Nagle, 2008^167^ | Cohort of women with ovarian cancer in three Australian states [underlined: Exposed:] 310 women [underlined: Unexposed:] 366 women | 0.88 | | 0.70 to 1.11 | Stage, age group, histologic grade, residual disease, smoking | Australia/NZ | Fair | 2
Population-Level Mortality
Hannaford, 2010^33^ | Royal College General Practitioners Oral Contraceptive Study [underlined: Exposed]: 28,806 women [underlined: Unexposed]: 17,306 women | 0.53 | | 0.38 to 0.72 | Age, parity, smoking and social class | UK | Fair | 2
Vessey, 2010^165^ | Oxford Family Planning Association contraception study 602,700 person-years of observation for unexposed and exposed | 0.87 | | 0.79 to 0.96 | Age, parity, social class, smoking, BMI | UK | Fair | 2

CI = confidence interval; NZ = New Zealand; OC = oral contraceptive; OR = odds ratio; UK = United Kingdom

a Study identifies the primary abstracted article. For details about the relationships between companion studies and articles, refer to Tables C-1 and C-2 in Appendix C.

b Meta-analysis code: 2 = Excluded from the meta-analysis due to differences in study populations.

### Strength of Evidence for OC Use and Risk of Ovarian Cancer

The strength of evidence for each outcome is described in Table 16 using the four domains listed as guidance. Because no randomized controlled trials were included in our analysis, the risk of bias was categorized as medium at best and high if other possible sources of bias were identified. With regard to directness of evidence, relationships between high and low steroid hormone doses and ovarian cancer incidence were considered to be indirect based on the use of “never OC use” as the reference category in those studies.

Table 16 Strength of evidence domains for the effect of OC use on ovarian cancer

Comparison | Number of Studies (Women and/or Person-years) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Comparison | Number of Studies (Women and/or Person-years) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Incidence of Ovarian Cancer in Overall Population
Ever vs. never use | 24 (657,055 and 3,981,072 person-years) | Medium | Consistent | Direct | Precise | Moderate 0.73 (0.66 to 0.81)
Duration of use | 15 (574,363 and 3,493,072 person-years) | Medium | Consistent | Direct | Precise | Moderate 1–12 mo: 0.91 (0.78 to 1.07) 13–60 mo: 0.77 (0.66 to 0.89) 61–120 mo: 0.65 (0.55 to 0.77) >120 mo: 0.43 (0.37 to 0.51)
Age at first use | 6 (111,817) | High | Consistent | Direct | Imprecise | Low <20 yr: 0.63 (0.45 to 0.89) 20–24 yr: 0.71 (0.51 to 0.99) 25–30 yr: 0.67 (0.46 to 0.99) > 30 yr: 0.89 (0.60 to 1.32)
Time since last use | 8 (210,069 and 1,083,000 person-years) | High | Inconsistent | Direct | Imprecise | Low 0–10 yr: 0.41 (0.34 to 0.50) 10–20 yr: 0.65 (0.56 to 0.74) 20–30 yr: 0.92 (0.76 to 1.12) >30 yr: 0.79 (0.58 to 1.12)
High-dose vs. low-dose estrogen | 6 (9007) | High | Consistent | Indirect | Imprecise | Low 1.25 (0.95 to 1.64)
High-dose vs. low-dose progestin | 4 (7528) | High | Inconsistent | Indirect | Imprecise | Low 0.86 (0.60 to 1.21)
Incidence in BRCA1- or BRCA2-Positive Women
Ever vs. never use | 3 (6855) | Medium | Consistent | Direct | Precise | Moderate 0.58 (0.46 to 0.73)
Incidence in BRCA1-Positive Women
Ever vs. never use | 4 (5519) | Medium | Consistent | Direct | Precise | Moderate 0.55 (0.47 to 0.66)
Incidence in BRCA2-Positive Women
Ever vs. never use | 3 (1592) | Medium | Inconsistent | Direct | Imprecise | Low 0.65 (0.34 to 1.24)
Incidence in Women With Family History
Ever vs. never use | 3 (9193) | High | Inconsistent | Direct | Imprecise | Low Decreased incidence
Incidence in Gravid/Parous and Nulligravid/Nulliparous Women
Ever vs. never use | 2 (4732) | Medium | Inconsistent | Direct | Imprecise | Insufficient
Mortality From Ovarian Cancer
Ever vs. never use | 2 (46,112 and 602,700 person-years) | Medium | Consistent | Direct | Imprecise | Moderate Decreased cause-specific mortality
Survival Among Women With Ovarian Cancer
Ever vs. never use | 1 (676) | High | NA | Direct | Imprecise | Insufficient (not performed)

CI = confidence interval; mo = month/months; NA = not applicable; SOE = strength of evidence; yr = year/years

We graded as moderate the strength of evidence for relationships between ever OC use and ovarian cancer incidence and mortality in the general population and between ever OC use and ovarian cancer incidence in the BRCA mutation-carrying population. The relationship between duration of OC use and ovarian cancer incidence was also graded as moderate. The strength of evidence for the remaining relationships was graded as low.

## Discussion

In the systematic review and meta-analysis for Section 2, OC use was associated with a decreased incidence of ovarian cancer (OR 0.73, 95% CI, 0.66-0.81), with results from two large cohort studies showing a concomitant decrease in mortality. There is a positive relationship between the duration of OC use and the degree of the protective effect. These findings are consistent with prior pooled analyses,21,23,24 which reported odds ratios for ever versus never OC use of between 0.60 and 0.73 and similarly identified a relationship between longer duration of OC use and lower incidence of ovarian cancer. We did not identify a significant relationship between time since last OC use and degree of protection—although such a relationship has been identified in the largest prior pooled analysis.21 Note that we found no evidence for publication bias in any of the meta-analyses (Appendix E).

### Temporal Relationships in OC Use

The results of our meta-analysis show a strong relationship between duration of OC use and the incidence of ovarian cancer (Figure 12). Women who use OCs for 10 or more years show a reduction in ovarian cancer incidence of more than 50 percent. Prior pooled analyses are consistent with these findings.21,23,24 While our reported odds ratio comparing OC use for less than 12 months with never use does not meet criteria for statistical significance, our duration analysis suggests that there is no time threshold for OC effectiveness, and the duration-response relationship likely starts as soon as a woman commences OC use.

Regarding age at first OC use, the odds ratios also appear to show a clearly positive relationship. This suggests that the earlier a woman begins using OCs, the greater the reduction in ovarian cancer incidence. However, it is not possible to differentiate the effects of age at first use from the effects of duration of use. Our findings are consistent with the largest pooled analysis,21 and are not unexpected, since the earlier a woman starts using OCs, the longer the potential duration of use. The number of studies (6) in our primary analysis of age at first OC use was much lower than the number of studies (15) in the analysis of duration, and so it is not possible to determine which factor is more predictive. The protective effect of OCs appears to attenuate with increasing time since last use, again consistent with the findings of the Collaborative Group,21 although it remains significantly reduced even up to 30 years after stopping. Although the data available at the study level preclude estimation of the joint effect of duration and time since last use, stratified analysis of the pooled individual data by the Collaborative Group suggest that the magnitude of protection with increased duration is greater than the attenuation with time since last use.

### Women at Elevated Genetic Risk for Ovarian Cancer

The results of our meta-analysis suggest that ever use of OCs reduces the risk of ovarian cancer in BRCA1 or BRCA2 mutation carriers similar to what has been observed consistently in the general population. The odds ratio for ever use of OCs (OR 0.58; 95% CI, 0.46 to 0.73) for BRCA1 or BRCA2 mutation carriers was lower than the odds ratio calculated from the overall meta-analysis (OR 0.73, 95% CI, 0.66 to 0.81).

Although the breast cancer literature clearly demonstrates that clinical and pathologic characteristics of BRCA1-associated cancers differ from BRCA2-associated cancers and sporadic cancers, the same does not appear to be true for ovarian cancer.168 Our analyses of the effects of OCs in BRCA1 and BRCA2 mutation carriers found similar odds ratios for ovarian cancer in each group, and a test for differences between groups was not statistically significant (p=0.916). Although the analyses did not suggest there were statistically significant differences between BRCA1 and BRCA2 mutation carriers, these results should be interpreted cautiously because of the small number of studies and the relatively small sample sizes for BRCA2 mutation carriers.

For women that do not have a known BRCA1 or BRCA2 mutation but are at increased risk for ovarian cancer due to a family history of breast or ovarian cancer, the data were inadequate to perform a meta-analysis because of differences between studies in their definitions of family history and the reference group to which OC users were compared. Within individual studies, particularly those focusing specifically on a family history of ovarian cancer, the relatively small numbers within the strata defined by a positive family history led to unstable estimates. The possible use of OCs as an ovarian cancer prevention strategy is clearly of interest to women with a family history of ovarian or breast cancer; however, the published data do not provide consistent evidence to support a recommendation for use.

### Limitations

In an effort to enhance the applicability of these findings to contemporary OC formulations and dosages, we included only studies published on or after January 1, 2000, for the primary analysis and 1990 for the sensitivity analysis. However, our meta-analysis produced a very similar odds ratio comparing ever use with never use (0.73) to odds ratios reported in the sensitivity analysis (0.72) and a pooled analyses that included older studies. This suggests that current OC formulations may have a similar effectiveness to older formulations in reducing the incidence of ovarian cancer. This is supported by our finding that the relative estrogen and progestin doses in OCs do not appear to have an impact on ovarian cancer incidence. However, given that the age of peak incidence of ovarian cancer is in a woman's early 60s, even more recent publications do not capture the potential long-term effect of formulations introduced in the past 20 years.

Another limitation of the current analysis is the degree of generalizability of the included studies to clinical decisionmaking. The included studies almost never specifically reported the reasons for OC use. It is likely that most women who have taken OCs have done so for contraception or to control symptoms related to menses. Therefore, the use of OCs specifically to prevent ovarian cancer has not been addressed in reported studies, and use of the currently available data to guide a risk/benefit discussion regarding chemoprophylaxis is premature.

The main limitation of our analysis is the lack of any randomized, prospective trials examining the preventive effect of OCs on ovarian cancer, raising the potential for bias. The most common study design within our primary ever/never incidence analyses was case-control (71%), with a minority being cohort studies (29%); given that ovarian cancer is relatively uncommon, this is not unexpected. The point estimate for case-control studies (0.72) was lower than for cohort studies (0.75), suggesting that there may be some residual confounding in the case-control studies. Likewise, although the vast majority of studies were rated as good or fair quality (92%), there was marked inconsistency across studies, particularly in the methods for adjustment of confounding. Individual odds ratios or relative risks were always adjusted for potential confounders, but both the choice of covariates and the way the covariates were modeled in the reported results were not consistent among studies (Tables 5, 6, 8, 10, 12–15). For example, relevant ages and durations of exposure were described using a variety of categories with widely varying definitions.

The observed association between OC use and reduced ovarian cancer risk (and for many of the other associations discussed in Sections 3 and 4) fulfills many of the classic criteria for causal inference in epidemiology,169 including strength of association, consistency across studies, temporality, a biological gradient, biological plausibility, and coherence. However, the potential for the limitations discussed above to lead to biased estimates of the effects of OC require considerable caution when using the results for clinical decisionmaking. Although the literature synthesis for each outcome and the model (described in Section 5) represent our best efforts at integrating the available data quantitatively, the inherent limitations of observational studies mean that we cannot rule out the possibility that some or all of the observed associations between OC use and both harmful and beneficial outcomes are the result of unmeasured confounding.

### Future Research

The current literature consistently shows a statistically significant reduction in ovarian cancer risk among women with a history of OC uses, with greater reductions in risk with longer duration of use. Results were similar across different subgroups with varying degrees of risk, such as nulliparous women and BRCA1 and BRCA2 mutation carriers. While the overall body of evidence is supportive of the beneficial effects of OCs on ovarian cancer, the potential for unmeasured bias is substantial. Even if the magnitude of the observed protective association is accurate, our analysis demonstrates that there is insufficient evidence to guide more specific recommendations regarding the preferred OC formulation and dose, the optimal time period of use for ovarian cancer prevention, and the benefits in certain high-risk women. Ideally, many of these issues would be resolved by a randomized trial, but, as discussed in Section 5, the challenges to conducting such a trial may be insurmountable.

While the current analysis did not identify a relationship between estrogen or progestin formulation and incidence of ovarian cancer, there were a limited number of studies meeting criteria for these meta-analyses. In particular, the progestin component of the OC formulation appears to have an effect on the ovarian epithelium in animal studies.170 Given that only four studies defined progestin dose uniformly and were included in the meta-analysis, further investigation into the relationship between progestin dose/formulation and ovarian cancer incidence is warranted. This is particularly important given that both the estrogen and progestin components are likely related to the risk of some of the adverse outcomes associated with OC use—especially acute vascular events (see Section 4).

Our analyses were based on more recently published data than previous pooled analyses were, yet we arrived at a similar estimate of the odds ratio associated with ever OC use. This suggests that lower dose OCs—which are more commonly evaluated in recent studies—are potentially as effective as higher dose OCs in reducing ovarian cancer risk. Continued evaluation of effects by dose of OCs is warranted, especially since some of the older women included in studies published since 1990 would have taken OCs when higher doses were more commonly prescribed.

Further research is needed to sort out the relative importance of the duration and timing of use of OCs. Greater reductions in risk were observed for women who were younger at first use of OCs; however, data were not available to determine whether this was due to longer duration of use among women who initiated OC use at younger ages. Analogously, although ovarian cancer risk was lower among more recent OC users compared with those with a longer time since last use, these analyses did not account for duration of use. Understanding the combined effects of timing and duration is particularly important for making recommendations to women of mid-to-late reproductive age who are considering OC use for ovarian cancer prevention but not necessarily for contraception. To facilitate future systematic reviews, one step would be to standardize the categories and descriptive statistics for reporting results. Although particular categorization choices may be best suited for analyzing individual studies on the basis of study design and characteristics of a given population, reporting of standardized results—perhaps as an appendix to the main analysis—would greatly improve the ability to combine published results in meta-analysis.

Additional research is also needed to learn whether women at high risk for ovarian cancer due to their family history show a similar benefit with OC use as women from the general population. The proportion of women with a reported family history of ovarian cancer is quite small in most studies; however, this group may be keenly interested in chemoprevention given the high mortality of ovarian cancer. It would be highly desirable for pooled analyses to include a sufficient number of women with a positive family history to provide stable risk estimates.