# Introduction and Methods

This evidence report was funded by the Centers for Disease Control and Prevention (CDC) in conjunction with the Agency for Healthcare Research and Quality (AHRQ) and was designed to evaluate the benefits and harms of the use of oral contraceptives as a primary preventive measure against ovarian cancer.

## Background

### Ovarian Cancer Incidence and Mortality

Although ovarian cancer is only the eighth most common cancer in women (annual age-adjusted incidence 12.3 per 100,000), it is the fifth leading cause of women's cancer deaths (8.2 per 100,000).1 Given current age-specific incidence data and U.S. Census demographic projections, the estimated annual number of new ovarian cancer cases will almost double (to 40,000) over the next 35 years as women born between 1946 and 1964 (the “baby boom” generation) reach the ages of highest risk (Figure 1).2

Figure 1 Projected ovarian cancer incidence and mortality for 2010 to 2050

Description: Figure 1 shows an estimate that the annual number of new ovarian cancer cases will almost double (to 40,000) over the next 35 years as the women of the baby boom generation (born between 1946 and 1964) reach the ages of highest risk.

#### Trends

##### Age-Specific Incidence and Mortality

Age-specific ovarian cancer incidence and mortality follow a similar pattern that is consistent with the high case-to-fatality ratio of ovarian cancer (Figure 2).

Figure 2 Age-specific incidence and mortality for ovarian cancer^a^ a Surveillance, Epidemiology, and End Results (SEER), 2000–2008.

Description: Figure 2 shows age-specific ovarian cancer incidence and mortality follow a similar pattern consistent with the high case-to-fatality ratio of ovarian cancer.

After a slight decline from 1975 through 1985, age-adjusted ovarian cancer mortality was mostly stable until 2002, when mortality had dropped by an annual rate of 1.7 percent (Figure 3). At the same time, age-adjusted incidence was also declining.3 There are three potential explanations for this decreased mortality: improved survival after diagnosis because of improved treatments, improved survival through effective screening, or decreased incidence. Some of this decrease in mortality may be attributed to the cumulative effects of recent advancements in the treatment of ovarian cancer, which include recognition of the importance of aggressive primary cytoreductive surgery, introduction of platinum- and taxane-based chemotherapy, and introduction of the intraperitoneal route of chemotherapy administration.

Figure 3 Age-adjusted ovarian cancer incidence and mortality rates

Description: Figure 3 shows age-adjusted SEER ovarian cancer incidence and mortality rates form 1975-2008. After a slight decline from 1975 through 1985, age-adjusted ovarian cancer mortality was mostly stable until 2002, when mortality had dropped by an annual rate of 1.7 percent.

### Lack of Effectiveness of Screening

Despite the advances in primary treatment, the mortality rate for ovarian cancer remains the highest among the gynecologic malignancies. Because ovarian cancer typically presents at a much later stage (with concomitant higher mortality) than other common cancers,1 there has been intense interest in developing effective screening strategies.

Unfortunately, these efforts have had disappointing results to date, especially in the ability of screening to result in reduced mortality.4-10 Several factors limit the success of screening for ovarian cancer. First, the cause and pathogenesis of the disease remain unknown. While certain histologic subtypes have been associated with precursor lesions, there is still no preinvasive “Stage 0” lesion that is universal, definitive, and detectible. Second, there is no physical barrier to impede rapid spread of malignant cells from the surface of the ovary (FIGO Stage I) (or, as a growing body of evidence suggests, from the epithelium of the fallopian tube) to the upper abdomen (FIGO Stage III).11 The possibility of rapid spread from the ovary means that many of the cancers identified at Stage I may represent a subgroup of less aggressive tumors rather than a necessary first step in the development of all tumors. Recent pathogenetic studies support the heterogeneity of ovarian cancer, with some subtypes acting as more indolent lesions that are more likely to be detected in an early stage and to be more curable.12 If this is the case, screening, which is more likely to identify slower growing tumors, may have only a limited impact on overall ovarian cancer mortality.13 Recently, the Prostate, Lung, Colorectal, and Ovarian Phase III ovarian cancer screening trial reported no clinical benefit—and noted possible harm due to false-positive results—when postmenopausal women were screened annually for up to 6 years with CA-125 and pelvic ultrasound.10

A second large Phase III trial, the United Kingdom Collaborative Trial of Ovarian Cancer Screening (UKCTOCS),7 randomized women to usual care, ultrasound-based screening, or a multimodality screening algorithm consisting of a CA-125 followed by ultrasound for those with abnormal or rising CA-125 results. The UKCTOCS trial has released the results of prevalence screening, with an encouraging shift toward detection at earlier disease stages noted. However, the mortality outcomes of this trial are not yet known and, as such, the benefit of screening for ovarian cancer remains unproven.

### Primary Prevention

Given that the potential effectiveness of screening to reduce morbidity and mortality from ovarian cancer appears to be limited by the underlying biology of the disease, alternative strategies—including the use of more efficacious and less toxic therapies after diagnosis as well as primary prevention—need to be considered and evaluated.

#### Surgery

Surgical prophylaxis, in the form of bilateral salpingo-oophorectomy (BSO), is a primary preventive approach to ovarian cancer that has been widely used only for women at high genetic risk. In a BRCA1/2 mutation–carrying population, BSO has been demonstrated to reduce the risk of ovarian, tubal, or peritoneal cancers by 80 percent and the risk of breast cancers by 50 percent.14 The Gynecologic Oncology Group is currently completing a nonrandomized prospective trial comparing risk-reducing salpingo-oophorectomy to longitudinal screening with CA-125 and ultrasound. Several groups have performed health-economic models suggesting that prophylactic surgery is both effective and cost-effective in the BRCA carrier population.15,16 Given the potential harms of prophylactic surgery and premature loss of ovarian function, surgical prophylaxis in the absence of other indications for pelvic surgery has not been recommended in the general premenopausal population. There is also evidence from observational studies that two gynecological surgical procedures performed for other indications, tubal sterilization and hysterectomy,17-19 also reduce ovarian cancer risk, even without removal of the ovaries. In light of accumulating evidence that many, if not most, ovarian cancers originate in the fallopian tube, some groups, notably the British Columbia Cancer Association, are advocating removal of the tubes at the time of surgical sterilization or hysterectomy for other indications, but there is no evidence on potential effectiveness.20

#### Oral Contraceptives

Oral contraceptives (OCs) represent a potentially promising primary prevention strategy for ovarian cancer. Several studies suggest a protective effect of OCs on ovarian cancer risk, with a reduction in risk of up to 50 percent with long-term use.21,22

##### Age-Period Cohort

Data from the National Cancer Institute's Surveillance, Epidemiology, and End Results (SEER) registry suggest a reduction in both age-specific incidence and mortality in cohorts born in 1940 or later (i.e., those who had access to OCs during their entire reproductive life span). Figure 4 shows age-specific incidence, and Figure 5 shows age-specific mortality by age-period cohort, derived from SEER age-specific incidence and mortality data from 1974 to 2008. Lines refer to women born in the indicated year.

Figure 4 Age-specific incidence by age-period cohort

Description: Figure 4 shows age-specific ovarian cancer incidence, derived from SEER data from 1974 to 2008. Lines refer to women born in the indicated year and suggest a reduction in age-specific incidence in cohorts born in 1940 or later.

Figure 5 Age-specific mortality by age-period cohort

Description: Figure 5 shows age-specific ovarian cancer mortality, derived from SEER age-specific mortality data from 1974 to 2008. Lines refer to women born in the indicated year and suggest a reduction in age-specific mortality in cohorts born in 1940 or later.

#### Clinical Data

A large number of observational studies provide evidence that OC use has a protective effect on ovarian cancer incidence and mortality. The largest pooled analysis combined data from 45 epidemiological studies in 21 countries representing 23,257 women with ovarian cancer and 87,303 controls. This analysis described an odds ratio for ever OC use of 0.73 (95% CI, 0.70 to 0.76). There was a strong relationship between degree of risk and duration of OC use, with the overall risk decreased by 20 percent (95% CI, 18% to 23%) for every 5 years of OC use. Based on these findings the authors estimated that use of OCs has already prevented 200,000 ovarian cancers and 100,000 deaths from ovarian cancer.21 Two other pooled analyses of epithelial ovarian cancer had consistent findings, with odds ratios for ever OC use of 0.66 (95% CI, 0.56 to 0.79) and 0.6 (95% CI, 0.4 to 0.8).23,24

#### Modeling Results

There have been no prior modeling studies to inform the possible preventive effects of OCs on ovarian cancer incidence and mortality.

#### Biological Plausibility

The mechanisms underlying a potential protective effect of OCs on ovarian cancer risk are not entirely clear. One longstanding hypothesis (“the incessant ovulation theory”) is that repetitive ovulations throughout reproductive life result in epithelial damage and repair cycles that subsequently increase the risk of developing ovarian cancer. Factors that decrease the number of ovulations such as pregnancies, breastfeeding, and use of OCs, therefore, are expected to reduce ovarian cancer risk.25

A protective effect of OCs may also be due to direct effects of the hormones on the ovarian epithelium, a theory that is supported by some biological evidence. First, the incidence of ovarian cancer is significantly elevated in poultry hens, which ovulate daily.26 Second, in a 3-year study, macaque monkeys treated either with combination OCs or their individual estrogen or progestin components or with controls, a significant increase in apoptosis of the ovarian epithelium was demonstrated in the groups receiving progestins.27 The apoptosis pathway preferentially eliminates cells that have sustained genetic damage.28 The finding that progestins activate this critical pathway in the ovarian epithelium raises the possibility that progestin-mediated apoptotic effects, and not solely inhibition of ovulation, may be responsible for the reduction in ovarian cancer risk that is associated with OC use.29 Finally, Schildkraudt et al. reported an increase in the protective effect of OCs when a high potency progestin was used.29

Although there are some biologically plausible mechanisms for a protective effect of OCs on ovarian cancer risk, recent pathogenetic data now suggest that many high-grade serous epithelial ovarian cancers arise not from the ovarian epithelium but from the distal fallopian tube.30 Consistent with the epidemiologic data regarding OC use, prior work suggests that the fallopian tube epithelium is influenced by ovulatory cycles, with ovulation exerting an inhibitory effect.31

### Rationale for Review

Although the evidence suggests that most women can take OCs safely,32 the potential benefit of using OCs to reduce the risk of ovarian cancer must be weighed with knowledge of both the potential noncontraceptive health benefits of OCs33,34 and their potential harms.35-38 No comparative effectiveness analyses have been conducted to inform decisions about the use of OCs as a primary preventive strategy for ovarian cancer. Also, because the majority of evidence on noncontraceptive benefits and harms of OC use is derived from observational studies, careful consideration must be given to the potential biases inherent in those study designs when developing a research agenda and clinical recommendations. The combination of systematic review and decision-analytic modeling presented in this report allows us to estimate the tradeoffs between the harms and benefits of OC use for the overall population and for individual women, accounting for the potential influence of other factors.

## Scope and Key Questions

### Scope of Review

To evaluate the benefits and harms of the use of OCs as a primary preventive measure against ovarian cancer, we focused on synthesizing the available evidence for the effectiveness of this strategy in a general population and in groups at elevated risk. We also evaluated benefits and harms of OC use that are not related to the development of ovarian cancer. Finally, we designed a comparative effectiveness model to inform the questions generated by this review.

The scope of the review specifically excluded the unquestioned effectiveness of OCs in preventing unintended pregnancies; the potential effectiveness of OCs as primary or adjunctive treatments for conditions such as menstrual disorders (e.g., dysmenorrhea or menorrhagia), endometriosis, or premenstrual dysphoric disorder; and the potential role of OCs in preventing the onset of these conditions. For women considering the use of OCs for contraception or as treatment for symptomatic conditions, these effects are clearly the most important consideration. However, our overall focus was on the potential role of OCs as primary prevention for ovarian cancer. The overall clinical question we addressed was not, “What are the overall benefits and harms of OCs as a method of contraception or as treatment for certain conditions?”—a question that would require explicit comparisons of different contraceptive methods on all the relevant outcomes. Rather, the implicit question was, “Do the benefits and harms of OCs potentially justify their use solely as a primary preventive intervention (analogous to aspirin for the prevention of myocardial infarction) even in women who do not need contraception?”

### Key Questions

With input from AHRQ, the CDC, and a Technical Expert Panel (TEP) of external stakeholders, we defined Key Questions using the general approach of specifying the population of interest, the interventions, comparators, outcomes, timing of outcomes, and settings (PICOTS; see the section on “Inclusion and Exclusion Criteria” in the Methods section for details). The Key Questions (KQs) considered in this systematic review were:

KQ 1: What is the effectiveness of combined (estrogen and progestin containing) and progestin-only oral contraceptives (OCs) for reducing the risk of ovarian cancer?

KQ 2: Do specifics of OC use (e.g., dose/formulation, age at initiation, duration of use) affect the relative risk of developing ovarian cancer?

KQ 3: Does the use of OCs by specific populations of women (e.g., those defined by age, family history of breast and ovarian cancer, BRCA1/BRCA2 mutation status, parity) affect the relative risk of developing ovarian cancer?

KQ 4: Aside from pregnancy prevention, are there other benefits of OC use in reducing the risks of endometrial cancer or colorectal cancer?

KQ 5: What are the harms of OC use, including breast cancer incidence, cervical cancer incidence, venous thromboembolic disease, stroke, or myocardial infarction? How do these harms vary by dose or formulation, duration of use, or specific population?

KQ 6: Based on the comprehensive literature review, what are the benefits and harms from the use of OCs to reduce the incidence of ovarian cancer for specific populations? Based on the decision model, what is the estimated effect of these benefits and harms on life expectancy and quality-adjusted life expectancy?

KQ 7: Based on the systematic review and decision model, what research gaps need to be filled to better understand whether OCs are effective for the primary prevention of ovarian cancer?

#### Analytic Framework

Figure 6 shows the analytic framework for this systematic review.

Figure 6 Analytic framework for systematic review

BRCA = breast cancer (genetic mutation); K = Key Question; OC = oral contraceptive

Note: KQ 7 is not shown in the analytic framework.

Figure 6 depicts the key questions (KQs) within the context of the PICO (population, interventions, comparators, and outcomes) described elsewhere in this document. In general, the figure shows that KQs 1-3 and 6 focus on ovarian cancer outcomes, KQ 4 on benefits of OC use and KQ 5 on harms of OC use. KQ 7, research gaps, is not shown in the analytic framework.

## Organization of Report

This report departs from the standard AHRQ evidence report organization. The evidence is instead presented in four topic-focused sections. Figure 7 shows the relationship between the Key Questions and the report sections. Three of these sections address the relationship between OC use and specific groups of benefits and/or harms. The first such section, “Oral Contraceptives and Ovarian Cancer,” focuses on ovarian cancer outcomes (KQ 1, KQ 2, and KQ 3); the second section, “Oral Contraceptives and Other Cancers,” on breast, cervical, colorectal, and endometrial cancers (KQ 4 and KQ 5); and the third, “Oral Contraceptives and Vascular Events,” on venous thromboembolism, stroke, and myocardial infarction (KQ 5). Within each section, the benefits and/or harms of OC use are considered for both the general population and specific populations of women for whom the risk levels of ovarian cancer are elevated. Where possible, our analyses also consider potential modifying factors such as dose, formulation, and duration of OC use. Each section also considers specific evidence gaps and needs for future research regarding the association between OC use and the specific outcomes (KQ 7).

Figure 7 Report roadmap

KQ = Key Question; OC = oral contraceptive

* Note that Section 5 also summarizes the Key Questions.

Figure 7 illustrates the structure of this report, which departs from the standard AHRQ evidence report organization. The evidence is instead presented in four topic-focused sections that map to the Key Questions. The first section, “Oral Contraceptives and Ovarian Cancer,” focuses on ovarian cancer outcomes (KQ 1, KQ 2, and KQ 3); the second, “Oral Contraceptives and Other Cancers,” on breast, cervical, colorectal, and endometrial cancers (KQ 4 and KQ 5); and the third, “Oral Contraceptives and Vascular Events,” on venous thromboembolism, stroke, and myocardial infarction (KQ 5). Within each section, the benefits and/or harms of OC use are considered for both the general population and specific populations of women for whom the risk levels of ovarian cancer are elevated. Where possible, our analyses also consider potential modifying factors such as dose, formulation, and duration of OC use. Each section also considers specific evidence gaps and needs for future research regarding the association between OC use and the specific outcomes (KQ 7). The final section of the report, <Overall Benefits and Harms of Oral Contraceptives for Prevention of Ovarian Cancer,> uses a decision analytic framework to explore the overall benefits and harms of all outcomes considered in the report. In this section, we present the results of our comparative effectiveness decision model, considering the overall effect of OC use on benefits and harms for both the general population and specific populations of women at varying levels of risk (KQ 6). In this final section, we also use the modeling framework to identify additional evidence gaps and needs for future research related to the potential overall benefits and harms of OCs for prevention of ovarian cancer (KQ 7).

The final section of the report, “Overall Benefits and Harms of Oral Contraceptives for Prevention of Ovarian Cancer,” uses a decision analytic framework to explore the overall benefits and harms of all outcomes considered in the report. In this section, we present the results of our comparative effectiveness decision model, considering the overall effect of OC use on benefits and harms for both the general population and specific populations of women at varying levels of risk (KQ 6). In this final section, we also use the modeling framework to identify additional evidence gaps and needs for future research related to the potential overall benefits and harms of OCs for prevention of ovarian cancer (KQ 7).

The final section of the report, “Overall Benefits and Harms of Oral Contraceptives for Prevention of Ovarian Cancer,” uses a decision analytic framework to explore the overall benefits and harms of all outcomes considered in the report. In this section, we present the results of our comparative effectiveness decision model, considering the overall effect of OC use on benefits and harms for both the general population and specific populations of women at varying levels of risk (KQ 6). In this final section, we also use the modeling framework to identify additional evidence gaps and needs for future research related to the potential overall benefits and harms of OCs for prevention of ovarian cancer (KQ 7).

## Methods

The methods for this evidence report follow those suggested in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (www.effectivehealthcare.ahrq.gov/methodsguide.cfm; hereafter referred to as the “Methods Guide”).39 The main sections in this chapter reflect the elements of the protocol established for the systematic review; certain methods map to the PRISMA checklist.40 All methods and analyses were guided by a review protocol, which was developed as described below.

### Review Protocol

At the outset of this review, the Key Questions were defined collaboratively with input from AHRQ, the CDC, and the TEP. The TEP comprised individuals representing medical professional societies/clinicians in the areas of obstetrics, gynecology, reproductive health, and gynecologic oncology; Federal health agencies with an interest in cancer care/prevention, oral contraceptive benefits/harms, and women's health research; scientific and methodological experts; a nonprofit cancer advocacy organization; and representatives of ovarian cancer patient and women's reproductive health groups. The TEP was convened to provide input in defining populations, interventions, comparisons, and outcomes; considering potential analysis and modeling approaches; and aiding in identifying particular studies or databases to search. Members of the TEP were required to disclose any relevant business or professional conflicts of interest and any financial conflicts of interest greater than $10,000. Potential conflicts of interest were balanced or mitigated. Members of the TEP did not perform analyses of any kind and did not contribute to the writing of the report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol, which was then refined based on their input, reviewed by AHRQ and the CDC, and posted for public access at the AHRQ Effective Health Care Web site.41

### Literature Search Strategy

#### Search Strategy

We searched PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews to identify relevant literature published from January 1990 to June 2012. Our search strategies used the National Library of Medicine's medical subject headings (MeSH) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. We date-limited our searches to articles published since January 1990 because, given the lag time between OC exposure and subsequent ovarian cancer development, much of the older literature concerning OC use and ovarian cancer is based on OC formulations that are no longer on the market. In addition, many of the other benefits and harms of OC use are observed within several years of initial use. Restricting the search to 1990 forward increases the likelihood that the types of OCs used by the women in the studies we retrieved were similar to those currently available, and thus aids in maximizing the generalizability and clinical relevance of the results. In addition to the databases listed above, we also searched ClinicalTrials.gov to identify additional relevant articles from completed studies. Search dates and exact search strings for all searches are provided in Appendix A. All searches were designed and conducted in collaboration with an experienced search librarian.

We supplemented the electronic searches with a manual search of citations from a set of key review articles.42-67 The reference lists from these articles were hand-searched and cross-referenced against our library of database search results. Additional relevant articles not already under consideration were retrieved for screening. All citations were imported into an electronic database (EndNote^®^ Version X4; Thomson Reuters, Philadelphia, PA). We did not systematically search gray literature databases beyond our review of potentially relevant studies listed in ClinicalTrials.gov—the high volume of literature identified through our searches of peer-reviewed articles made it unlikely that further searching of gray literature would substantially increase the chances of identifying relevant data that would meet inclusion criteria. However, we did invite additional information through a request for scientific information packets that was submitted to drug manufacturers on our behalf by AHRQ. Submissions received through this mechanism were reviewed and relevant citations screened against the review inclusion/exclusion criteria.

#### Inclusion and Exclusion Criteria

The PICOTS-based criteria developed to screen articles for inclusion/exclusion at the title/abstract and full-text levels are detailed in Table 1.

Table 1 Summary of inclusion and exclusion criteria for the systematic review

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | - All KQs:; ○ Women taking OCs for contraception or women taking OCs for primary prevention of ovarian cancer^a^; ○ Women who do not have a history of ovarian cancer and have not undergone bilateral oophorectomy; - KQs 3 and 6:; ○ Women with a family history of ovarian or premenopausal breast cancer suggesting increased risk based on current recommendations; ○ Women with a known BRCA1/BRCA2 mutation | Nonhuman studies
Interventions | OC use (includes OC use for varying time periods and OC use with different formulations) | Study does not provide a description of at least one of the following:; 1. OC formulation(s) used; 2. Length of OC use; (Not required for studies reporting ovarian cancer outcomes or conducted in a population taking OCs for primary prevention of ovarian cancer)
Comparators | No use of combination or progestin-only OCs, including either no contraceptive method at all or contraceptive methods other than combination or progestin-only OCs (e.g., natural family planning, barrier methods, sterilization, intrauterine devices, injectable or implantable hormonal contraception) | Study does not include controls; i.e., an estimate of outcomes in women not using OCs (population estimates are acceptable) Studies comparing OC formulations (without including a non-OC control) are acceptable for studies reporting venous thromboembolism, stroke, or MI outcomes
Outcomes | Study reports quantitative association between exposure to OCs and one of the outcomes listed below:; - KQs 1, 2, 3, 6:; ○ Diagnosis of ovarian cancer, ovarian cancer mortality; ○ Adverse effects (see KQ 5); - KQ 4:; ○ Diagnosis of endometrial cancer, endometrial cancer mortality, diagnosis of colorectal cancer, colorectal cancer mortality; ○ Adverse effects (see KQ 5); - KQ 5:; ○ Diagnosis of breast cancer, cervical cancer, venous thromboembolic event, stroke, or myocardial infarction; disease-specific mortality associated with these outcomes; - KQ 7: Not applicable | Study only reports outcomes related to assisted reproductive technologies or abortion
Timing | Studies of any duration | None
Setting | All settings | None
Study design | - Controlled studies (randomized trials, cohort studies, case-control studies), pooled patient-level meta-analyses, or systematic reviews and study-level meta-analyses^b^; - Study sample size ≥ 100 subjects for nonrandomized studies^c^ | - Not a clinical study (e.g., editorial, non–systematic review, or letter to the editor); - Exploratory study with inadequate sample size
Publications | - English-language only; - Peer-reviewed articles; - Outcome reporting falls within the following publication ranges:; ○ Study reports an ovarian cancer outcome of interest and was published on or after 01-Jan-1990^d^; ○ Study reports a breast, endometrial, cervical, or colorectal cancer outcome of interest and was published on or after 01-Jan-2000^e^; ○ Study reports a venous thromboembolic event, stroke, or myocardial infarction outcome of interest and was published on or after 01-Jan-1995^f^ | Non-English articles^g^

KQ=Key Question; MI = myocardial infarction; OC=oral contraceptive

a If the purpose of OC use was unclear, it was assumed to be contraception.

b Systematic reviews and study-level meta-analyses were excluded from direct abstraction; those representing key sources were hand-searched as potential sources of additional material.

c Small nonrandomized studies <100 subjects were excluded because confidence intervals for outcomes of interest are generally quite wide if appropriate adjustment for confounding is performed, and variability in reporting of potential confounders makes meta-analysis problematic.

d We considered studies published from January 2000 to June 2012 for the primary ovarian cancer outcome analyses. Older data (with publication dates beginning January 1990) were used to conduct sensitivity analyses allowing us to compare the results from the January 2000 to June 2012 analyses with those from a longer date range (January 1990 to June 2012).

e Date ranges for these cancer outcomes were selected to balance generalizability (OC formulations used in earlier studies not currently on market) and power (peak incidence of cancers 10 to 30 years after typical use of oral contraceptives).

f Date ranges for acute vascular events associated with OC use were restricted to more recent years to reflect currently available formulations.

g Non-English articles were excluded (1) due to the high volume of literature available in English-language publications (including the majority of known important studies) and (2) due to concerns about the applicability of non-English publication studies to populations in the United States. The variability in OC formulations approved for use across countries increases the likelihood that non-English language studies would include OCs not available or not in use in the United States.

#### Study Selection

Using the inclusion and exclusion criteria described in Table 1, two investigators independently reviewed the titles and abstracts of articles retrieved through the search strategies for potential relevance to the KQs. Articles included by either reviewer were promoted to full-text screening. At the full-text screening stage, two investigators independently reviewed the full text of each article and indicated a decision to include or exclude the article for data abstraction. When paired reviewers arrived at different decisions about whether to include or exclude an article, or about the reason for exclusion, we reconciled the difference through review and discussion among investigators. Articles meeting eligibility criteria were included for data abstraction. All screening decisions were made and tracked in a Distiller SR database (Evidence Partners Inc., Manotick, ON, Canada).

#### Data Extraction

The investigative team created forms for abstracting the data elements for the KQs. The abstraction forms were pilot-tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors for accuracy. Based on clinical and methodological expertise, pairs of researchers were assigned to abstract data from the eligible articles. One researcher abstracted the data, and the second reviewed the completed abstraction form alongside the original article to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer's opinion if consensus could not be reached by the first two researchers.

To aid in both reproducibility and standardization of data collection, guidance documents were drafted and given to the researchers as reference material, and researchers received further data abstraction instructions directly on each form created specifically for this project within the DistillerSR data synthesis software. We designed the data abstraction forms for this project to collect information required to conduct the review, including data needed to evaluate the specified eligibility criteria for inclusion; demographic and other patient characteristics of relevance (e.g., family history of ovarian cancer); details of the interventions and comparators (e.g., OC dose, formulation, patterns of use); outcome measures and adjustment factors applied in study analyses; and data needed to assess quality and applicability. Appendix B provides a detailed listing of the data elements abstracted.

### Quality Assessment of Individual Studies

We evaluated the quality of individual studies using the approach described in AHRQ's “Methods Guide.”39 To assess quality, we used the approach to (1) classify the study design, (2) apply predefined criteria for quality and critical appraisal, and (3) arrive at a summary judgment of the study's quality. To evaluate methodological quality, we applied criteria for each study type derived from core elements described in the “Methods Guide.” Criteria of interest for all studies included similarity of groups at baseline, the extent to which outcomes were described, blinding of subjects and providers, blinded assessment of the outcome(s), intention-to-treat analysis, differential loss to followup between the compared groups or overall high loss to followup, and conflicts of interest. No randomized controlled trials were identified for inclusion in this review, thus criteria specific to randomized studies (e.g., methods of randomization and allocation concealment) were not considered.

Additional elements considered for observational studies included methods for selection of participants and management of selection bias, measurement of interventions/exposures, addressing any design-specific issues, and controlling confounding. To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of good, fair, and poor (Table 2). For each study, one investigator assigned a summary quality rating, which was then reviewed by a second investigator; disagreements were resolved by consensus or by a third investigator if agreement could not be reached. Several studies are represented by more than one article. In some of those cases, the study data could not be combined into one abstraction. In those instances, the quality ratings for individual abstractions within a study grouping could vary based on the specific component articles' quality of reporting, the evaluated outcomes, and the statistical and analytical methods used.

Table 2 Definitions of overall quality ratings

Quality Rating | Description
Good | A study with the least bias; results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results. In addition, specific to cohort and case-control studies, inclusion/exclusion criteria were applied consistently to all comparison groups; cases and controls were selected appropriately; strategies for recruiting patients were consistent across study groups; and confounding variables were assessed using valid and reliable measures and implemented consistently across all study participants.
Fair | A study that is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | A study with significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

### Data Synthesis

We used two complementary approaches to data synthesis. First, we summarized the primary literature by abstracting relevant continuous (e.g., age and categorical data (e.g., BRCA1/2 mutation status). We then determined the feasibility of completing a quantitative synthesis. Feasibility generally depended on the volume of relevant literature, the conceptual homogeneity of the studies, and the completeness of the reporting of results. For this topic, meta-analysis was particularly challenging, because (1) all of the literature was observational, increasing the methodological complexity of the meta-analysis, and (2) there was substantial heterogeneity in the types of exposures (e.g., OC formulation), timing of exposures (e.g., intermittent use of OCs over the course of a reproductive lifetime) and how exposures were measured and reported (ever users versus never users or current versus noncurrent users, duration of use as a continuous or categorical variable). Despite the challenges, we determined that meta-analysis was indicated for a number of the outcomes of interest considered in this review; other outcomes for which meta-analysis was not feasible are summarized using descriptive statistics.

Even when meta-analysis was feasible, at best the results provide evidence for whether there is an association between OC use and a specific outcome, the direction of that association (toward harm or benefit), and the magnitude and precision of that association, which allows estimation of the probability of developing that outcome in OC users relative to nonusers. Estimating the impact of the association on the absolute probability of developing that outcome, for either an individual or a population, requires additional methods. First, in order to estimate the absolute increase or decrease in risk based on the results of the meta-analysis, we used the results of the meta-analyses, together with data on the overall incidence of the outcome and the prevalence of OC use, to estimate age-specific incidence in ever versus never users (for cancer outcomes) and current versus noncurrent users (for acute vascular events). Although these results are useful for estimating the risk of individual outcomes, they do not account for the interaction of multiple competing risks, including both the outcomes of interest and other events, such as death from other causes or surgical removal of the ovaries for benign conditions, that affect the overall impact of OC use at the individual and population level. In order to estimate these joint effects, we developed a comparative effectiveness decision model that allowed us to simulate the joint effects of OC use on cancer and vascular events on the overall balance of benefits and harms. The model also allows exploration of the effects of variation in different aspects of OC use (such as age at first use, duration of use, or individual risk of various outcomes) on the overall impact of OC use. Finally, the model allows estimation of uncertainty in the individual estimates of OC effects on overall uncertainty about the balance of benefits and harms, which in turn may help prioritize future research needs.

#### Outcome Measures

For each disease/condition of interest, we estimated the effect of OC use on a number of outcomes. Outcome measures considered for the meta-analyses were:

- Disease-specific incidence (i.e., were OC users more or less likely to develop the disease/condition?)
- Disease-specific mortality (i.e., were OC users more or less likely to die from a given cause than nonusers?)
- Disease-specific survival (i.e., among women who developed the outcome, were OC users more or less likely to die than nonusers?)

The following outcome measures were considered for modeling:

- Age-specific incidence
- Cumulative lifetime incidence
- Cumulative lifetime mortality from outcomes
- Life expectancy
- Quality-adjusted life expectancy
- Number needed to harm and number needed to prevent (derived from absolute differences in lifetime incidence and mortality)
- Harm/benefit ratio for disease incidence (defined as the sum of excess cases of breast cancer, cervical cancer, myocardial infarction, deep venous thrombosis, pulmonary embolism, and stroke in OC users, divided by the sum of prevented cases of ovarian, colorectal, and endometrial cancers); each cancer also was considered individually
- Harm/benefit ratio for disease mortality (defined as the sum of excess deaths from breast cancer, cervical cancer, myocardial infarction, deep venous thrombosis, pulmonary embolism, and stroke in OC users, divided by the sum of prevented deaths from ovarian, colorectal, and endometrial cancers); each cancer also was considered individually

#### Meta-Analytic Methods

Details of the specific approaches to the meta-analysis of the effects of OC use on ovarian cancer, other cancers, and acute vascular events are provided in the relevant sections. Our general approach for each outcome was to analyze, if possible, the following associations:

- Temporal relationships:
  ○ Ever versus never OC use
  ○ Current versus noncurrent OC use
  ○ Duration of current OC use
  ○ Age at first OC use
  ○ Time since last OC use
- OC formulation:
  ○ Estrogen dose (high versus low)
  ○ Progestin generation (first, second, third, and fourth generations)
- Special populations (such as women with known family history or genetic predisposition)

When study designs and outcomes reported were similar and the population in the study was broad (e.g., not Factor V Leiden carriers), we estimated pooled odds ratios with 95% confidence intervals (95% CIs) using a random-effects model. We evaluated heterogeneity visually and with the Cochran Q statistic using a threshold p-value of less than 0.10. We stratified analyses by study type (case-control, cohort, pooled analyses). All meta-analyses were performed using Comprehensive Meta-Analysis Version 2 (Biostat; Englewood, NJ; 2005).68

Confidence intervals from the included study publications were entered into the Comprehensive Meta-Analysis (CMA) program. However, many of these confidence intervals had been rounded to a single decimal place. The CMA program checks the intervals for symmetry in the logarithmic scale. In certain cases, the rounded limits were not accepted by CMA. In such cases, we kept the point estimate as given but changed the confidence limits so that they were symmetric. This resulted in slight differences in the confidence intervals in the forest plots when compared with the study publications.

Results were discussed qualitatively when study numbers were insufficient for meta-analysis (less than three), when confidence intervals around measures of association were not reported or could not be calculated, or when a study included a special population that is not likely to be representative of the general population of reproductive age women.

We included data from pooled analysis articles in our meta-analyses if all three of the following conditions were met:

- None of the individual studies included in the pooled analysis had already been included for meta-analysis.
- At least half of the studies in the pooled analysis were published on or after the date threshold applied for the outcome under consideration in the analysis (January 1, 2000, for ovarian cancer outcomes; January 1, 2000, for other included cancer outcomes; and January 1, 1995, for acute vascular events)
- Data in the pooled analyses were presented such that their inclusion in the current meta-analysis was feasible.

##### Estimation of Absolute Risks

We estimated the impact of OC use on age-specific absolute risk from population-based estimates of age-specific incidence, age-specific exposure estimates for OCs, and the derived odds ratios from the meta-analyses. For any outcome,

Overall Incidence = (Incidence in OC users) * (Prevalence OC use) + (Incidence in nonusers) * (Prevalence nonuse).

since

Incidence in OC users = (Incidence in nonusers) * (Relative risk in OC users),

and

Prevalence nonuse = 1 – (Prevalence OC use),

separate estimates for age-specific incidence in users and nonusers can be derived from the overall incidence, the prevalence of OC use, and the relative risks (estimated here from the odds ratios from the respective meta-analyses).

#### Simulation Model

We constructed a semi-Markov state-transition model that modeled a cohort of women aged 10 to 100, using TreeAge Pro 2012 (Williamstown, MA: TreeAge, Inc.). Age-specific and race-specific probabilities of OC use and important competing risks or effect modifiers, such as all-cause mortality, tubal ligation, hysterectomy, and oophorectomy, were obtained from the literature or publicly available data sources. Estimates for the effect of OC use on cancers and vascular events were based on the results of the meta-analysis, based on either ever or current use of OCs. Other factors, such as duration of use, were included if they were statistically significant in the meta-analysis.

The model was run as a microsimulation, which allowed conditioning of probabilities on past history. Depending on the analysis, each model run included 5,000 to 1,000,000 simulated individuals, with estimates of the outcomes of interest based on the mean value of each model run (or, in some cases, the weighted average of multiple model runs).

Estimates were derived for both the overall population given current OC use patterns (i.e., the cumulative effect of current patterns of age of starting OCs and duration of use on the outcomes of interest based on the risk estimates compared with a scenario where OCs had no effect on risk), as well as at the individual level (the cumulative effect of OC use in all users, based on current patterns of use, vs. nonusers).

The impact of varying age of starting and duration of use was assessed in a separate analysis.

Finally, we assessed the impact of uncertainty in the estimates of OC effects by using a method analogous to cost-effectiveness analysis, where total harms were considered as “costs” and assessing the effect of uncertainty in the effects (based on the confidence intervals of the relative risk estimate) on whether OC use would be recommended based on different “willingness-to-pay” thresholds for harm/benefit ratio.

### Strength of Evidence

The strength of evidence for each Key Question and outcome was assessed using the approach described in the “Methods Guide.”39,69 The evidence was evaluated using the four required domains (Table 3).

Table 3 Strength of evidence required domains

Domain | Rating | How Assessed
Risk of bias | Low Medium High | Assessed primarily through study design (RCT vs. observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether effect sizes are generally on the same side of “no effect” and the overall range of effect sizes
Directness | Direct Indirect | Assessed by whether the evidence involves direct comparisons (e.g., direct comparison of stroke risk in women using OCs compared with women using IUDs) or indirect comparisons through use of surrogate outcomes (e.g., measurement of blood-clotting factors in women using OCs vs. IUDs) or use of separate bodies of evidence (risk of stroke in OC users vs. placebo, and risk of stroke in IUD users vs. placebo)
Precision | Precise Imprecise | Based primarily on the size of the confidence intervals of effect estimates

IUD = intrauterine device; OC = oral contraceptive; RCT = randomized controlled trial

Additionally, when appropriate, the studies were evaluated for dose-response association, the presence of confounders that diminished an observed effect, strength of association (magnitude of effect), and publication bias. The strength of evidence was assigned an overall grade of high, moderate, low, or insufficient according to the following four-level scale:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

### Applicability

To assess applicability, we used the PICOTS format to identify specific issues that may limit the applicability of individual studies or a body of evidence as recommended in the “Methods Guide.”39,70 We used data abstracted on the population studied, the intervention and comparator, the outcomes measured, study settings, and timing of assessments to identify specific issues that may limit the applicability of individual studies or a body of evidence as recommended in the “Methods Guide.”

Specific factors affecting applicability included (but were not limited to):

- Population: We anticipated that most of the literature was based on women using OCs for contraception, not as prevention for ovarian cancer. Factors such as parity and BRCA status, which affect underlying ovarian cancer risk, may differ (or not be reported) compared with current relevant groups. The balance of other benefits and harms (particularly cardiovascular and thrombotic risks) may differ based on age of use, which would be relevant in some subpopulations (e.g., women over 35 who have not previously used OCs).
- Intervention and comparator: The formulation of OCs used in the literature may not reflect currently available OCs, and the duration and pattern of use may not reflect potential duration and pattern in the setting of primary ovarian cancer prevention. Currently available alternatives to OCs may not have been included in “nonuser” groups in the literature.
- Outcomes: Data on all the relevant outcomes is unlikely to be available for all potentially applicable comparators, particularly newer contraceptive methods.

We used these data to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population in comparison with the target population, version or characteristics of the intervention used in comparison with therapies currently in use, and clinical relevance and timing of the outcome measures. We summarized issues of applicability qualitatively throughout the sections of the report.

### Peer Review and Public Commentary

The peer review process is our principal external quality-monitoring device. Experts in key clinical and research areas (obstetrics/gynecology; gynecologic oncology; prevention, screening, treatment, and management of gynecologic cancers; chemoprevention of cancer; women's health), methodological areas (cancer epidemiology, decision modeling, systematic review), along with individuals representing ovarian cancer patient interest communities and women's reproductive health stakeholders were invited to provide external peer review of this draft report. AHRQ, CDC representatives, and an associate editor provided comments, as did members of the Technical Expert Panel. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented our responses in a disposition of comments report that will be made available 3 months after the Agency posts the final report on the AHRQ Web site.

### Literature Search Results

In Figure 8, we depict the flow of articles through the literature search and screening process for the review as a whole. Searches of PubMed, Embase, and the Cochrane Database of Systematic Reviews yielded 7,196 citations, 767 of which were duplicates. Manual searching and contacts to drug manufacturers identified 47 additional citations, for a total of 6476. No additional relevant citations beyond those already identified were found from a search for relevant studies listed on ClinicalTrials.gov. After applying inclusion/exclusion criteria at the title-and-abstract level, 1919 full-text articles were retrieved and screened. Of these, 1671 were excluded at the full-text screening stage, leaving 248 articles (representing 157 unique studies) for data abstraction. As indicated in Figure 8, several articles/studies were relevant to more than one outcome of interest (55 relevant to ovarian cancer outcomes (KQ 1, KQ 2, KQ 3), 66 to other cancers of interest (KQ 4, KQ 5), and 50 to vascular events (KQ 5).

Figure 8 Literature flow diagram

MI = myocardial infarction; OC = oral contraceptive; RCT = randomized controlled trial; VTE = venous thromboembolism

* Note that a given study may address more than one outcome group.

Figure 8 depicts the flow of articles through the literature search and screening process for the review as a whole. Searches of PubMed, Embase, and the Cochrane Database of Systematic Reviews yielded 7196 citations, 767 of which were duplicates. Manual searching and contacts to drug manufacturers identified 47 additional citations, for a total of 6476. After applying inclusion/exclusion criteria at the title-and-abstract level, 1919 full-text articles were retrieved and screened. Of these, 1671 were excluded at the full-text screening stage, leaving 248 articles (representing 157 unique studies) for data abstraction. As indicated in Figure 8, several articles/studies were relevant to more than one outcome of interest (55 relevant to ovarian cancer outcomes (KQ 1, KQ 2, KQ 3), 66 to other cancers of interest (KQ 4, KQ 5), and 50 to vascular events (KQ 5).

Subsequent sections of this report describe the key points of the findings, summaries of the included studies relevant to each section, and a detailed synthesis of the evidence. Appendix C provides full citations of included articles as well as the relationship between related articles for the same study/patient population. Note that in the descriptive portions of the text, related data from articles considered to be part of one study grouping may be represented in both the case-control and cohort categories (if both designs are applicable) due to a relationship between the represented patient populations. Similarly, related data from articles considered to be part of one study grouping may be represented in more than one quality category (see the Methods section for a full description of quality assessment). Appendix D provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.