# Peer Reviewers

Prior to publication of the final evidence report, the Evidence-based Practice Center (EPC) sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Jeffrey C. Andrews, M.D.
  Associate Professor of Medicine, Obstetrics and Gynecology
  Vanderbilt University of School of Medicine
  Nashville, TN
- Jeremy Goldhaber-Fiebert, Ph.D.
  Assistant Professor of Medicine, Centers for Health Policy/Center for Primary Care and Outcomes Research
  Stanford University School of Medicine
  Stanford, CA
- Shalini L. Kulasingam, Ph.D.
  Assistant Professor, School of Public Health
  University of Minnesota
  Minneapolis, MN
- Malcolm C. Pike, Ph.D.
  Professor of Medicine, Keck School of Medicine
  University of Southern California
  Los Angeles, CA