# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the Evidence-based Practice Center (EPC) consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Andrew Berchuck, M.D.
  Director, Division of Gynecologic Oncology
  Duke University Medical Center
  Durham, NC
- Wendy R. Brewster, M.D., Ph.D.
  Research Director
  UNC Center for Women's Health
  Chapel Hill, NC
- Louise A. Brinton, Ph.D., M.P.H.
  Chief, Hormonal and Reproductive Epidemiology Branch
  National Cancer Institute
  Rockville, MD
- Karen Orloff Kaplan, M.S.W., M.P.H., Sc.D.
  Former CEO, Ovarian Cancer National Alliance
  Washington, DC
- Cara J. Krulewitch, C.N.M., Ph.D.
  Chief, Epidemiology Evaluation and Research Branch II
  Division of Epidemiology
  U.S. Food and Drug Administration
  Silver Spring, MD
- Joan D. Nagel M.D., M.P.H
  Program Director, Interdisciplinary Research Programs
  National Institutes of Health
  Bethesda, MD
- Doug K. Owens, M.D., M.S.
  Director, Program on Clinical Decision Making and Guideline Development
  Center for Primary Care and Outcomes Research
  Stanford University School of Medicine
  Stanford, CA
- Debbie Saslow, Ph.D.
  Director, Breast and Gynecologic Cancer
  American Cancer Society, Inc.
  Atlanta, GA
- Rachel Walden, M.L.I.S.
  Consultant, Our Bodies Ourselves
  Nashville, TN
- Maura K. Whiteman, Ph.D.
  Epidemiologist, Women's Health & Fertility Branch, Division of Reproductive Health
  Centers for Disease Control and Prevention
  Atlanta, GA