# Acknowledgments

The authors thank Robert Kane, M.D., for his critical reading of the report, and Megan von Isenburg, M.S.L.S., for her help with the literature search and retrieval.