# Analyses of Potential Publication Bias

We used Comprehensive Meta-Analysis Version 2 (Borenstein M, Hedges L, Higgins J, Rothstein H. Comprehensive Meta-analysis Version 2, Biostat, Englewood NJ [2005]) to test for potential publication bias for the outcomes described below. Figures E-1 to E-5 show the resulting funnel plot for each outcome. Note that there is no asymmetry in any of the plots.

## Ovarian Cancer Incidence

Figure E-1 Funnel plot for ovarian cancer incidence

Description: Figure E-1 shows the resulting funnel plot from the examination of potential publication bias of studies of ovarian cancer incidence. There is no asymmetry in the plot.

## Breast Cancer Incidence

Figure E-2 Funnel plot for breast cancer incidence

Description: Figure E-2 shows the resulting funnel plot from the examination of potential publication bias of studies of breast cancer incidence. There is no asymmetry in the plot.

## Cervical Cancer Incidence

Figure E-3 Funnel plot for cervical cancer incidence

Description: Figure E-3 shows the resulting funnel plot from the examination of potential publication bias of studies of cervical cancer incidence. There is no asymmetry in the plot.

## Colorectal Cancer Incidence

Figure E-4 Funnel plot for colorectal cancer incidence

Description: Figure E-4 shows the resulting funnel plot from the examination of potential publication bias of studies of colorectal cancer incidence. There is no asymmetry in the plot.

## Endometrial Cancer Incidence

Figure E-5 Funnel plot for endometrial cancer incidence

Description: Figure E-5 shows the resulting funnel plot from the examination of potential publication bias of studies of endometrial cancer incidence. There is no asymmetry in the plot.

We also computed Begg and Mazumdar's correlation test for publication bias for each cancer incidence (Table E-1). None of the correlations were significant although breast cancer incidence was marginal.

Table 1 Begg and Mazumdar's correlation test for publication bias

Cancer Incidence | Correlation | p-value
Ovarian | -0.055 | 0.6458
Breast | 0.289 | 0.0539
Cervical | 0.278 | 0.2972
Colorectal | 0.000 | 1.0000
Endometrial | -0.048 | 0.8806

Overall, there was no evidence of publication bias in the meta-analyses.