# Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reason shown in bold. Reasons for eclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles

## Abstract only or full text unobtainable

AlHilli MM, Dowdy SC, Weaver A, et al. Factors associated with synchronous ovarian and endometrial cancer: A population-based case control study. Journal of Clinical Oncology. 2011;29(15):2011-06. [pmid: 21502544].
Anonymous. The safety and contraceptive efficacy of a 24-day low-dose oral contraceptive regimen containing gestodene 60 microg and ethinylestradiol 15 microg. Eur J Contracept Reprod Health Care. Suppl 2. 1999;4:9-15. [pmid: 14677620].
Aung MT, Soe MY, Mya WW. Study on risk factors for cervical carcinoma at Central Womens Hospital, Yangon, Myanmar. BJOG: An International Journal of Obstetrics and Gynaecology. SUPPL. 1. 2012;119:124.
Carney M, Goodman M, Lurie G, et al. NSAIDS do not prevent ovarian cancer. Gynecologic Oncology. SUPPL. 1. 2012;125:S97.
Cea-Soriano L, Blenk T, M-A AW, et al. Hormonal therapies and meningioma: A UK primary care study. Pharmacoepidemiology and Drug Safety. SUPPL. 1. 2011;20:S240-S241.
Coutinho Nunes F, Caetano C, Figueiredo Dias M, et al. Oral contraception and breast cancer. European Journal of Contraception and Reproductive Health Care. SUPPL. 1. 2012;17:S137.
Cramer DW, Titus-Ernstoff L, Vitonis AF. Genital talc use and ovarian cancer: Influence of histologic type and menopausal status on strength and dose response of the association. Cancer Research. 2011;71(8):2011-04.
Dentali F, Poli D, Scoditti U, et al. Clinical history of patients with cerebral vein thrombosis: Results of a large multicenter international cohort study. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:763.
DeVries M, Agnihotram RV, Koushik A, et al. The role of environmental cofactors in the progression of cervical precancerous lesions. American Journal of Epidemiology. SUPPL. 11. 2011;173:S169.
Dinger J, Assmann A, Moehner S. Oral contraceptives and the risk of VTE: Reanalysis of the EURAS/LASS study. Pharmacoepidemiology and Drug Safety. SUPPL. 1. 2011;20:S74-S75.
Dinger J, Bardenheuer K, Assmann A. Safety and effectiveness of oral contraceptives in obese women. Pharmacoepidemiology and Drug Safety. SUPPL. 1. 2011;20:S15-S16.
Dinger J, Bardenheuer K, Franke C. The risk of VTE in users of a 24-day regimen of a combined oral contraceptive compared to conventional 21-day OC regimens: Results from the INASOC study. Pharmacoepidemiology and Drug Safety. SUPPL. 1. 2011;20:S131.
Dinger J, Moehner S, Do Minh T. Early use effects on the risk of venous thromboembolism after initiation of oral contraceptive use. Eur J Contracept Reprod Health Care. 2010;94(4 Suppl 1):S3.
Dinger J, Moehner S, Do Minh T. The risk of venous thromboembolism in users of an etonogestrel/ethinylestradiol containing vaginal ring - Interim results from the tasc study. Fertility and Sterility. 2011;96(3 SUPPL. 1):S36.
Driak D, Sehnal B, Hurt K, et al. Influence of combined oral contraception with progestin dominancy on uterine fibroid development. European Journal of Contraception and Reproductive Health Care. SUPPL. 1. 2012;17:S96-S97.
Farhat GN, LaCroix A, Grady D, et al. Hot flashes, hormone therapy, and breast cancer risk: The Women's Health Initiative Clinical Trials. Cancer Prevention Research. 2010;3(12):2010-11.
Feldman L, Goldstein L, Ouyang B, et al. Oral contraceptive and hormone replacement therapy in women with cerebral aneurysms. Journal of NeuroInterventional Surgery. SUPPL. 1. 2010;2:A13-A14.
Gold EB, Crawford SL, Avis N, et al. Factors longitudinally related to age at menopause. American Journal of Epidemiology. SUPPL. 11. 2011;173:S152.
Haque R, Inzhakova G, Shi JM, et al. The new generation of combined hormone contraceptives and risk of gynecologic cancers. Journal of Clinical Oncology. 2011;29(15):2011-06. [pmid: 21502544].
Heit JA, Armasu SM, Matsumoto ME, et al. Association of gene-environment interactions with venous thromboembolism (VTE): A merged/imputed genome-wide scan/candidate-gene case-control study. Blood. 2011;118(21):2011-12.
Heit JA, Armasu SM, Petterson T, et al. Association of gene-environment interactions with venous thromboembolism (VTE): A pathway-directed candidate-gene case-control study. Blood. 2010;116(21):2010-12.
Howard B, Weiss H, Ricciotti N. A multicentre, randomised, double-blind study to evaluate the efficacy of an extended regimen oral contraceptive pill for the management of menstruallyrelated migraine headaches. European Journal of Contraception and Reproductive Health Care. SUPPL. 1. 2012;17:S45-S46.
M, Lopez-Bermejo A, et al. Ethinylestradiol-cyproterone acetate vs pioglitazone-flutamide-metformin in adolescent girls with androgen excess. Hormone Research in Paediatrics. SUPPL. 2. 2011;76:93. [pmid: 21625068].
Kelsall D. Clinical shorts. Cmaj. 2011;183(17):2016.
Lijfering WM, Rosendaal F, Reitsma P, et al. Risk of venous thrombosis associated with coagulation factor viii and its interrelationship with other procoagulant and environmental risk factors. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:400-401.
Lindh I, Milsom I. The influence of intrauterine contraception on the prevalence and severity of dysmenorrhoea: A longitudinal population study. European Journal of Contraception and Reproductive Health Care. SUPPL. 1. 2012;17:S106-S107.
Lodigiani C, Lorusso R, Ferrazzi P, et al. Sudden sensorineural hearing loss: A possible role of thrombophilia and cardiovascular risk factors. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:875. [pmid: 21255245].
Mantha S, Raghavan V, Karp R, et al. Progestin-only contraceptives and the risk of venous thromboembolism: Systematic review and meta-analysis. Blood. 2011;118(21):2011-12.
Naz T, Akhter Z, Jamal T. Oral contraceptives versus expectant treatment in the management of functional ovarian cysts. Journal of Medical Sciences. 2011;19(4):185-188.
Nezhat FR, Nezhat CH, Borhan S, et al. Is Hormonal Suppression Efficacious in Treating Functional Ovarian Cysts?. J Am Assoc Gynecol Laparosc. 1994;1(4, Part 2):S26. [pmid: 9073730].
Papadakis E, Spyrou A, Gatsa E, et al. Hormonal therapy (HT) associated thromboembolism. retrospective analysis of 81 cases and long term follow up, experience from a single center. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:632.
Poole EM, Schernhammer ES, Tworoger SS. Rotating night shift work and risk of ovarian cancer. Cancer Prevention Research. 2010;3(12):2010-11.
Schrijver LH, Rookus MA, Mooij TM, et al. Brca1 carriers and oral contraceptives-risk-benefit calculation on breast and ovarian cancer. European Journal of Cancer. SUPPL. 1. 2012;48:S75.
Setiawan VW, Karageorgi S, Deming S, et al. Age at last birth and endometrial cancer risk: Pooled analysis in the Epidemiology of Endometrial Cancer Consortium. Cancer Research. 2011;71(8):2011-04.
Siegerink B, Algra A, Rosendaal FR. High molecular weight kininogen and the risk of myocardial infarction and ischaemic stroke in young women: Results from the ratio case-control study. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:567.
Siegerink B, Andersson HM, Luken BM, et al. VWF and ADAMTS13 levels and the risk of myocardial infarction and ischaemic stroke in young women: Results from the ratio case-control study. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:209.
Skouby SO. Oral contraceptives and cancer incidence. European Journal of Contraception and Reproductive Health Care. SUPPL. 1. 2012;17:S158.
Stegeman BH, Vos HL, Helmerhorst FM, et al. Haplotypes in the CYP1A2 and CYP3A4 genes and the risk of oral contraceptive-associated venous thrombosis. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:768.
Stegeman BH, Vos HL, Helmerhorst FM, et al. Increased levels of sex hormone binding globulin in association with venous thrombosis. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:428. [pmid: 21155967].
Trentham-Dietz A, Sprague B, Hampton J, et al. Are risk factors for breast cancer in woman < 50 years of age different than for women over 50?. American Journal of Epidemiology. SUPPL. 11. 2011;173:S256.
Uccella S, Mariani A, Wang AH, et al. Epidemiologic risk factors for type I versus type II endometrial cancer in the Iowa women's health study (IWHS). International Journal of Gynecological Cancer. 2011;21(12 SUPPL. 3):S1127.
Van Den Berg L, De Jong S, Huisman M, et al. Endogenous female reproductive hormones and the risk of amyotrophic lateral sclerosis. Neurology. 2012;78(1):2012-04.
Van Hylckama Vlieg A, Flinterman LE, Cannegieter SC, et al. The risk of recurrent venous thrombosis associated with oral contraceptive use. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:173. [pmid: 20961397].
Van Hylckama Vlieg A, Smith NL, Lijfering WM, et al. The association of concomitant use of estrogen hormones and statins and the risk of venous thrombosis. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:401.
Vercellini P, Somigliana E, Vigano P, et al. Surgical reduction of ovarian reserve in women with endometriomas. Human Reproduction. SUPPL. 1. 2011;26:i41.
Wahner Hendrickson AE, Goode EL, Knutson KL, et al. Predictors of ovarian cancer survival: A prospective study at Mayo Clinic. Journal of Clinical Oncology. 2011;29(15):2011-06. [pmid: 21502544].
Winckers K, Siegerink B, Duckers C, et al. An increased tissue factor pathway inhibitor (TFPI) activity is associated with myocardial infarction in young women: Results from the ratio study. Journal of Thrombosis and Haemostasis. SUPPL. 2. 2011;9:900.
Yang HP, Trabert B, Murphy MA, et al. Ovarian cancer risk factors by histologic subtypes in the NIH-AARP Diet and Health Study. Cancer Research. 2011;71(8):2011-04.

## Non-English language

Heinemann LAJ, Lewis MA, Kuhl-Habich D, et al. Lifetime history of oral contraceptive use and development of tumours of the uterus and ovary. Geburtshilfe und Frauenheilkunde. 2002;62(6):566-573.
Heinemann LAJ, Lewis MA, Kuhl-Habich D, et al. The risk of breast tumours and lifetime history of oral contraceptive use. Geburtshilfe und Frauenheilkunde. 2002;62(8):750-757.
Heinemann LAJ, Lewis MA, Kuhl-Habich D, et al. Use of Oral Contraceptives and Risk of Cancer of the Uterine Corpus or Ovary. Two Case-Control Studies. Geburtshilfe und Frauenheilkunde. 2003;63(10):1018-1026.
Moradan S, Ghorbani R, Baghani S. Incidence of abnormal uterine bleeding in individuals who used hormonal contraceptive methods and referred to Semnan health centers (2006-2007). Koomesh. 2009;10(3):219-224+33.

## Not RCT, cohort, case-control, or patient-level meta-analysis

Aho K, Heliovaara M. Risk factors for rheumatoid arthritis. Ann Med. 2004;36(4):242-51. [pmid: 15224650].
Aktun H, Moroy P, Cakmak P, et al. Depo-Provera: use of a long-acting progestin injectable contraceptive in Turkish women. Contraception. 2005;72(1):24-7. [pmid: 15964288].
Alhenc-Gelas M, Plu-Bureau G, Guillonneau S, et al. Impact of progestagen on activated protein C (APC) resistance among users of oral contraceptives. Journal of Thrombosis and Haemostasis. 2004;2(9):1594-1600. [pmid: 15333036].
Alhilli MM, Dowdy SC, Weaver AL, et al. Incidence and factors associated with synchronous ovarian and endometrial cancer: A population-based case-control study. Gynecologic Oncology. 2012;125(1):109-113. [pmid: 22210467].
Allen TW. Low-dose contraceptives increase cerebral thromboembolic attack risk. Journal of the American Osteopathic Association. 1993;93(7):755.
Allen VM, Armson BA, Wilson RD, et al. Teratogenicity associated with pre-existing and gestational diabetes. J Obstet Gynaecol Can. 2007;29(11):927-44. [pmid: 17977497].
Al-Shanqeeti A, van Hylckama Vlieg A, Berntorp E, et al. Protein Z and protein Z-dependent protease inhbitor. Determinants of level and risk of venous thrombosis. Thrombosis and Haemostasis. 2005;93(3):411-413. [pmid: 15735788].
Althaus FA, Kaeser L. At pill's 30th birthday, breast cancer question is unresolved. Fam Plann Perspect. 1990;22(4):173-6. [pmid: 2226748].
Anonymous. 30 years of change: the current perspective on cardiovascular risks and oral contraceptives. Contracept Rep. 1995;6(2):4-9. 14. [pmid: 12319497].
Anonymous. A multinational case-control study of cardiovascular disease and steroid hormone contraceptives Description and validation of methods. World Health Organization Collaborative Study of Cardiovascular and Steroid Hormone Contraception. J Clin Epidemiol. 1995;48(12):1513-47. [pmid: 8543965].
Anonymous. Age at last birth has significant impact on ovarian cancer risk. South African Medical Journal. 2004;94(9):740-741.
Anonymous. An open-label, multicenter, noncomparative safety and efficacy study of Mircette, a low-dose estrogen-progestin oral contraceptive. The Mircette Study Group. Am J Obstet Gynecol. 1998;179(1):S2-8. [pmid: 9704812].
Anonymous. Birth control pills, cigarettes, alcohol linked to liver cancer. Oncology (Williston Park). 1992;6(3):101. [pmid: 1533135].
Anonymous. Cardiovascular disease and steroid hormone contraception. Report of a WHO Scientific Group. World Health Organ Tech Rep Ser. 1998;877:i-vii. 1. 89. [pmid: 9615606].
Anonymous. Cervical carcinoma and reproductive factors: collaborative reanalysis of individual data on 16,563 women with cervical carcinoma and 33,542 women without cervical carcinoma from 25 epidemiological studies. Int J Cancer. 2006;119(5):1108-24. [pmid: 16570271].
Anonymous. Combined oral contraceptive and heart attacks. New Zealand Medical Journal. 1997;110(1049):285.
Anonymous. Continuation rates for oral contraceptives and hormone replacement therapy. The ESHRE Capri Workshop Group. Hum Reprod. 2000;15(8):1865-71. [pmid: 10920118].
Anonymous. Contraceptive methods and breast cancer risk: an update. Contracept Rep. 2000;11(2):9-11. [pmid: 12349712].
Anonymous. Does the pill affect bone mineral density?. Contracept Technol Update. 2000;21(8):95-6. [pmid: 12349761].
Anonymous. Drospirenone: high risk of venous thrombosis. Prescrire Int. 2011;20(113):43-5. [pmid: 21488592].
Anonymous. Familial breast cancer: collaborative reanalysis of individual data from 52 epidemiological studies including 58,209 women with breast cancer and 101,986 women without the disease. Lancet. 2001;358(9291):1389-99. [pmid: 11705483].
Anonymous. Health risks outweigh benefits for combined estrogen plus progestin. Clinical trial stopped early in major study. Ginecol Obstet Mex. 2002;70:411-2. [pmid: 12449905].
Anonymous. Hormones and breast cancer. Hum Reprod Update. 2004;10(4):281-93. [pmid: 15192054].
Anonymous. Improved utilization of spacing methods--intrauterine devices (IUDs) and low-dose combined oral contraceptives (OCs)--through re-orientation training for improving quality of services. Indian Council of Medical Research Task Force on IUD and Hormonal Contraceptives. Contraception. 1994;50(3):215-28. [pmid: 7805372].
Anonymous. Less joint damage for arthritis patients who are often pregnant or use oral contraceptives long-term. Pharmaceutical Journal. 2002;268(7197):638.
Anonymous. Levonorgestrel is more effective, has fewer side-effects, than Yuzpe regimen. Prog Hum Reprod Res. 1999;(51):3-5. [pmid: 12349416].
Anonymous. Little risk of stroke for healthy young women using oral contraceptives. Prog Hum Reprod Res. 1996;(39):3-4. [pmid: 12292199].
Anonymous. No link between OC use and heart attack. Contracept Technol Update. 1999;20(10):115-6. [pmid: 12322318].
Anonymous. Oral contraceptive pills and the risk of venous thromboembolism. Prog Hum Reprod Res. 1996;(39):2-3. [pmid: 12292198].
Anonymous. Oral contraceptive users may be at some increased risk of cervical carcinoma. Family Planning Perspectives. 1995;27(3):134-135.
Anonymous. Oral contraceptives and hormone replacement therapy may protect against colorectal cancer. Contracept Rep. 1996;7(4):10. [pmid: 12291811].
Anonymous. Oral contraceptives and liver cancer. Contracept Rep. 1997;8(5):4-8. [pmid: 12348250].
Anonymous. Oral contraceptives and neoplasia World Health Organization- Technical Report Series. 1992;(817):1-46. [pmid: 1539455].
Anonymous. Oral contraceptives associated with long-term reduction in ovarian cancer risk. Journal of the National Medical Association. 2008;100(5):578.
Anonymous. Oral contraceptives not associated with increased risk of breast cancer. Pharmaceutical Journal. 2002;269(7205):6.
Anonymous. Plan B OTC. Med Lett Drugs Ther. 2006;48(1243):75. [pmid: 16977288].
Anonymous. Premature ovarian failure: frequency and risk factors among women attending a network of menopause clinics in Italy. BJOG. 2003;110(1):59-63. [pmid: 12504937].
Anonymous. Recent studies confirm the safety of oral contraceptives with respect to stroke. Contracept Rep. 1996;7(4):4-9. [pmid: 12291813].
Anonymous. Revised oral contraceptive labeling: FDA approves recommendation allowing delay of pelvic exam. Contracept Rep. 1993;4(5):4-7. [pmid: 12287403].
Anonymous. Venous thrombosis with cyproterone. Prescrire Int. 2002;11(60):116. [pmid: 12199266].
Anonymous. What is breast cancer risk with Depo-Provera?. Contracept Technol Update. 1992;13(1):15-6. [pmid: 12343459].
Arscott A, Nettelfield P. Myocardial infarction and oral contraceptives. Prof Nurse. 2001;16(5):1117-20. [pmid: 12029914].
Ascari E, Siragusa S, Piovella F. The epidemiology of deep vein thrombosis and pulmonary embolism. Haematologica. 1995;80(2 Suppl):36-41. [pmid: 7628769].
Ashrafunnessa, Kamal M. Cervical intraepithelial neoplasia and its relationship with hormonal contraceptive methods. Bangladesh Medical Research Council Bulletin. 2008;34(1):33-34. [pmid: 18783075].
Baeten JM, Lavreys L, Sagar M, et al. Effect of contraceptive methods on natural history of HIV: studies from the Mombasa cohort. J Acquir Immune Defic Syndr. Suppl 1. 2005;38:S18-21. [pmid: 15867603].
Bagshaw S. The combined oral contraceptive. Risks and adverse effects in perspective. Drug Saf. 1995;12(2):91-6. [pmid: 7766340].
Bahamondes L, Bahamondes MV. Use of combined oral contraceptives for the management of heavy menstrual bleeding. Expert Review of Obstetrics and Gynecology. 2011;6(5):485-489.
Baillargeon JP, McClish DK, Essah PA, et al. Association between the current use of low-dose oral contraceptives and cardiovascular arterial disease: a meta-analysis. J Clin Endocrinol Metab. 2005;90(7):3863-70. [pmid: 15814774].
Bannemerschult R, Hanker JP, Wunsch C, et al. A multicenter, uncontrolled clinical investigation of the contraceptive efficacy, cycle control, and safety of a new low dose oral contraceptive containing 20 micrograms ethinyl estradiol and 100 micrograms levonorgestrel over six treatment cycles. Contraception. 1997;56(5):285-90. [pmid: 9437556].
Barbosa IC, Filho CI, Faggion D Jr, et al. Prospective, open-label, noncomparative study to assess cycle control, safety and acceptability of a new oral contraceptive containing gestodene 60 microg and ethinylestradiol 15 microg (Minesse). Contraception. 2006;73(1):30-3. [pmid: 16371291].
Barnes MN, Grizzle WE, Grubbs CJ, et al. Paradigms for primary prevention of ovarian carcinoma. CA Cancer J Clin. 2002;52(4):216-25. [pmid: 12139233].
Barnhart K, Mirkin S, Grubb G, et al. Return to fertility after cessation of a continuous oral contraceptive. Fertil Steril. 2009;91(5):1654-6. [pmid: 18462723].
Becker H. Supportive European data on a new oral contraceptive containing norgestimate. Acta Obstet Gynecol Scand Suppl. 1990;152:33-9. [pmid: 2189283].
Benagiano G, Primiero FM. Seventy-five microgram desogestrel minipill, a new perspective in estrogen-free contraception. Ann N Y Acad Sci. 2003;997:163-73. [pmid: 14644823].
Bergendal A, Odlind V, Persson I, et al. Limited knowledge on progestogen-only contraception and risk of venous thromboembolism. Acta Obstet Gynecol Scand. 2009;88(3):261-6. [pmid: 19172422].
Berlin JA, Longnecker MP, Greenland S. Meta-analysis of epidemiologic dose-response data. Epidemiology. 1993;4(3):218-28. [pmid: 8512986].
Bermejo-Perez MJ, Marquez-Calderon S, Llanos-Mendez A. Effectiveness of preventive interventions in BRCA1/2 gene mutation carriers: a systematic review. Int J Cancer. 2007;121(2):225-31. [pmid: 17471565].
Berrington A, Cox DR. Generalized least squares for the synthesis of correlated information. Biostatistics. 2003;4(3):423-31. [pmid: 12925509].
Bertram CC. Evidence for practice: oral contraception and risk of cervical cancer. J Am Acad Nurse Pract. 2004;16(10):455-61. [pmid: 15543923].
Black A, Francoeur D, Rowe T, et al. SOGC clinical practice guidelines: Canadian contraception consensus. J Obstet Gynaecol Can. 2004;26(3):219-96. [pmid: 15016334].
Blanco-Molina A, Rota LL, Di Micco P, et al. Venous thromboembolism during pregnancy, postpartum or during contraceptive use. Thromb Haemost. 2010;103(2):306-11. [pmid: 20126835].
Blickstein D, Blickstein I. Oral contraception and thrombophilia. Curr Opin Obstet Gynecol. 2007;19(4):370-6. [pmid: 17625421].
Blinkenberg EO, Kristoffersen AH, Sandberg S, et al. Usefulness of factor V Leiden mutation testing in clinical practice. Eur J Hum Genet. 2010;18(8):862-6. [pmid: 20332812].
Bosch FX, de Sanjose S. The epidemiology of human papillomavirus infection and cervical cancer. Dis Markers. 2007;23(4):213-27. [pmid: 17627057].
Bosetti C, Bravi F, Negri E, et al. Oral contraceptives and colorectal cancer risk: a systematic review and meta-analysis. Hum Reprod Update. 2009;15(5):489-98. [pmid: 19414526].
Bousser MG, Kittner SJ. Oral contraceptives and stroke. Cephalalgia. 2000;20(3):183-9. [pmid: 10997772].
Brady MS, Coit DG. Focal nodular hyperplasia of the liver. Surg Gynecol Obstet. 1990;171(5):377-81. [pmid: 2173158].
Bray F, Dos Santos, Silva I, Moller H, et al. Endometrial cancer incidence trends in Europe: underlying determinants and prospects for prevention. Cancer Epidemiol Biomarkers Prev. 2005;14(5):1132-42. [pmid: 15894663].
Brinton LA. Oral contraceptives and cervical neoplasia. Contraception. 1991;43(6):581-95. [pmid: 1868734].
Brown C, Ling F, Wan J. A new monophasic oral contraceptive containing drospirenone. Effect on premenstrual symptoms. J Reprod Med. 2002;47(1):14-22. [pmid: 11838304].
Brown DA, Vartan CM. Risk of venous thromboembolism with drospirenone-containing oral contraceptives. Am J Health Syst Pharm. 2011;68(11):1003-10. [pmid: 21593228].
Brynhildsen J, Ekblad S, Hammar M. Oral contraceptives and low back pain. Attitudes among physicians, midwives and physiotherapists. Acta Obstet Gynecol Scand. 1995;74(9):714-7. [pmid: 7572106].
Bulow Pedersen I, Laurberg P, Knudsen N, et al. Lack of association between thyroid autoantibodies and parity in a population study argues against microchimerism as a trigger of thyroid autoimmunity. Eur J Endocrinol. 2006;154(1):39-45. [pmid: 16381989].
Burke W, Daly M, Garber J, et al. Recommendations for follow-up care of individuals with an inherited predisposition to cancer. II. BRCA1 and BRCA2. Cancer Genetics Studies Consortium. JAMA. 1997;277(12):997-1003. [pmid: 9091675].
Buss L, Tolstrup J, Munk C, et al. Spontaneous abortion: a prospective cohort study of younger women from the general population in Denmark. Validation, occurrence and risk determinants. Acta Obstet Gynecol Scand. 2006;85(4):467-75. [pmid: 16612710].
Calhaz-Jorge C, Mol BW, Nunes J, et al. Clinical predictive factors for endometriosis in a Portuguese infertile population. Hum Reprod. 2004;19(9):2126-31. [pmid: 15229202].
Calhoun A. Combined hormonal contraceptives: Is it time to reassess their role in migraine?. Headache. 2012;52(4):648-660. [pmid: 22221001].
Callejo J, Diaz J, Ruiz A, et al. Effect of a low-dose oral contraceptive containing 20 microg ethinylestradiol and 150 microg desogestrel on dysmenorrhea. Contraception. 2003;68(3):183-8. [pmid: 14561538].
Canto-Cetina TE, Cetina-Manzanilla J. Oral contraceptives and autoimmune diseases. Current Women's Health Reviews. 2007;3(2):139-144.
Carolei A, Marini C, Ferranti E, et al. A prospective study of cerebral ischemia in the young Analysis of pathogenic determinants. The National Research Council Study Group. Stroke. 1993;24(3):362-7. [pmid: 8446970].
Carr BR, Ory H. Estrogen and progestin components of oral contraceptives: relationship to vascular disease. Contraception. 1997;55(5):267-72. [pmid: 9220222].
Castellsague X, Munoz N. Chapter 3: Cofactors in human papillomavirus carcinogenesis--role of parity, oral contraceptives, and tobacco smoking. J Natl Cancer Inst Monogr. 2003;(31):20-8. [pmid: 12807941].
Castle PE, Wacholder S, Lorincz AT, et al. Smoking, but not parity or OC use, increased the risk of high-grade cervical neoplasia in women infected with HPV. Evidence-based Obstetrics and Gynecology. 2003;5(2):92-93.
Cavalcanti SM, Deus FC, Zardo LG, et al. Human papillomavirus infection and cervical cancer in Brazil: a retrospective study. Mem Inst Oswaldo Cruz. 1996;91(4):433-40. [pmid: 9070405].
Chabbert-Buffet N, Amoura Z, Scarabin PY, et al. Pregnane progestin contraception in systemic lupus erythematosus: a longitudinal study of 187 patients. Contraception. 2011;83(3):229-37. [pmid: 21310284].
Chakhtoura Z, Canonico M, Gompel A, et al. Progestogen-Only Contraceptives and the Risk of Acute Myocardial Infarction: A Meta-Analysis. J Clin Endocrinol Metab. 2011;96(4):1169-74. [pmid: 21289250].
Chakhtoura Z, Canonico M, Gompel A, et al. Progestogen-only contraceptives and the risk of stroke: a meta-analysis. Stroke. 2009;40(4):1059-62. [pmid: 19211491].
Chan WS, Ray J, Wai EK, et al. Risk of stroke in women exposed to low-dose oral contraceptives: a critical evaluation of the evidence. Arch Intern Med. 2004;164(7):741-7. [pmid: 15078643].
Chasan-Taber L, Stampfer MJ. Epidemiology of oral contraceptives and cardiovascular disease. Ann Intern Med. 1998;128(6):467-77. [pmid: 9499331].
Chen PL, Zhou H, Dominik R. Estimating cycle pregnancy probability with incomplete data in contraceptive studies. J Biopharm Stat. 2003;13(3):507-17. [pmid: 12921397].
Chi C, Pollard D, Tuddenham EG, et al. Menorrhagia in adolescents with inherited bleeding disorders. J Pediatr Adolesc Gynecol. 2010;23(4):215-22. [pmid: 20471874].
Chilvers CE, Deacon JM. Oral contraceptives and breast cancer. Br J Cancer. 1990;61(1):1-4. [pmid: 2404506].
Chilvers CE, Pike MC, Taylor CN, et al. General practitioner notes as a source of information for case-control studies in young women. UK National Case-Control Study Group. J Epidemiol Community Health. 1994;48(1):92-7. [pmid: 8138777].
Christerson S, Stromberg B. Childhood stroke in Sweden I: incidence, symptoms, risk factors and short-term outcome. Acta Paediatr. 2010;99(11):1641-9. [pmid: 20586998].
Cibula D, Gompel A, Mueck AO, et al. Hormonal contraception and risk of cancer. Hum Reprod Update. 2010;16(6):631-50. [pmid: 20543200].
Cibula D, Zikan M, Dusek L, et al. Oral contraceptives and risk of ovarian and breast cancers in BRCA mutation carriers: a meta-analysis. Expert Rev Anticancer Ther. 2011;11(8):1197-207. [pmid: 21916573].
Claus EB, Black PM, Bondy ML, et al. Exogenous hormone use and meningioma risk: what do we tell our patients?. Cancer. 2007;110(3):471-6. [pmid: 17580362].
Colditz GA. The Nurses' Health Study: Findings during 10 years of follow-up of a cohort of U.S. women. Current Problems in Obstetrics, Gynecology and Fertility. 1990;13(4):135-140.
Cole JA, Norman H, Doherty M, et al. Venous thromboembolism, myocardial infarction, and stroke among transdermal contraceptive system users. Obstet Gynecol. 2007;109(2 Pt 1):339-46. [pmid: 17267834].
Conard J. Biological coagulation findings in third-generation oral contraceptives. Hum Reprod Update. 1999;5(6):672-80. [pmid: 10652977].
Costa HL, Doyle P. Influence of oral contraceptives in the development of post-molar trophoblastic neoplasia--a systematic review. Gynecol Oncol. 2006;100(3):579-85. [pmid: 16297971].
Coutinho EM, Spinola P, Tomaz G, et al. Efficacy, acceptability, and clinical effects of a low-dose injectable contraceptive combination of dihydroxyprogesterone acetophenide and estradiol enanthate. Contraception. 2000;61(4):277-80. [pmid: 10899484].
Cox M, Blacksell S. Clinical performance of the levonorgestrel intra-uterine system in routine use by the UK Family Planning and Reproductive Health Research Network: 12-month report. Br J Fam Plann. 2000;26(3):143-7. [pmid: 10920290].
Crane K. Oral contraceptives as ovarian cancer prevention. J Natl Cancer Inst. 2011;103(17):1286-8. [pmid: 21852259].
Creinin MD, Lisman R, Strickler RC. Screening for factor V Leiden mutation before prescribing combination oral contraceptives. Fertil Steril. 1999;72(4):646-51. [pmid: 10521103].
Cremer M, Phan-Weston S, Jacobs A. Recent innovations in oral contraception. Semin Reprod Med. 2010;28(2):140-6. [pmid: 20391327].
Cromer BA. Bone mineral density in adolescent and young adult women on injectable or oral contraception. Curr Opin Obstet Gynecol. 2003;15(5):353-7. [pmid: 14501237].
Culwell KR, Curtis KM, del Carmen Cravioto M. Safety of contraceptive method use among women with systemic lupus erythematosus: a systematic review. Obstet Gynecol. 2009;114(2 Pt 1):341-53. [pmid: 19622996].
Curtis KM, Chrisman CE, Peterson HB. Contraception for women in selected circumstances. Obstet Gynecol. 2002;99(6):1100-12. [pmid: 12052606].
Curtis KM, Mohllajee AP, Peterson HB. Use of combined oral contraceptives among women with migraine and nonmigrainous headaches: a systematic review. Contraception. 2006;73(2):189-94. [pmid: 16413849].
Curtis KM, Mohllajee AP, Martins SL, et al. Combined oral contraceptive use among women with hypertension: a systematic review. Contraception. 2006;73(2):179-88. [pmid: 16413848].
Curtis KM. Safety of implantable contraceptives for women: data from observational studies. Contraception. 2002;65(1):85-96. [pmid: 11861058].
D'Arcy PF. Follow up of mortality associated with oral contraceptives over 25 years. International Pharmacy Journal. 1999;13(2):45-46.
Darwish A, Labeeb S, Galal M, et al. Cervical changes associated with progestagen-only contraceptives: a team approach. Contraception. 2004;69(2):121-7. [pmid: 14759616].
Davidson AR, Kalmuss D, Cushman LF, et al. Injectable contraceptive discontinuation and subsequent unintended pregnancy among low-income women. Am J Public Health. 1997;87(9):1532-4. [pmid: 9314810].
Davis AR, Kroll R, Soltes B, et al. Occurrence of menses or pregnancy after cessation of a continuous oral contraceptive. Fertil Steril. 2008;89(5):1059-63. [pmid: 17658522].
Dawson DA. Trends in use of oral contraceptives--data from the 1987 National Health Interview Survey. Fam Plann Perspect. 1990;22(4):169-72. [pmid: 2226747].
de Araujo FF, Barbieri M, Guazzelli CA, et al. The T 380A intrauterine device: a retrospective 5-year evaluation. Contraception. 2008;78(6):474-8. [pmid: 19014793].
De Berardis D, Serroni N, Salerno RM, et al. Treatment of premenstrual dysphoric disorder (PMDD) with a novel formulation of drospirenone and ethinyl estradiol. Ther Clin Risk Manag. 2007;3(4):585-90. [pmid: 18472980].
de Jonge ET, Yigit R, Molenberghs G, et al. Predictors of oligoamenorrhea at 1-year follow-up in premenopausal women using a levonorgestrel-releasing intrauterine system. Contraception. 2007;76(2):91-5. [pmid: 17656176].
Delgado-Rodriguez M, Sillero-Arenas M, Rodriguez-Contreras R, et al. Oral contraceptives and breast cancer. A meta-analysis. Rev Epidemiol Sante Publique. 1991;39(2):165-81. [pmid: 1830968].
Dibble SL, Roberts SA, Robertson PA, et al. Risk factors for ovarian cancer: lesbian and heterosexual women. Oncol Nurs Forum. 2002;29(1):E1-7. [pmid: 11845216].
Diehl AK, Schwesinger WH, Holleman DR Jr, et al. Clinical correlates of gallstone composition: distinguishing pigment from cholesterol stones. Am J Gastroenterol. 1995;90(6):967-72. [pmid: 7771432].
Dietrich T, Garcia RI, de Pablo P, et al. The effects of cigarette smoking on C-reactive protein concentrations in men and women and its modification by exogenous oral hormones in women. Eur J Cardiovasc Prev Rehabil. 2007;14(5):694-700. [pmid: 17925630].
Dinger J. Oral contraceptives and venous thromboembolism: old questions revisited. J Fam Plann Reprod Health Care. 2009;35(4):211-3. [pmid: 19849911].
Dinger JC, Bardenheuer K, Assmann A. International Active Surveillance Study of Women Taking Oral Contraceptives (INAS-OC Study). BMC Med Res Methodol. 2009;9:77. [pmid: 19922634].
Dodick DW. Migraine as a risk factor for white matter lesions, silent infarctions, and ischemic stroke. Headache Currents. 2005;2(3):58-61.
dos Santos Silva I, Swerdlow AJ. Recent trends in incidence of and mortality from breast, ovarian and endometrial cancers in England and Wales and their relation to changing fertility and oral contraceptive use. Br J Cancer. 1995;72(2):485-92. [pmid: 7640237].
Dougherty PL. Menstrual suppression: benefits and risks of continuous combined oral contraceptives. Nurs Womens Health. 2008;12(3):243-8. [pmid: 18557855].
Douketis JD, Ginsberg JS, Holbrook A, et al. A reevaluation of the risk for venous thromboembolism with the use of oral contraceptives and hormone replacement therapy. Arch Intern Med. 1997;157(14):1522-30. [pmid: 9236553].
Drife J. Oral contraception and the risk of thromboembolism: what does it mean to clinicians and their patients?. Drug Saf. 2002;25(13):893-902. [pmid: 12381211].
Drife JO. Oral contraceptives and heavy periods. Obstetrics and Gynecology. 2011;117(4):773-774. [pmid: 21422845].
Duijkers I, Engels L, Klipping C. Length of the menstrual cycle after discontinuation of oral contraceptives. Gynecol Endocrinol. 2005;20(2):74-9. [pmid: 15823825].
Dumeaux V, Lund E, Hjartaker A. Use of oral contraceptives, alcohol, and risk for invasive breast cancer. Cancer Epidemiol Biomarkers Prev. 2004;13(8):1302-7. [pmid: 15298950].
Dunn MS, Manahan KJ, Geisler JP. Primary carcinoma of the fallopian tube and epithelial ovarian carcinoma: A case control analysis. Obstetrical and Gynecological Survey. 2009;64(1):26-27.
Dunn N. No increased risk of heart attack associated with oral contraceptives. Biomedicine and Pharmacotherapy. 2000;54(3):170.
Dunn NR, Arscott A, Thorogood M, et al. Case and control recruitment, and validation of cases for the MICA case-control study in England, Scotland and Wales. Pharmacoepidemiol Drug Saf. 1999;8(4):285-90. [pmid: 15073921].
Dunn NR, Thorogood M, de Caestecker L, et al. Myocardial infarction and oral contraceptives, a retrospective case control study in England and Scotland (‘MICA’ Study). Pharmacoepidemiol Drug Saf. 1997;6(4):283-9. [pmid: 15073780].
Duska LR, Garrett A, Rueda BR, et al. Endometrial cancer in women 40 years old or younger. Gynecol Oncol. 2001;83(2):388-93. [pmid: 11606102].
Edgren RA. Oral contraceptives and cancer. Int J Fertil. Suppl 3. 1991;36:37-50. [pmid: 1687403].
Elit L. Familial ovarian cancer. Can Fam Physician. 2001;47:778-84. [pmid: 11340759].
Engel NS. Update on cancer risk and oral contraceptives. MCN Am J Matern Child Nurs. 1990;15(1):37. [pmid: 2105427].
Ewertz M. Breast cancer in Denmark. Incidence, risk factors, and characteristics of survival. Acta Oncol. 1993;32(6):595-615. [pmid: 8260176].
Farhoudi M, Sharifipour E, Ayromlou H, et al. Does low dose contraceptive pills increase stroke rate? A cross sectional study in North-West Iran. Pakistan Journal of Medical Sciences. 2012;28(3):501-505.
Farley TM, Meirik O, Chang CL, et al. Combined oral contraceptives, smoking, and cardiovascular risk. J Epidemiol Community Health. 1998;52(12):775-85. [pmid: 10396518].
Farmer RD, Lawrenson RA. Oral contraceptives and venous thromboembolic disease: the findings from database studies in the United Kingdom and Germany. Am J Obstet Gynecol. 1998;179(3 Pt 2):S78-86. [pmid: 9753314].
Farmer RD, Lawrenson RA, Hambleton IR. Oral contraceptive switching patterns in the United Kingdom: an important potential confounding variable in studies of venous thromboembolism. Eur J Contracept Reprod Health Care. 1996;1(1):31-7. [pmid: 9678135].
Farmer RD, Lawrenson RA, Todd JC, et al. Oral contraceptives and venous thromboembolic disease. Analyses of the UK General Practice Research Database and the UK Mediplus database. Hum Reprod Update. 1999;5(6):688-706. [pmid: 10652979].
Farmer RD, Todd JC, Lewis MA, et al. The risks of venous thromboembolic disease among German women using oral contraceptives: a database study. Contraception. 1998;57(2):67-70. [pmid: 9589831].
Farrow A, Hull MGR, Northstone K, et al. Previous long-term oral contraceptive use did not result in delayed conception of planned pregnancy. Evidence-based Obstetrics and Gynecology. 2003;5(3):124-125.
Felcher AH, Mularski RA, Mosen DM, et al. Incidence and risk factors for venous thromboembolic disease in podiatric surgery. Chest. 2009;135(4):917-22. [pmid: 19017868].
Fernandez E, La Vecchia C, Balducci A, et al. Oral contraceptives and colorectal cancer risk: a meta-analysis. Br J Cancer. 2001;84(5):722-7. [pmid: 11237397].
Foidart JM, Sulak PJ, Schellschmidt I, et al. The use of an oral contraceptive containing ethinylestradiol and drospirenone in an extended regimen over 126 days. Contraception. 2006;73(1):34-40. [pmid: 16371292].
Foster RH, Wilde MI. Dienogest. Drugs. 1998;56(5):825-33. discussion 834-5. [pmid: 9829156].
Fowkes FG, Lee AJ, Evans CJ, et al. Lifestyle risk factors for lower limb venous reflux in the general population: Edinburgh Vein Study. Int J Epidemiol. 2001;30(4):846-52. [pmid: 11511615].
Franceschi S, La Vecchia C. Oral contraceptives and colorectal tumors. A review of epidemiologic studies. Contraception. 1998;58(6):335-43. [pmid: 10095969].
Franks AL, Beral V, Cates W Jr, et al. Contraception and ectopic pregnancy risk. Am J Obstet Gynecol. 1990;163(4 Pt 1):1120-3. [pmid: 2220914].
Freeman EW, Halbreich U, Grubb GS, et al. An overview of four studies of a continuous oral contraceptive (levonorgestrel 90 mcg/ethinyl estradiol 20 mcg) on premenstrual dysphoric disorder and premenstrual syndrome. Contraception. 2012;85(5):437-445. [pmid: 22152588].
Freeman EW. Evaluation of a unique oral contraceptive (Yasmin) in the management of premenstrual dysphoric disorder. Eur J Contracept Reprod Health Care. Suppl 3. 2002;7:27-34. discussion 42-3. [pmid: 12659404].
Funkhouser E, Waterbor JW, Cole P, et al. Mammographic patterns and breast cancer risk factors among women having elective screening. South Med J. 1993;86(2):177-80. [pmid: 8434288].
Furlong LA. Ectopic pregnancy risk when contraception fails. A review. J Reprod Med. 2002;47(11):881-5. [pmid: 12497674].
Gadducci A, Barsotti C, Cosio S, et al. Smoking habit, immune suppression, oral contraceptive use, and hormone replacement therapy use and cervical carcinogenesis: a review of the literature. Gynecol Endocrinol. 2011;27(8):597-604. [pmid: 21438669].
Gaffield ME, Culwell KR, Ravi A. Oral contraceptives and family history of breast cancer. Contraception. 2009;80(4):372-80. [pmid: 19751860].
Galarza M, Gazzeri R. Cerebral venous sinus thrombosis associated with oral contraceptives: the case for neurosurgery. Neurosurg Focus. 2009;27(5):E5. [pmid: 19877796].
Gallo MF, Grimes DA, Schulz KF. Skin patch and vaginal ring versus combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2003;(1):CD003552. [pmid: 12535478].
Gammon MD, Neugut AI, Santella RM, et al. The Long Island Breast Cancer Study Project: description of a multi-institutional collaboration to identify environmental risk factors for breast cancer. Breast Cancer Res Treat. 2002;74(3):235-54. [pmid: 12206514].
Gandini S, Iodice S, Koomen E, et al. Hormonal and reproductive factors in relation to melanoma in women: current review and meta-analysis. Eur J Cancer. 2011;47(17):2607-17. [pmid: 21620689].
Gartner V, Weber M, Eichinger S. The emotional impact of genetic testing and aspects of counseling prior to prescription of oral contraceptives. Contraception. 2008;78(5):392-8. [pmid: 18929736].
Garza-Flores J, Valles de Bourges V, Martinez M, et al. Safety and efficacy of a combined oral contraceptive: gestodene 75 micrograms plus ethinyl estradiol 30 micrograms in Mexican women. Adv Contracept. 1994;10(1):19-26. [pmid: 8030449].
Gay JW, Cardwell MS. Oral contraceptives and breast cancer. Mo Med. 1990;87(10):763-7. [pmid: 2259330].
Gehlert S, Song IH, Chang CH, et al. The prevalence of premenstrual dysphoric disorder in a randomly selected group of urban and rural women. Psychol Med. 2009;39(1):129-36. [pmid: 18366818].
Gemzell-Danielsson K, Inki P, Boubli L, et al. Bleeding pattern and safety of consecutive use of the levonorgestrel-releasing intrauterine system (LNG-IUS)--a multicentre prospective study. Hum Reprod. 2010;25(2):354-9. [pmid: 19955104].
Gerstman BB, Piper JM, Freiman JP, et al. Oral contraceptive oestrogen and progestin potencies and the incidence of deep venous thromboembolism. Int J Epidemiol. 1990;19(4):931-6. [pmid: 2084024].
Gerstman BB, Piper JM, Tomita DK, et al. Oral contraceptive estrogen dose and the risk of deep venous thromboembolic disease. Am J Epidemiol. 1991;133(1):32-7. [pmid: 1983896].
Gezginc K, Balci O, Karatayli R, et al. Contraceptive efficacy and side effects of Implanon. Eur J Contracept Reprod Health Care. 2007;12(4):362-5. [pmid: 17853166].
Ghandehari K, Shams M, Atalu A, et al. Oral contraceptive consumption and cerebral venous thrombosis in Mashhad, Iran. Internet Journal of Neurology. 2009;11(2).
Gigantes S. The use of exogenous hormones and the risk of thromboembolism in women. HAEMA. 2003;6(4):462-474.
Gillum LA, Mamidipudi SK, Johnston SC. Ischemic stroke risk with oral contraceptives: A meta-analysis. JAMA. 2000;284(1):72-8. [pmid: 10872016].
Gillum LA, Mamidipudi SK, Johnston SC. Review: Current oral contraceptive use increases the risk for ischaemic stroke. Evidence-Based Medicine. 2001;6(2):60.
Girolami A, Spiezia L, Girolami B, et al. Effect of age on oral contraceptive-induced venous thrombosis. Clin Appl Thromb Hemost. 2004;10(3):259-63. [pmid: 15247983].
Girolami A, Spiezia L, Girolami B, et al. Tentative guidelines and practical suggestions to avoid venous thromboembolism during oral contraceptive therapy. Clin Appl Thromb Hemost. 2002;8(2):97-102. [pmid: 12121063].
Glattre E, Nygard JF. Fractal meta-analysis and ‘causality’ embedded in complexity: advanced understanding of disease etiology. Nonlinear Dynamics Psychol Life Sci. 2004;8(3):315-44. [pmid: 15233878].
Godsland IF, Winkler U, Lidegaard O, et al. Occlusive vascular diseases in oral contraceptive users. Epidemiology, pathology and mechanisms. Drugs. 2000;60(4):721-869. [pmid: 11085198].
Golbs S, Domhardt R, Radowicky S, et al. Clinical findings with the oral contraceptive combination ethinylestradiol/dienogest in Poland. Methods Find Exp Clin Pharmacol. 2002;24(9):585-92. [pmid: 12616705].
Goldzieher JW. Thirty years of hormonal contraception: an historical perspective. Int J Fertil. Suppl 3. 1991;36:10-5. [pmid: 1687399].
Green A. Oral contraceptives and skin neoplasia. Contraception. 1991;43(6):653-66. [pmid: 1868736].
Grimes DA. Dispelling OC myths and misperceptions. Dialogues Contracept. 1994;4(3):1-4. [pmid: 12345574].
Grimes DA. Neoplastic effects of oral contraceptives. Int J Fertil. Suppl 1. 1991;36:19-24. [pmid: 1678377].
Grimes DA. The safety of oral contraceptives: epidemiologic insights from the first 30 years. Am J Obstet Gynecol. 1992;166(6 Pt 2):1950-4. [pmid: 1605284].
Gronwald J, Byrski T, Huzarski T, et al. A survey of preventive measures among BRCA1 mutation carriers from. Poland Clin Genet. 2007;71(2):153-7. [pmid: 17250664].
Gross TP, Schlesselman JJ. The estimated effect of oral contraceptive use on the cumulative risk of epithelial ovarian cancer. Obstet Gynecol. 1994;83(3):419-24. [pmid: 8127536].
Guerra-Tapia A, Sancho Perez B. Ethinylestradiol/Chlormadinone acetate: dermatological benefits. Am J Clin Dermatol. Suppl 1. 2011;12:3-11. [pmid: 21895044].
Guilbert E, Boroditsky R, Black A, et al. Canadian Consensus Guideline on Continuous and Extended Hormonal Contraception, 2007. J Obstet Gynaecol Can. 2007;29(7 Suppl 2):S1-32. [pmid: 17761109].
Gupta S. Weight gain on the combined pill--is it real?. Hum Reprod Update. 2000;6(5):427-31. [pmid: 11045873].
Hadji P, Biskup J, Boekhoff J, et al. Evaluation of efficacy, safety and effects on symptoms of androgenization of a generic oral contraceptive containing chlormadinone acetate 2 mg/ethinylestradiol 0.03 mg. Contraception. 2012. Mar. 23. [pmid: 22445436].
Hankinson SE, Colditz GA, Hunter DJ, et al. A quantitative assessment of oral contraceptive use and risk of ovarian cancer. Obstet Gynecol. 1992;80(4):708-14. [pmid: 1407899].
Hannaford PC, Owen-Smith V. Using epidemiological data to guide clinical practice: review of studies on cardiovascular disease and use of combined oral contraceptives. BMJ. 1998;316(7136):984-7. [pmid: 9550959].
Hannaford PC. Combined oral contraceptives: do we know all of their effects?. Contraception. 1995;51(6):325-7. [pmid: 7554970].
Hartard M, Kleinmond C, Kirchbichler A, et al. Age at first oral contraceptive use as a major determinant of vertebral bone mass in female endurance athletes. Bone. 2004;35(4):836-41. [pmid: 15454090].
Hartge P, Hayes R, Reding D, et al. Complex ovarian cysts in postmenopausal women are not associated with ovarian cancer risk factors: preliminary data from the prostate, lung, colon, and ovarian cancer screening trial. Am J Obstet Gynecol. 2000;183(5):1232-7. [pmid: 11084571].
Hassan J, Kulenthran A, Thum YS. The return of fertility after discontinuation of oral contraception in Malaysian women. Med J Malaysia. 1994;49(4):348-50. [pmid: 7674970].
Hawley W, Nuovo J, DeNeef CP, et al. Do oral contraceptive agents affect the risk of breast cancer? A meta-analysis of the case-control reports. J Am Board Fam Pract. 1993;6(2):123-35. [pmid: 8452064].
Hedenmalm K, Samuelsson E. Fatal venous thromboembolism associated with different combined oral contraceptives: a study of incidences and potential biases in spontaneous reporting. Drug Saf. 2005;28(10):907-16. [pmid: 16180940].
Hedenmalm K, Samuelsson E, Spigset O. Pulmonary embolism associated with combined oral contraceptives: reporting incidences and potential risk factors for a fatal outcome. Acta Obstet Gynecol Scand. 2004;83(6):576-85. [pmid: 15144341].
Heinemann LA, Dinger J. Safety of a new oral contraceptive containing drospirenone. Drug Saf. 2004;27(13):1001-18. [pmid: 15471507].
Heinemann LA, Garbe E, Farmer R, et al. Venous thromboembolism and oral contraceptive use: a methodological study of diagnostic suspicion and referral bias. Eur J Contracept Reprod Health Care. 2000;5(3):183-91. [pmid: 11131783].
Heinemann LA, Lewis MA, Assmann A, et al. Case-control studies on venous thromboembolism: bias due to design? A methodological study on venous thromboembolism and steroid hormone use. Contraception. 2002;65(3):207-14. [pmid: 11929642].
Heinemann LA, Lewis MA, Assmann A, et al. Could preferential prescribing and referral behaviour of physicians explain the elevated thrombosis risk found to be associated with third generation oral contraceptives?. Pharmacoepidemiol Drug Saf. 1996;5(5):285-94. [pmid: 15073814].
Heinemann LA, Thomas DB, Mohner M. Multicentre international liver tumour study protocol of the case-control study on hepatocellular cancer. Pharmacoepidemiol Drug Saf. 1996;5(3):173-86. [pmid: 15073834].
Heinemann LAJ, Garbe E, Sattar FA, et al. Third generation oral contraceptives and the risk of venous thrombo- embolism. Middle East Fertility Society Journal. 1998;3(1):29-42.
Helmerhorst FM, Bloemenkamp KW, Rosendaal FR, et al. Oral contraceptives and thrombotic disease: risk of venous thromboembolism. Thromb Haemost. 1997;78(1):327-33. [pmid: 9198174].
Hennessy S, Berlin JA, Kinman JL, et al. Risk of venous thromboembolism from oral contraceptives containing gestodene and desogestrel versus levonorgestrel: a meta-analysis and formal sensitivity analysis. Contraception. 2001;64(2):125-33. [pmid: 11704089].
Henningson M, Johansson U, Borg A, et al. CYP17 genotype is associated with short menstrual cycles, early oral contraceptive use and BRCA mutation status in young healthy women. Mol Hum Reprod. 2007;13(4):231-6. [pmid: 17307805].
Hidayet NM, Sharaf SA, Aref SR, et al. Correlates of age at natural menopause: a community-based study in Alexandria. East Mediterr Health J. 1999;5(2):307-19. [pmid: 10793807].
Hietala M, Sandberg T, Borg A, et al. Testosterone levels in relation to oral contraceptive use and the androgen receptor CAG and GGC length polymorphisms in healthy young women. Hum Reprod. 2007;22(1):83-91. [pmid: 16920725].
Hirvonen E, Allonen H, Anttila M, et al. Oral contraceptive containing natural estradiol for premenopausal women. Maturitas. 1995;21(1):27-32. [pmid: 7731379].
Hite RC, Bannemerschult R, Fox-Kuchenbecker P, et al. Large observational trial of a new low-dose oral contraceptive containing 20 micrograms ethinylestradiol and 100 micrograms levonorgestrel (Miranova) in Germany. Eur J Contracept Reprod Health Care. 1999;4(1):7-13. [pmid: 10367190].
Hollander D. Pill-related stroke risk is low, especially if users lack other risk factors. Family Planning Perspectives. 1997;29(2):95-96.
Hollander D. Third-generation pills may elevate risk of venous thromboembolism, slightly lower heart attack risk. Family Planning Perspectives. 1996;28(3):131-132.
Honore LH, Koch M, Brown LB. Comparison of oral contraceptive use in women with adenocarcinoma and squamous cell carcinoma of the uterine cervix. Gynecol Obstet Invest. 1991;32(2):98-101. [pmid: 1748331].
Hulman G, Trowbridge P, Taylor CN, et al. Oral contraceptive use and histopathology of cancerous breasts in young women. Members of the U.K. National Case-Control Study Group. J Pathol. 1992;167(4):407-11. [pmid: 1403359].
Iatrakis G, Iavazzo C, Zervoudis S, et al. The role of oral contraception use in the occurrence of breast cancer. A retrospective study of 405 patients. Clin Exp Obstet Gynecol. 2011;38(3):225-7. [pmid: 21995151].
Inoue M, Sawada N, Matsuda T, et al. Attributable causes of cancer in Japan in 2005-Systematic assessment to estimate current burden of cancer attributable to known preventable risk factors in Japan. Annals of Oncology. 2012;23(5):1362-1369. [pmid: 22048150].
Iodice S, Barile M, Rotmensz N, et al. Oral contraceptive use and breast or ovarian cancer risk in BRCA1/2 carriers: a meta-analysis. Eur J Cancer. 2010;46(12):2275-84. [pmid: 20537530].
Ismail MT. A prospective study of a monophasic oral contraceptive containing 30 mcg ethinyl oestradiol and 150 mcg desogestrel (Marvelon). Malays J Reprod Health. 1994;12(1):43-8. [pmid: 12320338].
Janssen AWM, De Leeuw FE, Janssen MCH. Risk factors for ischemic stroke and transient ischemic attack in patients under age 50. Journal of Thrombosis and Thrombolysis. 2011;31(1):85-91. [pmid: 20532956].
Jemec GB, Linneberg A, Nielsen NH, et al. Have oral contraceptives reduced the prevalence of acne? a population-based study of acne vulgaris, tobacco smoking and oral contraceptives. Dermatology. 2002;204(3):179-84. [pmid: 12037444].
Jenkins MA, Dharmage SC, Flander LB, et al. Parity and decreased use of oral contraceptives as predictors of asthma in young women. Clin Exp Allergy. 2006;36(5):609-13. [pmid: 16650045].
Jensen JT. Evaluation of a new estradiol oral contraceptive: estradiol valerate and dienogest. Expert Opin Pharmacother. 2010;11(7):1147-57. [pmid: 20367275].
Jeune B, Wielandt H. Prevalence of smoking and oral contraception in a sample of Danish young women. Scand J Soc Med. 1991;19(1):44-6. [pmid: 1925426].
Jick SS, Jick H. Cerebral venous sinus thrombosis in users of four hormonal contraceptives: levonorgestrel-containing oral contraceptives, norgestimate-containing oral contraceptives, desogestrel-containing oral contraceptives and the contraceptive patch. Contraception. 2006;74(4):290-2. [pmid: 16982227].
Jick SS, Jick H. The contraceptive patch in relation to ischemic stroke and acute myocardial infarction. Pharmacotherapy. 2007;27(2):218-20. [pmid: 17253912].
Johnston SC, Colford JM Jr, Gress DR. Oral contraceptives and the risk of subarachnoid hemorrhage: a meta-analysis. Neurology. 1998;51(2):411-8. [pmid: 9710012].
Kahlenborn C, Modugno F, Potter DM, et al. Oral contraceptive use as a risk factor for premenopausal breast cancer: a meta-analysis. Mayo Clin Proc. 2006;81(10):1290-302. [pmid: 17036554].
Kalev M, Day T, Van de Water N, et al. Screening for a prothrombotic diathesis in patients attending family planning clinics. N Z Med J. 1999;112(1096):358-61. [pmid: 10587055].
Kapiga SH, Shao JF, Lwihula GK, et al. Risk factors for HIV infection among women in Dar-es-Salaam, Tanzania. J Acquir Immune Defic Syndr. 1994;7(3):301-9. [pmid: 8106970].
Kaplan B, Rabinerson DR, Levavi H, et al. Contraceptive methods and premalignant changes of the cervix. Cervix and the Lower Female Genital Tract. 1995;13(3):95-98.
Kaplan B. Desogestrel, norgestimate, and gestodene: the newer progestins. Ann Pharmacother. 1995;29(7-8):736-42. [pmid: 8520092].
Karsay K. The relationship between vascular headaches and low-dose oral contraceptives. Ther Hung. 1990;38(4):181-5. [pmid: 2094059].
Kasule J, Mbizvo M, Makuyana D, et al. Evaluation of a combined oral contraceptive pill in black Zimbabwean women. Cent Afr J Med. 1991;37(12):403-9. [pmid: 1806254].
Kaunitz AM. Depot medroxyprogesterone acetate contraception and the risk of breast and gynecologic cancer. J Reprod Med. 1996;41(5 Suppl):419-27. [pmid: 8725705].
Kawachi I, Colditz GA, Hankinson S. Long-term benefits and risks of alternative methods of fertility control in the United States. Contraception. 1994;50(1):1-16. [pmid: 7924318].
Keam SJ, Wagstaff AJ. Ethinylestradiol/drospirenone: a review of its use as an oral contraceptive. Treat Endocrinol. 2003;2(1):49-70. [pmid: 15871554].
Kelman L. Women's issues of migraine in tertiary care. Headache. 2004;44(1):2-7. [pmid: 14979877].
Kemmeren JM, Algra A, Grobbee DE. Third generation oral contraceptives and risk of venous thrombosis: meta-analysis. BMJ. 2001;323(7305):131-4. [pmid: 11463678].
Khader YS, Rice J, John L, et al. Oral contraceptives use and the risk of myocardial infarction: a meta-analysis. Contraception. 2003;68(1):11-7. [pmid: 12878281].
Khoo SK, Chick P. Sex steroid hormones and breast cancer: is there a link with oral contraceptives and hormone replacement therapy?. Med J Aust. 1992;156(2):124-32. [pmid: 1736053].
Klitsch M. New generation of progestins may raise oral contraceptive users' risk of blood clots. Family Planning Perspectives. 1996;28(1):33-35.
Kluft C. Renewed interest in haemostasis changes induced by oral contraceptives (OCs). Thromb Haemost. 2000;84(1):1-3. [pmid: 10928460].
Koetsawang S, Ji G, Krishna U, et al. Microdose intravaginal levonorgestrel contraception: a multicentre clinical trial. I. Contraceptive efficacy and side effects. World Health Organization. Task Force on Long-Acting Systemic Agents for Fertility Regulation. Contraception. 1990;41(2):105-24. [pmid: 2107054].
Koetsawang S, Ji G, Krishna U, et al. Microdose intravaginal levonorgestrel contraception: a multicentre clinical trial. IV. Bleeding patterns. World Health Organization. Task Force on Long-Acting Systemic Agents for Fertility Regulation. Contraception. 1990;41(2):151-67. [pmid: 2107057].
Koh SC, Singh K. Levonorgestrel-intrauterine system effects on hemostasis and menstrual blood loss in women seeking contraception. J Obstet Gynaecol Res. 2010;36(4):838-44. [pmid: 20666954].
Kost A, Pitney C. Tranexamic acid (Lysteda) for cyclic heavy menstrual bleeding. American Family Physician. 2011;84(8):883-886.
Koster T, Small RA, Rosendaal FR, et al. Oral contraceptives and venous thromboembolism: a quantitative discussion of the uncertainties. J Intern Med. 1995;238(1):31-7. [pmid: 7608644].
Kroll R, Reape KZ, Margolis M. The efficacy and safety of a low-dose, 91-day, extended-regimen oral contraceptive with continuous ethinyl estradiol. Contraception. 2010;81(1):41-8. [pmid: 20004272].
Kruse C, Seyer-Hansen M, Forman A. Diagnosis and treatment of rectovaginal endometriosis: An overview. Acta Obstetricia et. Gynecologica Scandinavica. 2012;91(6):648-657.
Kwon JS, Lu KH. Cost-effectiveness analysis of endometrial cancer prevention strategies for obese women. Obstet Gynecol. 2008;112(1):56-63. [pmid: 18591308].
La Vecchia C, Franceschi S. Reproductive factors and colorectal cancer. Cancer Causes Control. 1991;2(3):193-200. [pmid: 1873449].
La Vecchia C, Tavani A. Female hormones and benign liver tumours. Dig Liver Dis. 2006;38(8):535-6. [pmid: 16753350].
La Vecchia C, Tavani A, Franceschi S, et al. Oral contraceptives and cancer. A review of the evidence. Drug Saf. 1996;14(4):260-72. [pmid: 8713694].
La Vecchia C. Oral contraceptives and ovarian cancer: an update, 1998-2004. Eur J Cancer Prev. 2006;15(2):117-24. [pmid: 16523008].
La Vecchia C. Sex hormones and cardiovascular risk. Hum Reprod. 1992;7(2):162-7. [pmid: 1577926].
Lawoyin JO, Lawoyin DO, Arowojolu MO, et al. Prevalence of pregnancy related oral granuloma in a Nigerian population group and the possible role of contraceptives. Afr J Med Med Sci. 2003;32(4):409-12. [pmid: 15259928].
Lawrenson R, Farmer R. Venous thromboembolism and combined oral contraceptives: does the type of progestogen make a difference?. Contraception. 2000;62(2 Suppl):21S-28S. discussion 37S-38S. [pmid: 11102599].
Lea CS, Gordon NP, Prebil LA, et al. Differences in reproductive risk factors for breast cancer in middle-aged women in Marin County, California and a sociodemographically similar area of Northern California. BMC Women's Health. 2009;9:6. [pmid: 19320996].
Lech MM, Ostrowska L. Oral contraceptives use and weight gain in women with a Central European life-style. Eur J Contracept Reprod Health Care. 2005;10(1):59-65. [pmid: 16036300].
Lee AJ, Evans CJ, Hau CM, et al. Pregnancy, oral contraception, hormone replacement therapy and the occurrence of varicose veins: Edinburgh vein study. Phlebology. 1999;14(3):111-117.
Lidegaard O. Oral contraception and cerebral thromboembolism. Acta Obstet Gynecol Scand Suppl. 1997;164:66-8. [pmid: 9225642].
Lidegaard O. The influence of thrombotic risk factors when oral contraceptives are prescribed. A control-only study. Acta Obstet Gynecol Scand. 1997;76(3):252-60. [pmid: 9093141].
Lip GY, Beevers M, Beevers DG. Malignant hypertension in young women is related to previous hypertension in pregnancy, not oral contraception. QJM. 1997;90(9):571-5. [pmid: 9349449].
Lippman J. Long-term profile of a new progestin. Int J Fertil. Suppl 4. 1992;37:218-22. [pmid: 1362189].
Lippman JS, Shangold GA. A review of post-marketing safety and surveillance data for oral contraceptives containing norgestimate and ethinyl estradiol. Int J Fertil Womens Med. 1997;42(4):230-9. [pmid: 9309456].
Liu HS, Kho BC, Chan JC, et al. Venous thromboembolism in the Chinese population--experience in a regional hospital in Hong Kong. Hong Kong Med J. 2002;8(6):400-5. [pmid: 12459595].
London RS, Chapdelaine A, Upmalis D, et al. Comparative contraceptive efficacy and mechanism of action of the norgestimate-containing triphasic oral contraceptive. Acta Obstet Gynecol Scand Suppl. 1992;156:9-14. [pmid: 1324557].
Lopez Laureen M, Chen M, Curtis Kathryn M, et al. Steroidal contraceptives and bone fractures in women: evidence from observational studies. Cochrane Database Syst Rev. 2012;(5):CD009849. [pmid: 22895991].
Lopez LM, Grimes DA, Gallo MF, et al. Skin patch and vaginal ring versus combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2008;(1):CD003552. [pmid: 18254023].
Lopez LM, Grimes DA, Gallo MF, et al. Skin patch and vaginal ring versus combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2010;(3):CD003552. [pmid: 20238323].
Lopez LM, Kaptein A, Helmerhorst FM. Oral contraceptives containing drospirenone for premenstrual syndrome. Cochrane Database Syst Rev. 2008;(1):CD006586. [pmid: 18254106].
Lopez LM, Kaptein AA, Helmerhorst FM. Oral contraceptives containing drospirenone for premenstrual syndrome. Cochrane Database Syst Rev. 2009;(2):CD006586. [pmid: 19370644].
Lucas R, Azevedo A, Barros H. Self-reported data on reproductive variables were reliable among postmenopausal women. J Clin Epidemiol. 2008;61(9):945-50. [pmid: 18468857].
Lumachi F, Ermani M, Marino F, et al. Relationship between oral contraceptive therapy and estrogen receptor status in patients with breast cancer. Anticancer Res. 2008;28(1B):491-3. [pmid: 18383890].
Lund E. Oral contraceptives and breast cancer. A review with some comments on mathematical models. Acta Oncol. 1992;31(2):183-6. [pmid: 1622632].
Lundberg V, Asplund K, Evrin PE, et al. Oral contraceptives and oestrogen replacement therapy as determinants of plasma fibrinogen level and fibrinolytic activity: The Northern Sweden MONICA Study. Fibrinolysis and Proteolysis. 1998;12(6):328-334.
Luxembourg B, Schmitt J, Humpich M, et al. Intrinsic clotting factors in dependency of age, sex, body mass index, and oral contraceptives: Definition and risk of elevated clotting factor levels. Blood Coagulation and Fibrinolysis. 2009;20(7):524-534. [pmid: 19620844].
MacDonald DJ, Sarna L, Uman GC, et al. Cancer screening and risk-reducing behaviors of women seeking genetic cancer risk assessment for breast and ovarian cancers. Oncol Nurs Forum. 2006;33(2):E27-35. [pmid: 16518435].
MacGregor EA, Igarashi H, Wilkinson M. Headaches and hormones: Subjective versus objective assessment. Headache Quarterly. 1997;8(2):126-136.
Machado RB, Fabrini P, Cruz AM, et al. Clinical and metabolic aspects of the continuous use of a contraceptive association of ethinyl estradiol (30 microg) and gestodene (75 microg). Contraception. 2004;70(5):365-70. [pmid: 15504374].
Maheshwari S, Sarraj A, Kramer J, et al. Oral contraception and the risk of hepatocellular carcinoma. J Hepatol. 2007;47(4):506-13. [pmid: 17462781].
Mant JW, Vessey MP. Trends in mortality from primary liver cancer in England and Wales 1975-92: influence of oral contraceptives. Br J Cancer. 1995;72(3):800-3. [pmid: 7669599].
Manzoli L, De Vito C, Marzuillo C, et al. Oral contraceptives and venous thromboembolism: a systematic review and meta-analysis. Drug Saf. 2012;35(3):191-205. [pmid: 22283630].
Marks M, Gravitt PE, Gupta SB, et al. The association of hormonal contraceptive use and HPV prevalence. Int J Cancer. 2010. Oct. 26. [pmid: 20734390].
Marquez De, Souza R, Rech Lazzaron A, Kaplan KC, et al. Oral contraceptives and hereditary ovarian cancer [1] (multiple letters). New England Journal of Medicine. 1999;340(1):59-60. [pmid: 9882211].
Martinelli I, Battaglioli T, Mannucci PM, et al. Combined Estrogen-Progestin Oral Contraceptives [5] (multiple letters). New England Journal of Medicine. 2004;350(3):307-308. [pmid: 14724315].
Martinez F, Ramirez I, Perez-Campos E, et al. Venous and pulmonary thromboembolism and combined hormonal contraceptives. Systematic review and meta-analysis. Eur J Contracept Reprod Health Care. 2012;17(1):7-29. [pmid: 22239262].
Martin-Johnston MK, Okoji OY, Armstrong A. Therapeutic amenorrhea in patients at risk for thrombocytopenia. Obstet Gynecol Surv. 2008;63(6):395-402. quiz 405. [pmid: 18492296].
Mathieu D, Kobeiter H, Maison P, et al. Oral contraceptive use and focal nodular hyperplasia of the liver. Gastroenterology. 2000;118(3):560-4. [pmid: 10702207].
Matsumoto Y, Yamabe S, Ideta K, et al. Impact of use of combined oral contraceptive pill on the quality of life of Japanese women. J Obstet Gynaecol Res. 2007;33(4):529-35. [pmid: 17688623].
McAlindon T, Giannotta L, Taub N, et al. Environmental factors predicting nephritis in systemic lupus erythematosus. Ann Rheum Dis. 1993;52(10):720-4. [pmid: 8257208].
McNaught J, Reid RL, Provencher DM, et al. Progesterone-only and non-hormonal contraception in the breast cancer survivor: Joint Review and Committee Opinion of the Society of Obstetricians and Gynaecologists of Canada and the Society of Gynecologic Oncologists of Canada. J Obstet Gynaecol Can. 2006;28(7):616-39. [pmid: 16924781].
Melvin L. Cancer risk among users of oral contraceptives: Cohort data from the Royal College of General Practitioners' oral contraception study. Journal of Family Planning and Reproductive Health Care. 2008;34(1):18.
Milne R, Vessey M. The association of oral contraception with kidney cancer, colon cancer, gallbladder cancer (including extrahepatic bile duct cancer) and pituitary tumours. Contraception. 1991;43(6):667-93. [pmid: 1868737].
Moghissi KS. Add-back therapy in the treatment of endometriosis: the North American experience. Br J Obstet Gynaecol. Suppl 14. 1996;103:14. [pmid: 8916981].
Mohllajee AP, Curtis KM, Martins SL, et al. Does use of hormonal contraceptives among women with thrombogenic mutations increase their risk of venous thromboembolism? A systematic review. Contraception. 2006;73(2):166-78. [pmid: 16413847].
Mok CC, Lau CS, Wong RW. Use of exogenous estrogens in systemic lupus erythematosus. Semin Arthritis Rheum. 2001;30(6):426-35. [pmid: 11404826].
Molsted-Pedersen L, Skouby SO, Damm P. Preconception counseling and contraception after gestational diabetes. Diabetes. Suppl 2. 1991;40:147-50. [pmid: 1748246].
Moodley J. Combined oral contraceptives and cervical cancer. Curr Opin Obstet Gynecol. 2004;16(1):27-9. [pmid: 15128004].
Moodley M, Lindeque G, Connolly C. Human papillomavirus (HPV)-type distribution in relation to oral contraceptive use in women with cervical intraepithelial neoplasia, Durban, South Africa. Eur J Gynaecol Oncol. 2010;31(3):278-83. [pmid: 21077468].
Moreno V, Bosch FX, Munoz N, et al. Long-term oral contraceptive use increased the risk of cervical cancer in HPV-positive women. Evidence-based Obstetrics and Gynecology. 2002;4(4):205-206.
Mueck AO, Seeger H, Rabe T. Hormonal contraception and risk of endometrial cancer: a systematic review. Endocr Relat Cancer. 2010;17(4):R263-71. [pmid: 20870686].
Mueller L. Predictability of exogenous hormone effect on subgroups of migraineurs. Headache. 2000;40(3):189-93. [pmid: 10759920].
Munoz MT, Morande G, Garcia-Centenera JA, et al. The effects of estrogen administration on bone mineral density in adolescents with anorexia nervosa. Eur J Endocrinol. 2002;146(1):45-50. [pmid: 11751066].
Muram D, Gale CL, Thompson E. Functional ovarian cysts in patients cured of ovarian neoplasms. Obstet Gynecol. 1990;75(4):680-3. [pmid: 2314787].
Nappi RE, Sances G, Allais G, et al. Effects of an estrogen-free, desogestrel-containing oral contraceptive in women with migraine with aura: a prospective diary-based pilot study. Contraception. 2011;83(3):223-8. [pmid: 21310283].
Narayan D, Kaul S, Ravishankar K, et al. Risk factors, clinical profile, and long-term outcome of 428 patients of cerebral sinus venous thrombosis: Insights from Nizams Institute Venous Stroke Registry, Hyderabad (India). Neurology India. 2012;60(2):154-159. [pmid: 22626695].
Nessa A, Latif SA, Uddin MM, et al. Serum HDL-cholesterol in women using low dose oral contraceptives. Mymensingh Med J. 2007;16(2 Suppl):S3-6. [pmid: 17917628].
Newell A, Sullivan A, Halai R, et al. Sexually transmitted diseases, cervical cytology and contraception in immigrants and refugees from the former Yugoslavia. Venereology. 1998;11(1):25-7. [pmid: 12321821].
Ninger L. Low- and high-dose pills are equally protective against ovarian cancer. Family Planning Perspectives. 2000;32(6):311-312.
Notelovitz M, Levenson I, McKenzie L, et al. The effect of low-dose oral contraceptives on lipids and lipoproteins in two at-risk populations: young female smokers and older premenopausal women. Contraception. 1991;44(5):505-16. [pmid: 1797465].
Oberstein EM, Fleming LE, Gomez-Marin O, et al. Pulmonary lymphangioleiomyomatosis (LAM): examining oral contraceptive pills and the onset of disease. J Womens Health (Larchmt). 2003;12(1):81-5. [pmid: 12639372].
Oldfield K, Milne R, Vessey M. The effects on mortality of the use of combined oral contraceptives. Br J Fam Plann. 1998;24(1):2-6. [pmid: 9719700].
Olsen MR, Love RR. Hormonal strategies for the prevention of breast cancer. Cancer Treat Res. 1998;94:135-57. [pmid: 9587686].
Ory HW. Epidemiology of venous thromboembolic disease and OC use. Dialogues Contracept. 1996;5(1):4-7. 10. [pmid: 12347722].
Ostensen M, Rugelsjoen A, Wigers SH. The effect of reproductive events and alterations of sex hormone levels on the symptoms of fibromyalgia. Scand J Rheumatol. 1997;26(5):355-60. [pmid: 9385346].
Osterlind A. Hormonal and reproductive factors in melanoma risk. Clin Dermatol. 1992;10(1):75-8. [pmid: 1504931].
Otero UB, Chor D, Carvalho MS, et al. Lack of association between age at menarche and age at menopause: Pro-Saude Study, Rio de Janeiro. Brazil Maturitas. 2010;67(3):245-50. [pmid: 20719438].
Palareti G, Legnani C, Frascaro M, et al. Screening for activated protein C resistance before oral contraceptive treatment: a pilot study. Contraception. 1999;59(5):293-9. [pmid: 10494482].
Parahuleva MS, Holschermann H, Erdogan A, et al. Factor seven ativating potease (FSAP) levels during normal pregnancy and in women using oral contraceptives. Thromb Res. 2010;126(1):e36-40. [pmid: 20381831].
Park HJ, Koo YA, Yoon BK, et al. Postoperative long-term maintenance therapy with oral contraceptives after gonadotropin-releasing hormone analog treatment in women with ovarian endometrioma. J Minim Invasive Gynecol. 2009;16(1):34-9. [pmid: 18976968].
Parkes A, Wight D, Henderson M, et al. Contraceptive method at first sexual intercourse and subsequent pregnancy risk: findings from a secondary analysis of 16-year-old girls from the RIPPLE and SHARE studies. J Adolesc Health. 2009;44(1):55-63. [pmid: 19101459].
Parkin L, Skegg DC, Wilson M, et al. Oral contraceptives and fatal pulmonary embolism. Lancet. 2000;355(9221):2133-4. [pmid: 10902629].
Pasanisi P, Hedelin G, Berrino J, et al. Oral contraceptive use and BRCA penetrance: a case-only study. Cancer Epidemiol Biomarkers Prev. 2009;18(7):2107-13. [pmid: 19549808].
Pastor Climente IP, Morales Suarez Varela MM, Magraner Gil JF, et al. Gynecological characteristics related to breast cancer in pre and postmenopausal women. Clin Transl Oncol. 2006;8(6):416-22. [pmid: 16790394].
Persson I, Bergstrom R, Sparen P, et al. Trends in breast cancer incidence in Sweden 1958-1988 by time period and birth cohort. Br J Cancer. 1993;68(6):1247-53. [pmid: 8260381].
Persson I, Schmidt M, Adami HO, et al. Trends in endometrial cancer incidence and mortality in Sweden, 1960-84. Cancer Causes Control. 1990;1(3):201-8. [pmid: 2102292].
Petersen KR, Skouby SO, Jespersen J. Contraception guidance in women with pre-existing disturbances in carbohydrate metabolism. Eur J Contracept Reprod Health Care. 1996;1(1):53-9. [pmid: 9678138].
Petitti DB, Porterfield D. Worldwide variations in the lifetime probability of reproductive cancer in women: implications of best-case, worst-case, and likely-case assumptions about the effect of oral contraceptive use. Contraception. 1992;45(2):93-104. [pmid: 1559340].
Petitti DB, Sidney S, Quesenberry CP Jr, et al. Incidence of stroke and myocardial infarction in women of reproductive age. Stroke. 1997;28(2):280-3. [pmid: 9040675].
Phillips MCL, Leyden JM, Chong WK, et al. Ischaemic stroke among young people aged 15 to 50 years in Adelaide, South Australia. Medical Journal of Australia. 2011;195(10):610-614. [pmid: 22107013].
Pike MC, Spicer DV. Hormonal contraception and chemoprevention of female cancers. Endocr Relat Cancer. 2000;7(2):73-83. [pmid: 10903525].
Poindexter AN, Burkman R, Fisher AC, et al. Cycle control, tolerability, and satisfaction among women switching from 30-35 microg ethinyl estradiol-containing oral contraceptives to the triphasic norgestimate/25 microg ethinyl estradiol-containing oral contraceptive Ortho Tri-Cyclen LO. Int J Fertil Womens Med. 2003;48(4):163-72. [pmid: 13677549].
Pollara T, Kelsberg G, Safranek S, et al. Clinical inquiries. What is the risk of adverse outcomes in a woman who develops mild hypertension from OCs?. J Fam Pract. 2006;55(11):986-8. [pmid: 17090360].
Porras C, Bennett C, Safaeian M, et al. Determinants of seropositivity among HPV-16/18 DNA positive young women. BMC Infect Dis. 2010;10:238. [pmid: 20698998].
Poulter NR, Chang CL, Farley TM, et al. Reliability of data from proxy respondents in an international case-control study of cardiovascular disease and oral contraceptives World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. J Epidemiol Community Health. 1996;50(6):674-80. [pmid: 9039388].
Prasad RN, Koh SC, Viegas OA, et al. Effects on hemostasis after two-year use of low dose combined oral contraceptives with gestodene or levonorgestrel. Clin Appl Thromb Hemost. 1999;5(1):60-70. [pmid: 10725985].
Prentice A. Commentary: promising results but wider recruitment needed. BMJ. 1998;316(7138):1126. [pmid: 9569415].
Prentice RL. Epidemiologic data on exogenous hormones and hepatocellular carcinoma and selected other cancers. Prev Med. 1991;20(1):38-46. [pmid: 1848935].
Price DT, Ridker PM. Factor V Leiden mutation and the risks for thromboembolic disease: a clinical perspective. Ann Intern Med. 1997;127(10):895-903. [pmid: 9382368].
Psychos DN, Voulgari PV, Skopouli FN, et al. Erythema nodosum: the underlying conditions. Clin Rheumatol. 2000;19(3):212-6. [pmid: 10870657].
Purdie DM. Risk of invasive epithelial ovarian neoplasia declined with each year of hormonal contraceptive use. Evidence-based Obstetrics and Gynecology. 2005;7(2):96-97.
Rajani R, Melin T, Bjornsson E, et al. Budd-Chiari syndrome in Sweden: epidemiology, clinical characteristics and survival - an 18-year experience. Liver Int. 2009;29(2):253-9. [pmid: 18694401].
Ranstam J, Olsson H, Garne JP, et al. Survival in breast cancer and age at start of oral contraceptive usage. Anticancer Res. 1991;11(6):2043-6. [pmid: 1776838].
Rapkin A. A review of treatment of premenstrual syndrome and premenstrual dysphoric disorder. Psychoneuroendocrinology. Suppl 3. 2003;28:39-53. [pmid: 12892989].
Reid R, Leyland N, Wolfman W, et al. Oral contraceptives and the risk of venous thromboembolism: an update. J Obstet Gynaecol Can. 2010;32(12):1192-7. [pmid: 21176332].
Reid R, Leyland N, Wolfman W, et al. SOGC clinical practice guidelines: Oral contraceptives and the risk of venous thromboembolism: an update: no. 252 December 2010. Int J Gynaecol Obstet. 2011;112(3):252-6. [pmid: 21416656].
Reid RL. Oral contraceptives and venous thromboembolism: pill scares and public health. J Obstet Gynaecol Can. 2011;33(11):1150-5. [pmid: 22082790].
Remez L. Risk of breast cancer is not significantly elevated among women who have ever relied on the pill. Family Planning Perspectives. 1991;23(2):93-94.
Remez L. Slightly increased risk of breast cancer among pill users disappears 10 years after discontinuation. Family Planning Perspectives. 1997;29(3):147-148.
Remorgida V, Abbamonte LH, Ragni N, et al. Letrozole and desogestrel-only contraceptive pill for the treatment of stage IV endometriosis. Aust N Z J Obstet Gynaecol. 2007;47(3):222-5. [pmid: 17550490].
Renier M, Buytaert P. Open prospective multicenter trial with a new monophasic contraceptive combination containing gestodene. Contraception. 1991;43(5):413-21. [pmid: 1914456].
Rintelen C, Mannhalter C, Ireland H, et al. Oral contraceptives enhance the risk of clinical manifestation of venous thrombosis at a young age in females homozygous for factor V Leiden. Br J Haematol. 1996;93(2):487-90. [pmid: 8639453].
Robinson JC, Plichta S, Weisman CS, et al. Dysmenorrhea and use of oral contraceptives in adolescent women attending a family planning clinic. Am J Obstet Gynecol. 1992;166(2):578-83. [pmid: 1536234].
Rodger MA, Kahn SR, Wells PS, et al. Identifying unprovoked thromboembolism patients at low risk for recurrence who can discontinue anticoagulant therapy. CMAJ. 2008;179(5):417-26. [pmid: 18725614].
Roederer MW, Blackwell JC. FPIN's Clinical inquiries. Risks and benefits of combination contraceptives. Am Fam Physician. 2006;74(11):1915-6. [pmid: 17168349].
Roig S, Gomez JA, Fiol M, et al. Spontaneous coronary artery dissection causing acute coronary syndrome: an early diagnosis implies a good prognosis. Am J Emerg Med. 2003;21(7):549-51. [pmid: 14655234].
Romero A, Alonso C, Rincon M, et al. Risk of venous thromboembolic disease in women A qualitative systematic review. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):8-17. [pmid: 15950363].
Romieu I, Berlin JA, Colditz G. Oral contraceptives and breast cancer. Review and meta-analysis. Cancer. 1990;66(11):2253-63. [pmid: 2147122].
Rose PG, Reale FR, Longcope C, et al. Prognostic significance of estrogen and progesterone receptors in epithelial ovarian cancer. Obstet Gynecol. 1990;76(2):258-63. [pmid: 2371031].
Rosenberg L, Palmer JR, Sands MI, et al. Modern oral contraceptives and cardiovascular disease. Am J Obstet Gynecol. 1997;177(3):707-15. [pmid: 9322646].
Rosenberg L. The risk of liver neoplasia in relation to combined oral contraceptive use. Contraception. 1991;43(6):643-52. [pmid: 1651205].
Rosenberg MJ, Waugh MS. Oral contraceptive discontinuation: a prospective evaluation of frequency and reasons. Am J Obstet Gynecol. 1998;179(3 Pt 1):577-82. [pmid: 9757954].
Rosner BA, Colditz GA, Webb PM, et al. Mathematical models of ovarian cancer incidence. Epidemiology. 2005;16(4):508-15. [pmid: 15951669].
Ross C, Coleman G, Stojanovska C. Prospectively reported symptom change across the menstrual cycle in users and non-users of oral contraceptives. J Psychosom Obstet Gynaecol. 2003;24(1):15-29. [pmid: 12685336].
Rubio-lotvin B, Ruiz-moreno JA, Gonzalez-ansorena R. Desogestrel-ethinylestradiol, an oral monophasic contraceptive. Clinical and lipid metabolic effects: a 5-year experience. Adv Contracept Deliv Syst. 1992;8(1-2):75-88. [pmid: 12285566].
Ruffing JA, Nieves JW, Zion M, et al. The influence of lifestyle, menstrual function and oral contraceptive use on bone mass and size in female military cadets. Nutrition and Metabolism. 2007;4:17. [pmid: 17683610].
Rushforth B. Efficacy of a combined oral contraceptive containing 0.030 mg ethinylestradiol/2 mg dienogest for the treatment of papulopustular acne in comparison with placebo and 0.035 mg ethinylestradiol/2 mg cyproterone acetate. Journal of Family Planning and Reproductive Health Care. 2009;35(3):150.
Rushton L, Jones DR. Oral contraceptive use and breast cancer risk: a meta-analysis of variations with age at diagnosis, parity and total duration of oral contraceptive use. Br J Obstet Gynaecol. 1992;99(3):239-46. [pmid: 1534994].
Ryden L, Boiesen P, Jonsson PE. Decreased angiogenic activity in breast cancer in ever-users of oral contraceptive therapy--preliminary report. Anticancer Res. 2003;23(3C):2875-8. [pmid: 12926126].
Saadatnia M, Tajmirriahi M. Hormonal contraceptives as a risk factor for cerebral venous and sinus thrombosis. Acta Neurol Scand. 2007;115(5):295-300. [pmid: 17489938].
Saadatnia M, Mousavi SA, Haghighi S, et al. Cerebral vein and sinus thrombosis in Isfahan-Iran: a changing profile. Can J Neurol Sci. 2004;31(4):474-7. [pmid: 15595250].
Sabatini R, Orsini G, Cagiano R, et al. Noncontraceptive benefits of two combined oral contraceptives with antiandrogenic properties among adolescents. Contraception. 2007;76(5):342-7. [pmid: 17963857].
Salazar EL, Sojo-Aranda I, Lopez R, et al. The evidence for an etiological relationship between oral contraceptive use and dysplastic change in cervical tissue. Gynecol Endocrinol. 2001;15(1):23-8. [pmid: 11293920].
Salobir B, Sabovic M. Interleukin-6 and antiphospholipid antibodies in women with contraceptive-related thromboembolic disease. Obstet Gynecol. 2004;104(3):564-70. [pmid: 15339770].
Salobir B, Sabovic M, Peternel P, et al. Classic risk factors, hypercoagulability and migraine in young women with cerebral lacunar infarctions. Acta Neurol Scand. 2002;105(3):189-95. [pmid: 11886363].
Sanders SA, Graham CA, Bass JL, et al. A prospective study of the effects of oral contraceptives on sexuality and well-being and their relationship to discontinuation. Contraception. 2001;64(1):51-8. [pmid: 11535214].
Sangthawan M, Taneepanichskul S. A comparative study of monophasic oral contraceptives containing either drospirenone 3 mg or levonorgestrel 150 microg on premenstrual symptoms. Contraception. 2005;71(1):1-7. [pmid: 15639064].
Sapp AV, Lindbloom EJ. Do third-generation oral contraceptives (OCs) increase the risk of venous thrombosis?. J Fam Pract. 2001;50(10):893. [pmid: 11674894].
Sargent MA. The pill and gynecologic cancer: controversy and mystery prevail. J Med Assoc Ga. 1995;84(7):320-2. [pmid: 7561539].
Sator PG, Schmidt JB, Honigsmann H. Clinical evidence of the endocrinological influence of a triphasic oral contraceptive containing norgestimate and ethinyl estradiol in treating women with acne vulgaris. A pilot study. Dermatology. 2003;206(3):241-8. [pmid: 12673082].
Schildkraut JM, Hulka BS. Oral contraceptives and breast cancer: A case-control study with hospital and community controls (Reply). Obstetrics and Gynecology. 1990;76(6):1147. [pmid: 2234730].
Schlesselman JJ. Net effect of oral contraceptive use on the risk of cancer in women in the United States. Obstet Gynecol. 1995;85(5 Pt 1):793-801. [pmid: 7724116].
Schlesselman JJ. Risk of endometrial cancer in relation to use of combined oral contraceptives. A practitioner's guide to meta-analysis. Hum Reprod. 1997;12(9):1851-63. [pmid: 9363696].
Schramm GA, Schrah G. The efficacy and safety of an oral contraceptive containing chlormadinone acetate: results of a pooled analysis of noninterventional trials in adult and adolescent women. Contraception. 2011;84(4):390-401. [pmid: 21920195].
Schwingl PJ, Shelton J. Modeled estimates of myocardial infarction and venous thromboembolic disease in users of second and third generation oral contraceptives. Contraception. 1997;55(3):125-9. [pmid: 9114999].
Sehovic N, Smith KP. Risk of venous thromboembolism with drospirenone in combined oral contraceptive products. Ann Pharmacother. 2010;44(5):898-903. [pmid: 20371756].
Seidman DS, Yeshaya A, Ber A, et al. A prospective follow-up of two 21/7 cycles followed by two extended regimen 84/7 cycles with contraceptive pills containing ethinyl estradiol and drospirenone. Isr Med Assoc J. 2010;12(7):400-5. [pmid: 20862819].
Sekadde-Kigondu C, Mwathe EG, Ruminjo JK, et al. Acceptability and discontinuation of Depo-Provera, IUCD and combined pill in Kenya. East Afr Med J. 1996;73(12):786-94. [pmid: 9103686].
Shamliyan T, Wang S, Virnig BA, et al. Association between patient and tumor characteristics with clinical outcomes in women with ductal carcinoma in situ. Journal of the National Cancer Institute - Monographs. 2010;2010(41):121-129. [pmid: 20956815].
Shapiro S, Dinger J. Risk of venous thromboembolism among users of oral contraceptives: a review of two recently published studies. J Fam Plann Reprod Health Care. 2010;36(1):33-8. [pmid: 20067670].
Shulman LP. The menopausal transition: how does route of delivery affect the risk/benefit ratio of hormone therapy?. J Fam Pract. 2004;(Suppl):S13-7. [pmid: 15251108].
Shulman LP. The use of triphasic oral contraceptives in a continuous use regimen. Contraception. 2005;72(2):105-10. [pmid: 16022848].
Sicat BL. Ortho Evra, a new contraceptive patch. Pharmacotherapy. 2003;23(4):472-80. [pmid: 12680477].
Skjeldestad FE. Oral contraceptive failures among women terminating their pregnancy. Acta Obstet Gynecol Scand. 2000;79(7):580-5. [pmid: 10929959].
Skjeldestad FE. Using induced abortion to measure contraceptive efficacy. Fam Plann Perspect. 1995;27(2):71-3. 96. [pmid: 7796899].
Skouby SO. Contraceptive use and behavior in the 21st century: a comprehensive study across five European countries. Eur J Contracept Reprod Health Care. 2004;9(2):57-68. [pmid: 15449817].
Smith EV, Grindlay DJ, Williams HC. What's new in acne? An analysis of systematic reviews published in 2009-2010. Clin Exp Dermatol. 2010. Aug. 25. [pmid: 20738323].
Smith JS, Green J, Berrington de Gonzalez A, et al. Cervical cancer and use of hormonal contraceptives: a systematic review. Lancet. 2003;361(9364):1159-67. [pmid: 12686037].
Smith KJ, Monsef BS, Ragni MV. Should female relatives of factor V Leiden carriers be screened prior to oral contraceptive use? A cost-effectiveness analysis. Thromb Haemost. 2008;100(3):447-52. [pmid: 18766261].
Smith NL, Heckbert SR, Lemaitre RN, et al. Risk of venous thrombosis was increased with conjugated equine estrogens but not esterified estrogens. Evidence-based Obstetrics and Gynecology. 2005;7(3):164-165.
Sogaard M, Kjaer SK, Gayther S. Ovarian cancer and genetic susceptibility in relation to the BRCA1 and BRCA2 genes. Occurrence, clinical importance and intervention. Acta Obstet Gynecol Scand. 2006;85(1):93-105. [pmid: 16521688].
Speroff L. The risk of breast cancer associated with oral contraception and hormone replacement therapy. Womens Health Issues. 1992;2(2):63-72. discussion 73-4. [pmid: 1535527].
Spitzer WO, Faith JM, MacRae KD. Myocardial infarction and third generation oral contraceptives: aggregation of recent studies. Hum Reprod. 2002;17(9):2307-14. [pmid: 12202417].
Spitzer WO, Faith JM, MacRae KD, et al. The risk of myocardial infarction is lower with third-,compared to second-, generation OC - Meta-analysis. Evidence-based Obstetrics and Gynecology. 2003;5(3):126-127.
Staffa JA, Newschaffer CJ, Jones JK, et al. Progestins and breast cancer: an epidemiologic review. Fertil Steril. 1992;57(3):473-91. [pmid: 1740192].
Stampfer MJ, Willett WC, Colditz GA, et al. Past use of oral contraceptives and cardiovascular disease: a meta-analysis in the context of the Nurses' Health Study. Am J Obstet Gynecol. 1990;163(1 Pt 2):285-91. [pmid: 2142573].
Sveinsdottir H, Backstrom T. Menstrual cycle symptom variation in a community sample of women using and not using oral contraceptives. Acta Obstet Gynecol Scand. 2000;79(9):757-64. [pmid: 10993099].
Szendei G, Hernadi Z, Devenyi N, et al. Is there any correlation between stages of endometriosis and severity of chronic pelvic pain? Possibilities of treatment. Gynecol Endocrinol. 2005;21(2):93-100. [pmid: 16109595].
Takamura M, Koga K, Osuga Y, et al. Post-operative oral contraceptive use reduces the risk of ovarian endometrioma recurrence after laparoscopic excision. Hum Reprod. 2009;24(12):3042-8. [pmid: 19684045].
Tan J. Hormonal treatment of acne: review of current best evidence. J Cutan Med Surg. Suppl 4. 2004;8:11-5. [pmid: 15778821].
Tanis BC, van den Bosch MAAJ, Kemmeren JM, et al. Second, but not third, generation oral contraceptive use was associated with an increased risk of myocardial infarction. Evidence-based Obstetrics and Gynecology. 2002;4(3):138-139.
Tao LC. Oral contraceptive-associated liver cell adenoma and hepatocellular carcinoma. Cytomorphology and mechanism of malignant transformation. Cancer. 1991;68(2):341-7. [pmid: 1712664].
Tarjanne S, Sjoberg J, Heikinheimo O. Rectovaginal endometriosis-characteristics of operative treatment and factors predicting bowel resection. J Minim Invasive Gynecol. 2009;16(3):302-6. [pmid: 19269901].
Tepper NK, Paulen ME, Marchbanks PA, et al. Safety of contraceptive use among women with peripartum cardiomyopathy: a systematic review. Contraception. 2010;82(1):95-101. [pmid: 20682147].
Tepper SJ, Taylor FR, Bigal ME, Kurth T, Gaziano JM, Cook NR, Logroscino G, Diener HC, Buring JE. Migraine and risk of cardiovascular disease in women. JAMA. 2006;296:283-291. Headache. 2007;47(2):303-305. [pmid: 16849661].
Thomas DB. Oral contraceptives and breast cancer: review of the epidemiologic literature. Contraception. 1991;43(6):597-642. [pmid: 1868735].
Thorogood M, Vessey MP. An epidemiologic survey of cardiovascular disease in women taking oral contraceptives. Am J Obstet Gynecol. 1990;163(1 Pt 2):274-81. [pmid: 2196799].
Thorogood M. Stroke and steroid hormonal contraception. Contraception. 1998;57(3):157-67. [pmid: 9617532].
Tiller K, Meiser B, Gould L, et al. Knowledge of risk management strategies, and information and risk management preferences of women at increased risk for ovarian cancer. Psychooncology. 2005;14(4):249-61. [pmid: 15386771].
Tolley E, Loza S, Kafafi L, et al. The impact of menstrual side effects on contraceptive discontinuation: findings from a longitudinal study in Cairo, Egypt. Int Fam Plan Perspect. 2005;31(1):15-23. [pmid: 15888405].
Tosetto A, Frezzato M, Rodeghiero F. Prevalence and risk factors of non-fatal venous thromboembolism in the active population of the VITA Project. J Thromb Haemost. 2003;1(8):1724-9. [pmid: 12911584].
Trollmann R, Strehl E, Dorr HG. Precocious puberty in children with myelomeningocele: treatment with gonadotropin-releasing hormone analogues. Dev Med Child Neurol. 1998;40(1):38-43. [pmid: 9459215].
Trussell J, Hatcher RA, Cates W Jr, et al. Contraceptive failure in the United States: an update. Stud Fam Plann. 1990;21(1):51-4. [pmid: 2180135].
Tuchman LK, Huppert JS, Huang B, et al. Adolescent use of the monthly contraceptive injection. J Pediatr Adolesc Gynecol. 2005;18(4):255-60. [pmid: 16171729].
Turati F, La Vecchia C. Risk factors for breast cancer in China: Similarities and differences with western populations. Archives of Medical Science. 2012;8(2):179-182. [pmid: 22661987].
van Berge Henegouwen GP, van der Werf SD. Serum bile acids and the bile acid tolerance test under oral contraception. Hepatogastroenterology. 1992;39(2):177-80. [pmid: 1634184].
van Bogaert LJ. ‘Failed’ contraception in a rural South African population. S Afr Med J. 2003;93(11):858-61. [pmid: 14677512].
van Hooff MH, Hirasing RA, Kaptein MB, et al. The use of oral contraceptives by adolescents for contraception, menstrual cycle problems or acne. Acta Obstet Gynecol Scand. 1998;77(9):898-904. [pmid: 9808377].
van Tilburg MA, Becht MC, Vingerhoets AJ. Self-reported crying during the menstrual cycle: sign of discomfort and emotional turmoil or erroneous beliefs?. J Psychosom Obstet Gynaecol. 2003;24(4):247-55. [pmid: 14702885].
Vandenbroucke JP, Rosing J, Bloemenkamp KW, et al. Oral contraceptives and the risk of venous thrombosis. N Engl J Med. 2001;344(20):1527-35. [pmid: 11357157].
Varney SJ, Guest JF. Relative cost effectiveness of Depo-Provera, Implanon, and Mirena in reversible long-term hormonal contraception in the UK. Pharmacoeconomics. 2004;22(17):1141-51. [pmid: 15612832].
Velentgas P, Daling JR. Risk factors for breast cancer in younger women. J Natl Cancer Inst Monogr. 1994;(16):15-24. [pmid: 7999458].
Vercellini P, Frontino G, De Giorgi O, et al. Continuous use of an oral contraceptive for endometriosis-associated recurrent dysmenorrhea that does not respond to a cyclic pill regimen. Fertil Steril. 2003;80(3):560-3. [pmid: 12969698].
Vercellini P, Somigliana E, Daguati R, et al. Postoperative oral contraceptive exposure and risk of endometrioma recurrence. Am J Obstet Gynecol. 2008;198(5):504 e1-5. [pmid: 18241819].
Vescovi JD, VanHeest JL, De Souza MJ. Short-term response of bone turnover to low-dose oral contraceptives in exercising women with hypothalamic amenorrhea. Contraception. 2008;77(2):97-104. [pmid: 18226672].
Vetrano G, Lombardi G, Di Leone G, et al. Cervical intraepithelial neoplasia: risk factors for persistence and recurrence in adolescents. Eur J Gynaecol Oncol. 2007;28(3):189-92. [pmid: 17624084].
Villard L, Murphy M. Endometrial cancer trends in England and Wales: a possible protective effect of oral contraception. Int J Epidemiol. 1990;19(2):255-8. [pmid: 2376432].
Voke J, Keidan J, Pavord S, et al. The management of antenatal venous thromboembolism in the UK and Ireland: a prospective multicentre observational survey. Br J Haematol. 2007;139(4):545-58. [pmid: 17916101].
Voordouw BC, Euser R, Verdonk RE, et al. Melatonin and melatonin-progestin combinations alter pituitary-ovarian function in women and can inhibit ovulation. J Clin Endocrinol Metab. 1992;74(1):108-17. [pmid: 1727807].
Waetjen LE, Grimes DA. Oral contraceptives and primary liver cancer: temporal trends in three countries. Obstet Gynecol. 1996;88(6):945-9. [pmid: 8942832].
Wahi MM, Shah N, Schrock CE, et al. Reproductive factors and risk of pancreatic cancer in women: a review of the literature. Ann Epidemiol. 2009;19(2):103-11. [pmid: 19185803].
Weber-Diehl F, Unger R, Lachnit U. Triphasic combination of ethinyl estradiol and gestodene. Long-term clinical trial. Contraception. 1992;46(1):19-27. [pmid: 1424620].
Weisman CS, Plichta S, Nathanson CA, et al. Adolescent women's contraceptive decision making. J Health Soc Behav. 1991;32(2):130-44. [pmid: 1861049].
Weiss G. Risk of venous thromboembolism with third-generation oral contraceptives: A review. Am J Obstet Gynecol. 1999;180(2 Pt 2):295-301. [pmid: 9988833].
Weiss NS, White E. Oral contraceptives and malignant melanoma. Cancer Causes Control. 1993;4(4):395-7. [pmid: 8347789].
Welker GC, Lookinland S, Tiedeman ME, et al. The role of genetics in the risk of thromboembolism: prothrombin 20210A and oral contraceptive therapy. J Am Acad Nurse Pract. 2004;16(3):106-15. 138. [pmid: 15130065].
Wester K, Jonsson A, Spigset O, et al. Spontaneously reported fatal suspected adverse drug reactions: A 10-year survey from Sweden. Pharmacoepidemiology and Drug Safety. 2007;16(2):173-180. [pmid: 16739241].
Westhoff C, Kerns J, Morroni C, et al. Quick start: novel oral contraceptive initiation method. Contraception. 2002;66(3):141-5. [pmid: 12384200].
Whalen KL, Rose R. Estradiol valerate/dienogest: a novel oral contraceptive. Ann Pharmacother. 2011;45(10):1256-61. [pmid: 21917554].
Wheeler JM, Malinak LR. Complexion changes in oral contraceptive users. Results from a phase IV multicenter trial evaluating the safety and efficacy of ethynodiol diacetate, 1 mg, with ethinyl estradiol, 35 micrograms. J Reprod Med. 1991;36(4 Suppl):340-4. [pmid: 2046083].
Whittemore AS, Harris R, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. IV. The pathogenesis of epithelial ovarian cancer. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1212-20. [pmid: 1476143].
Whittemore AS. Personal characteristics relating to risk of invasive epithelial ovarian cancer in older women in the United States. Cancer. 1993;71(2 Suppl):558-65. [pmid: 8420677].
Wilkinson E. HPV and oral contraceptives linked to cervical cancer risk. Lancet Oncology. 2002;3(5):265.
Willerson JT. Venous thromboembolic disease and combined oral contraceptives: Results of international multicenter case-control study. Circulation. 1996;93(8):1482.
Williams JK. Noncontraceptive benefits of oral contraceptive use: an evidence-based approach. Int J Fertil Womens Med. 2000;45(3):241-7. [pmid: 10929688].
Wilson TE, Koenig LJ, Walter E, et al. Dual contraceptive method use for pregnancy and disease prevention among HIV-infected and HIV-uninfected women: the importance of an event-level focus for promoting safer sexual behaviors. Sex Transm Dis. 2003;30(11):809-12. [pmid: 14603086].
Wimberly YH, Cotton S, Wanchick AM, et al. Attitudes and experiences with levonorgestrel 100 microg/ethinyl estradiol 20 microg among women during a 3-month trial. Contraception. 2002;65(6):403-6. [pmid: 12127637].
Winkel CA, Scialli AR. Medical and surgical therapies for pain associated with endometriosis. J Womens Health Gend Based Med. 2001;10(2):137-62. [pmid: 11268298].
Wong KK, Ng SC, Koong PL. Effect of the oral contraceptive pill on protein S and antithrombin-III levels in Malaysian women. Med Sci Res. 1992;20(12):439-40. [pmid: 12288974].
Wong MT, Singh K. The combined oral contraceptive pill in women over age forty. Ann Acad Med Singapore. 2003;32(5):624-31. [pmid: 14626790].
Wonglikhitpanya N, Taneepanichskul S. Effects of biphasic oral contraceptives containing desogestrel (Oilezz) on cycle control facial acne and seborrhea in healthy Thai women. J Med Assoc Thai. 2006;89(6):755-60. [pmid: 16850673].
Woods ER, Grace E, Havens KK, et al. Contraceptive compliance with a levonorgestrel triphasic and a norethindrone monophasic oral contraceptive in adolescent patients. Am J Obstet Gynecol. 1992;166(3):901-7. [pmid: 1550161].
Wu O, Greer IA. Is screening for thrombophilia cost-effective?. Curr Opin Hematol. 2007;14(5):500-3. [pmid: 17934357].
Wu O, Robertson L, Langhorne P, et al. Oral contraceptives, hormone replacement therapy, thrombophilias and risk of venous thromboembolism: a systematic review. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) Study. Thromb Haemost. 2005;94(1):17-25. [pmid: 16113779].
Wu O, Robertson L, Twaddle S, et al. Screening for thrombophilia in high-risk situations: systematic review and cost-effectiveness analysis. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) study. Health Technol Assess. 2006;10(11):1-110. [pmid: 16595080].
Xue L, Yuan W, Lou CH, et al. Choice and changes of contraceptive methods after primiparous delivery in Shanghai. Reprod Contracept. 1999;10(1):40-8. [pmid: 12295178].
Yoong WC, Tuck SM, Pasi KJ, et al. Markers of platelet activation, thrombin generation and fibrinolysis in women with sickle cell disease: effects of differing forms of hormonal contraception. Eur J Haematol. 2003;70(5):310-4. [pmid: 12694167].
Yuk VJ, Cumming CE, Fox EE, et al. Frequency and severity of premenstrual symptoms in women taking birth control pills. Gynecol Obstet Invest. 1991;31(1):42-5. [pmid: 2010113].
Zahradnik HP, Hanjalic-Beck A, Groth K. Nonsteroidal anti-inflammatory drugs and hormonal contraceptives for pain relief from dysmenorrhea: a review. Contraception. 2010;81(3):185-96. [pmid: 20159173].
Zimmermann T, Dietrich H, Wisser KH, et al. Efficacy and tolerability of the dienogest-containing oral contraceptive Valette(registered trademark). Results of a postmarketing surveillance study. Drugs of Today. 1999;35(SUPPL. C):79-87. [pmid: 12973411].

## Study population is not women taking OCs for contraception or for primary prevention of ovarian cancer

Abdel-Aleem H, d'Arcangues C, Vogelsong K, et al. Treatment of vaginal bleeding irregularities induced by progestin only contraceptives. Cochrane Database Syst Rev. 2007;(2):CD003449. [pmid: 17443526].
Adler AI, Weiss NS, Kamb ML, et al. Is diabetes mellitus a risk factor for ovarian cancer? A case-control study in Utah and Washington (United States). Cancer Causes Control. 1996;7(4):475-8. [pmid: 8813436].
Agarwal N, Kriplani A. Medical management of dysfunctional uterine bleeding. Int J Gynaecol Obstet. 2001;75(2):199-201. [pmid: 11684117].
AinMelk Y. Comparison of two continuous combined estrogen progestogen regimens in postmenopausal women: a randomized trial. Fertil Steril. 1996;66(6):962-8. [pmid: 8941062].
Al Kadri H, Hassan S, Al-Fozan HM, et al. Hormone therapy for endometriosis and surgical menopause. Cochrane Database Syst Rev. 2009;(1):CD005997. [pmid: 19160262].
Anderson GL, Chlebowski RT, Rossouw JE, et al. Prior hormone therapy and breast cancer risk in the Women's Health Initiative randomized trial of estrogen plus progestin. Maturitas. 2006;55(2):103-15. [pmid: 16815651].
Anderson GL, Judd HL, Kaunitz AM, et al. Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women's Health Initiative randomized trial. JAMA. 2003;290(13):1739-48. [pmid: 14519708].
Andersson K, Batar I, Rybo G. Return to fertility after removal of a levonorgestrel-releasing intrauterine device and Nova-T. Contraception. 1992;46(6):575-84. [pmid: 1493717].
Andersson K, Odlind V, Rybo G. Levonorgestrel-releasing and copper-releasing (Nova-T) IUDs during five years of use: a randomized comparative trial. Contraception. 1994;49(1):56-72. [pmid: 8137626].
Anonymous. An evidence-based guideline for the management of heavy menstrual bleeding. Working Party for Guidelines for the Management of Heavy Menstrual Bleeding. N Z Med J. 1999;112(1088):174-7. [pmid: 10391640].
Anonymous. Breast cancer and depot-medroxyprogesterone acetate: a multinational study. WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Lancet. 1991;338(8771):833-8. [pmid: 1681212].
Anonymous. Depot-medroxyprogesterone acetate (DMPA) and risk of endometrial cancer. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Cancer. 1991;49(2):186-90. [pmid: 1831802].
Anonymous. Depot-medroxyprogesterone acetate (DMPA) and risk of epithelial ovarian cancer. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Cancer. 1991;49(2):191-5. [pmid: 1831803].
Anonymous. Depot-medroxyprogesterone acetate (DMPA) and risk of invasive squamous cell cervical cancer. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Contraception. 1992;45(4):299-312. [pmid: 1387601].
Anonymous. Depot-medroxyprogesterone acetate (DMPA) and risk of liver cancer. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Cancer. 1991;49(2):182-5. [pmid: 1831801].
Arowojolu AO, Gallo MF, Lopez LM, et al. Combined oral contraceptive pills for treatment of acne. Cochrane Database Syst Rev. 2012;6:CD004425. [pmid: 22696343].
Atchley DP, Albarracin CT, Lopez A, et al. Clinical and pathologic characteristics of patients with BRCA-positive and BRCA-negative breast cancer. J Clin Oncol. 2008;26(26):4282-8. [pmid: 18779615].
Backman T, Huhtala S, Tuominen J, et al. Sixty thousand woman-years of experience on the levonorgestrel intrauterine system: an epidemiological survey in Finland. Eur J Contracept Reprod Health Care. Suppl 1. 2001;6:23-6. [pmid: 11336430].
Backman T, Rauramo I, Jaakkola K, et al. Use of the levonorgestrel-releasing intrauterine system and breast cancer. Obstet Gynecol. 2005;106(4):813-7. [pmid: 16199640].
Backstrom T, Hansson-Malmstrom Y, Lindhe BA, et al. Oral contraceptives in premenstrual syndrome: a randomized comparison of triphasic and monophasic preparations. Contraception. 1992;46(3):253-68. [pmid: 1451521].
Baglin T, Palmer CR, Luddington R, et al. Unprovoked recurrent venous thrombosis: prediction by D-dimer and clinical risk factors. J Thromb Haemost. 2008;6(4):577-82. [pmid: 18182040].
Baik I, Lambe M, Liu Q, et al. Birth spacing and maternal risk of invasive epithelial ovarian cancer in a Swedish nationwide cohort. Cancer Causes Control. 2008;19(10):1131-7. [pmid: 18509730].
Bailie R, Katzenellenbogen J, Hoffman M, et al. A case control study of breast cancer risk and exposure to injectable progestogen contraceptives. Methods and patterns of use among controls. S Afr Med J. 1997;87(3):302-5. [pmid: 9137342].
Baker J, Obermair A, Gebski V, et al. Efficacy of oral or intrauterine device-delivered progestin in patients with complex endometrial hyperplasia with atypia or early endometrial adenocarcinoma: A meta-analysis and systematic review of the literature. Gynecologic Oncology. 2012;125(1):263-270. [pmid: 22196499].
Baldaszti E, Wimmer-Puchinger B, Loschke K. Acceptability of the long-term contraceptive levonorgestrel-releasing intrauterine system (Mirena): a 3-year follow-up study. Contraception. 2003;67(2):87-91. [pmid: 12586318].
Barreiros FA, Guazzelli CA, Barbosa R, et al. Extended regimens of the contraceptive vaginal ring: evaluation of clinical aspects. Contraception. 2010;81(3):223-5. [pmid: 20159178].
Batukan C, Muderris II, Ozcelik B, et al. Comparison of two oral contraceptives containing either drospirenone or cyproterone acetate in the treatment of hirsutism. Gynecol Endocrinol. 2007;23(1):38-44. [pmid: 17484511].
Beral V, Bull D, Green J, et al. Ovarian cancer and hormone replacement therapy in the Million Women Study. Lancet. 2007;369(9574):1703-10. [pmid: 17512855].
Berry DC, Raynor DK, Knapp P, et al. Official warnings on thromboembolism risk with oral contraceptives fail to inform users adequately. Contraception. 2002;66(5):305-7. [pmid: 12443959].
Blumenthal PD, Gemzell-Danielsson K, Marintcheva-Petrova M. Tolerability and clinical safety of Implanon. Eur J Contracept Reprod Health Care. Suppl 1. 2008;13:29-36. [pmid: 18330815].
Braaten T, Weiderpass E, Kumle M, et al. Education and risk of breast cancer in the Norwegian-Swedish women's lifestyle and health cohort study. Int J Cancer. 2004;110(4):579-83. [pmid: 15122591].
Brown J, Kives S, Akhtar M. Progestagens and anti-progestagens for pain associated with endometriosis. 2012;(3):CD002122.
Bruni V, Pontello V, Luisi S, et al. An open-label, multicentre trial to evaluate the vaginal bleeding pattern of the combined contraceptive vaginal ring NuvaRing. Eur J Obstet Gynecol Reprod Biol. 2008;139(1):65-71. [pmid: 18358586].
Brynhildsen J, Hansson A, Persson A, et al. Follow-up of patients with low back pain during pregnancy. Obstet Gynecol. 1998;91(2):182-6. [pmid: 9469272].
Burkman RT, Tang MT, Malone KE, et al. Infertility drugs and the risk of breast cancer: findings from the National Institute of Child Health and Human Development Women's Contraceptive and Reproductive Experiences Study. Fertil Steril. 2003;79(4):844-51. [pmid: 12749419].
Calaf J, Lopez E, Millet A, et al. Long-term efficacy and tolerability of flutamide combined with oral contraception in moderate to severe hirsutism: a 12-month, double-blind, parallel clinical trial. J Clin Endocrinol Metab. 2007;92(9):3446-52. [pmid: 17566093].
Caruso S, Rugolo S, Agnello C, et al. Quality of sexual life in hyperandrogenic women treated with an oral contraceptive containing chlormadinone acetate. J Sex Med. 2009;6(12):3376-84. [pmid: 19832931].
Castelo-Branco C, Vicente JJ, Pons F, et al. Bone mineral density in young, hypothalamic oligoamenorrheic women treated with oral contraceptives. J Reprod Med. 2001;46(10):875-9. [pmid: 11725730].
Cetin NN, Karabacak O, Korucuoglu U, et al. Gonadotropin-releasing hormone analog combined with a low-dose oral contraceptive to treat heavy menstrual bleeding. Int J Gynaecol Obstet. 2009;104(3):236-9. [pmid: 19062012].
Charoenvisal C, Thaipisuttikul Y, Pinjaroen S, et al. Effects on acne of two oral contraceptives containing desogestrel and cyproterone acetate. Int J Fertil Menopausal Stud. 1996;41(4):423-9. [pmid: 8894800].
Cheewadhanaraks S, Choksuchat C, Dhanaworavibul K, et al. Postoperative Depot Medroxyprogesterone Acetate versus Continuous Oral Contraceptive Pills in the Treatment of Endometriosis-Associated Pain: A Randomized Comparative Trial. Gynecologic and Obstetric Investigation. 2012.
Chen JH, Wu SC, Shao WQ, et al. The comparative trial of TCu 380A IUD and progesterone-releasing vaginal ring used by lactating women. Contraception. 1998;57(6):371-9. [pmid: 9693396].
Cobb KL, Bachrach LK, Sowers M, et al. The effect of oral contraceptives on bone mass and stress fractures in female runners. Med Sci Sports Exerc. 2007;39(9):1464-73. [pmid: 17805075].
Coker AL, Hulka BS, McCann MF, et al. Barrier methods of contraception and cervical intraepithelial neoplasia. Contraception. 1992;45(1):1-10. [pmid: 1591917].
Coney P, Washenik K, Langley RG, et al. Weight change and adverse event incidence with a low-dose oral contraceptive: two randomized, placebo-controlled trials. Contraception. 2001;63(6):297-302. [pmid: 11672550].
Cosmi B, Legnani C, Bernardi F, et al. Value of family history in identifying women at risk of venous thromboembolism during oral contraception: observational study. BMJ. 2001;322(7293):1024-5. [pmid: 11325765].
Costa ML, Cecatti JG, Krupa FG, et al. Progestin-only contraception prevents bone loss in postpartum breastfeeding women. Contraception. 2012;85(4):374-380. [pmid: 22036473].
Costello MF, Shrestha B, Eden J, et al. Metformin versus oral contraceptive pill in polycystic ovary syndrome: a Cochrane review. Hum Reprod. 2007;22(5):1200-9. [pmid: 17261574].
Costello Michael F, Shrestha B, Eden J, et al. Insulin-sensitising drugs versus the combined oral contraceptive pill for hirsutism, acne and risk of diabetes, cardiovascular disease, and endometrial cancer in polycystic ovary syndrome. 2007;(1):CD005552.
Coutinho EM, de Souza JC, da Silva AR, et al. Comparative study on the efficacy and acceptability of two contraceptive pills administered by the vaginal route: an international multicenter clinical trial. Clin Pharmacol Ther. 1993;53(1):65-75. [pmid: 8422744].
Coutinho EM, O'Dwyer E, Barbosa IC, et al. Comparative study on intermittent versus continuous use of a contraceptive pill administered by vaginal route. Contraception. 1995;51(6):355-8. [pmid: 7554976].
Coutinho EM, Spinola P, Athayde C, et al. Comparison of two regimens of a monthly injectable contraceptive containing dihydroxyprogesterone acetophenide and estradiol enanthate. Contraception. 2006;73(3):249-52. [pmid: 16472564].
Coutinho EM, Spinola P, Barbosa I, et al. Multicenter, double-blind, comparative clinical study on the efficacy and acceptability of a monthly injectable contraceptive combination of 150 mg dihydroxyprogesterone acetophenide and 10 mg estradiol enanthate compared to a monthly injectable contraceptive combination of 90 mg dihydroxyprogesterone acetophenide and 6 mg estradiol enanthate. Contraception. 1997;55(3):175-81. [pmid: 9115007].
Creatsas G, Cardamakis E, Deligeoroglou E, et al. Tenoxicam versus lynestrenol-ethinyl estradiol treatment of dysfunctional uterine bleeding cases during adolescence. J Pediatr Adolesc Gynecol. 1998;11(4):177-80. [pmid: 9806127].
Creinin MD, Meyn LA, Borgatta L, et al. Multicenter comparison of the contraceptive ring and patch: a randomized controlled trial. Obstet Gynecol. 2008;111(2 Pt 1):267-77. [pmid: 18238962].
Culwell KR, Curtis KM. Use of contraceptive methods by women with current venous thrombosis on anticoagulant therapy: a systematic review. Contraception. 2009;80(4):337-45. [pmid: 19751856].
Cushman M, Glynn RJ, Goldhaber SZ, et al. Hormonal factors and risk of recurrent venous thrombosis: the prevention of recurrent venous thromboembolism trial. J Thromb Haemost. 2006;4(10):2199-203. [pmid: 16869933].
Daly E, Vessey MP, Hawkins MM, et al. Risk of venous thromboembolism in users of hormone replacement therapy. Lancet. 1996;348(9033):977-80. [pmid: 8855852].
Darney P, Patel A, Rosen K, et al. Safety and efficacy of a single-rod etonogestrel implant (Implanon): results from 11 international clinical trials. Fertil Steril. 2009;91(5):1646-53. [pmid: 18423453].
Davis A, Godwin A, Lippman J, et al. Triphasic norgestimate-ethinyl estradiol for treating dysfunctional uterine bleeding. Obstet Gynecol. 2000;96(6):913-20. [pmid: 11084177].
Davis AR, Westhoff CL. Primary dysmenorrhea in adolescent girls and treatment with oral contraceptives. J Pediatr Adolesc Gynecol. 2001;14(1):3-8. [pmid: 11358700].
Davis AR, Osborne LM, O'Connell KJ, et al. Challenges of conducting a placebo-controlled trial for dysmenorrhea in adolescents. J Adolesc Health. 2006;39(4):607-9. [pmid: 16982402].
Davis AR, Westhoff C, O'Connell K, et al. Oral contraceptives for dysmenorrhea in adolescent girls: a randomized trial. Obstet Gynecol. 2005;106(1):97-104. [pmid: 15994623].
Davis L, Kennedy SS, Moore J, et al. Modern combined oral contraceptives for pain associated with endometriosis. Cochrane Database Syst Rev. 2007;(3):CD001019. [pmid: 17636650].
del Carmen Cravioto M, Alvarado G, Canto-de-Cetina T, et al. A multicenter comparative study on the efficacy, safety, and acceptability of the contraceptive subdermal implants Norplant and Norplant-II. Contraception. 1997;55(6):359-67. [pmid: 9262932].
Diaz J, Faundes A, Diaz M, et al. Evaluation of the clinical performance of a levonorgestrel-releasing IUD, up to seven years of use, in Campinas, Brazil. Contraception. 1993;47(2):169-75. [pmid: 8449017].
Dinger JC, Heinemann LAJ, Mohner S, et al. Breast cancer risk associated with different HRT formulations: A register-based case-control study. BMC Women's Health. 2006;6:13. [pmid: 16965641].
Dore DD, Norman H, Loughlin J, et al. Extended case-control study results on thromboembolic outcomes among transdermal contraceptive users. Contraception. 2010;81(5):408-13. [pmid: 20399947].
Douglas S. Premenstrual syndrome. Evidence-based treatment in family practice. Can Fam Physician. 2002;48:1789-97. [pmid: 12489244].
Draper BH, Morroni C, Hoffman M, et al. Depot medroxyprogesterone versus norethisterone oenanthate for long-acting progestogenic contraception. Cochrane Database Syst Rev. 2006;3:CD005214. [pmid: 16856087].
Endrikat J, Gerlinger C, Plettig K, et al. A meta-analysis on the correlation between ovarian activity and the incidence of intermenstrual bleeding during low-dose oral contraceptive use. Gynecol Endocrinol. 2003;17(2):107-14. [pmid: 12737671].
Erkkola R, Hirvonen E, Luikku J, et al. Ovulation inhibitors containing cyproterone acetate or desogestrel in the treatment of hyperandrogenic symptoms. Acta Obstet Gynecol Scand. 1990;69(1):61-5. [pmid: 2140663].
Estevao RA, Nazario AC, Baracat EC. Effect of oral contraceptive with and without associated estriol on ultrasound measurements of breast fibroadenoma: randomized clinical trial. Sao Paulo Med J. 2007;125(5):275-80. [pmid: 18094894].
Fairfield KM, Hunter DJ, Fuchs CS, et al. Aspirin, other NSAIDs, and ovarian cancer risk (United States). Cancer Causes Control. 2002;13(6):535-42. [pmid: 12195643].
Falsetti L, Pasinetti E. Effects of long-term administration of an oral contraceptive containing ethinylestradiol and cyproterone acetate on lipid metabolism in women with polycystic ovary syndrome. Acta Obstet Gynecol Scand. 1995;74(1):56-60. [pmid: 7856434].
Farquhar C, Brown J. Oral contraceptive pill for heavy menstrual bleeding. Cochrane Database Syst Rev. 2009;(4):CD000154. [pmid: 19821266].
Fernandez E, La Vecchia C, Braga C, et al. Hormone replacement therapy and risk of colon and rectal cancer. Cancer Epidemiol Biomarkers Prev. 1998;7(4):329-33. [pmid: 9568789].
Ferrari B, Barusi L, Coppola F. Clinical and endocrine effects of ovulation induction with FSH and hCG supplementation in low responders in the midfollicular phase. A pilot study. J Reprod Med. 2002;47(2):137-43. [pmid: 11883353].
Follmann M, Heinemann LAJ, Dipl-Stat AB, et al. Treatment with potentially hepatotoxic drugs and the risk of hepatocellular carcinoma: Results of a European case-control study. Pharmacoepidemiology and Drug Safety. 2000;9(5):417-422. [pmid: 19025848].
Franceschi S, Rajkumar T, Vaccarella S, et al. Human papillomavirus and risk factors for cervical cancer in Chennai, India: a case-control study. Int J Cancer. 2003;107(1):127-33. [pmid: 12925967].
Fraser IS, McCarron G. Randomized trial of 2 hormonal and 2 prostaglandin-inhibiting agents in women with a complaint of menorrhagia. Aust N Z J Obstet Gynaecol. 1991;31(1):66-70. [pmid: 1872778].
Fraser IS, Parke S, Mellinger U, et al. Effective treatment of heavy and/or prolonged menstrual bleeding without organic cause: pooled analysis of two multinational, randomised, double-blind, placebo-controlled trials of oestradiol valerate and dienogest. Eur J Contracept Reprod Health Care. 2011;16(4):258-69. [pmid: 21774563].
Fraser IS, Weisberg E, Brache V, et al. Serum Nestorone and ethinyl estradiol levels, and ovulation inhibition in women using three different dosage combinations of a Nestorone progestogen-ethinyl estradiol contraceptive vaginal ring on a bleeding-signaled regimen. Contraception. 2005;72(1):40-5. [pmid: 15964291].
Freeman EW, Kroll R, Rapkin A, et al. Evaluation of a unique oral contraceptive in the treatment of premenstrual dysphoric disorder. J Womens Health Gend Based Med. 2001;10(6):561-9. [pmid: 11559453].
French R, Cowan F, Mansour D, et al. Hormonally impregnated intrauterine systems (IUSs), versus other forms of reversible contraceptives as effective methods of preventing pregnancy. Cochrane Database Syst Rev. 2001;(2):CD001776. [pmid: 11406007].
French R, Van Vliet H, Cowan F, et al. Hormonally impregnated intrauterine systems (IUSs) versus other forms of reversible contraceptives as effective methods of preventing pregnancy. Cochrane Database Syst Rev. 2004;(3):CD001776. [pmid: 15266453].
French RS, Cowan FM, Mansour D, et al. Levonorgestrel-releasing (20 microgram/day) intrauterine systems (Mirena) compared with other methods of reversible contraceptives. BJOG. 2000;107(10):1218-25. [pmid: 11028571].
French RS, Cowan FM, Mansour DJ, et al. Implantable contraceptives (subdermal implants and hormonally impregnated intrauterine systems) versus other forms of reversible contraceptives: two systematic reviews to assess relative effectiveness, acceptability, tolerability and cost-effectiveness. Health Technol Assess. 2000;4(7):i-vi. 1. 107. [pmid: 10944741].
Friedman AJ, Thomas PP. Does low-dose combination oral contraceptive use affect uterine size or menstrual flow in premenopausal women with leiomyomas?. Obstet Gynecol. 1995;85(4):631-5. [pmid: 7898846].
Gallo MF, Grimes DA, Lopez LM, et al. Combination injectable contraceptives for contraception. Cochrane Database Syst Rev. 2008;(4):CD004568. [pmid: 18843662].
Gallo MF, Grimes DA, Schulz KF, et al. Combination injectable contraceptives for contraception. Cochrane Database Syst Rev. 2005;(3):CD004568. [pmid: 16034938].
Gama CRB, Gama GF, Lasmar RB, et al. Clinical assessment of ethinylestradiol and cyproterone acetate in menstrual irregularities of hyper-androgenic origin. Revista Brasileira de Medicina. 2010;67(9):319-325.
Garcia y Narvaiza D, Navarrete MA, Falzoni R, et al. Effect of combined oral contraceptives on breast epithelial proliferation in young women. Breast J. 2008;14(5):450-5. [pmid: 18657146].
Genkinger JM, Hunter DJ, Spiegelman D, et al. Alcohol intake and ovarian cancer risk: a pooled analysis of 10 cohort studies. Br J Cancer. 2006;94(5):757-62. [pmid: 16495916].
Gerhardsson de Verdier M, London S. Reproductive factors, exogenous female hormones, and colorectal cancer by subsite. Cancer Causes Control. 1992;3(4):355-60. [pmid: 1617123].
Gerlinger C, Endrikat J, Kallischnigg G, et al. Evaluation of menstrual bleeding patterns: a new proposal for a universal guideline based on the analysis of more than 4500 bleeding diaries. Eur J Contracept Reprod Health Care. 2007;12(3):203-11. [pmid: 17763258].
Gollnick H, Albring M, Brill K. The efficacy of oral cyproterone acetate in combination with ethinyloestradiol in acne tarda of the facial type. Journal of Dermatological Treatment. 1998;9(2):71-79.
Graham CA, Sherwin BB. A prospective treatment study of premenstrual symptoms using a triphasic oral contraceptive. J Psychosom Res. 1992;36(3):257-66. [pmid: 1564678].
Griesinger G, Kolibianakis EM, Venetis C, et al. Oral contraceptive pretreatment significantly reduces ongoing pregnancy likelihood in gonadotropin-releasing hormone antagonist cycles: an updated meta-analysis. Fertil Steril. 2010;94(6):2382-4. [pmid: 20537631].
Griesinger G, Venetis CA, Marx T, et al. Oral contraceptive pill pretreatment in ovarian stimulation with GnRH antagonists for IVF: a systematic review and meta-analysis. Fertil Steril. 2008;90(4):1055-63. [pmid: 18054003].
Grimes DA, Jones LB, Lopez LM, et al. Oral contraceptives for functional ovarian cysts. Cochrane Database Syst Rev. 2006;(4):CD006134. [pmid: 17054275].
Grimes DA, Jones LB, Lopez LM, et al. Oral contraceptives for functional ovarian cysts. Cochrane Database Syst Rev. 2009;(2):CD006134. [pmid: 19370628].
Grimes DA, Jones LB, Lopez LM, et al. Oral contraceptives for functional ovarian cysts. Cochrane Database Syst Rev. 2011;(9):CD006134. [pmid: 21901701].
Grimes DA, Lopez LM, Manion C, et al. Cochrane systematic reviews of IUD trials: lessons learned. Contraception. 2007;75(6 Suppl):S55-9. [pmid: 17531618].
Guazzelli CA, Barreiros FA, Barbosa R, et al. Extended regimens of the vaginal contraceptive ring: cycle control. Contraception. 2009;80(5):430-5. [pmid: 19835716].
Guzick DS, Huang LS, Broadman BA, et al. Randomized trial of leuprolide versus continuous oral contraceptives in the treatment of endometriosis-associated pelvic pain. Fertil Steril. 2011;95(5):1568-73. [pmid: 21300339].
Haider A, Shaw JC. Treatment of acne vulgaris. JAMA. 2004;292(6):726-35. [pmid: 15304471].
Halbreich U. Selective serotonin reuptake inhibitors and initial oral contraceptives for the treatment of PMDD: effective but not enough. CNS Spectr. 2008;13(7):566-72. [pmid: 18622361].
Harada T, Momoeda M, Taketani Y, et al. Low-dose oral contraceptive pill for dysmenorrhea associated with endometriosis: a placebo-controlled, double-blind, randomized trial. Fertil Steril. 2008;90(5):1583-8. [pmid: 18164001].
Harada T, Momoeda M, Terakawa N, et al. Evaluation of a low-dose oral contraceptive pill for primary dysmenorrhea: a placebo-controlled, double-blind, randomized trial. Fertil Steril. 2011;95(6):1928-31. [pmid: 21420678].
Hendlish SK, Horowicz-Mehler NC, Brixner DI, et al. Contraceptive and noncontraceptive benefits of the LNG-IUS in a vertically integrated HMO. Contraception. 2008;78(1):36-41. [pmid: 18555816].
Hendrix SL, Alexander NJ. Primary dysmenorrhea treatment with a desogestrel-containing low-dose oral contraceptive. Contraception. 2002;66(6):393-9. [pmid: 12499030].
Herrero R, Brinton LA, Reeves WC, et al. Injectable contraceptives and risk of invasive cervical cancer: evidence of an association. Int J Cancer. 1990;46(1):5-7. [pmid: 2163991].
Hickey M, Higham J, Fraser IS. Progestogens versus oestrogens and progestogens for irregular uterine bleeding associated with anovulation. Cochrane Database of Systematic Reviews. 2007;(4):CD001895. [pmid: 17943761].
Hildesheim A, Brinton LA, Mallin K, et al. Barrier and spermicidal contraceptive methods and risk of invasive cervical cancer. Epidemiology. 1990;1(4):266-72. [pmid: 2083303].
Hillbom M, Haapaniemi H, Juvela S, et al. Recent alcohol consumption, cigarette smoking, and cerebral infarction in young adults. Stroke. 1995;26(1):40-5. [pmid: 7839395].
Hillman JB, Miller RJ, Inge TH. Menstrual concerns and intrauterine contraception among adolescent bariatric surgery patients. J Womens Health (Larchmt). 2011;20(4):533-8. [pmid: 21413894].
Hofmeyr GJ, Singata M, Lawrie TA. Copper containing intra-uterine devices versus depot progestogens for contraception. Cochrane Database Syst Rev. 2010;(6):CD007043. [pmid: 20556773].
Hubacher D, Grimes DA. Noncontraceptive health benefits of intrauterine devices: a systematic review. Obstet Gynecol Surv. 2002;57(2):120-8. [pmid: 11832788].
Hubacher D, Lopez L, Steiner MJ, et al. Menstrual pattern changes from levonorgestrel subdermal implants and DMPA: systematic review and evidence-based comparisons. Contraception. 2009;80(2):113-8. [pmid: 19631785].
Hughes E, Brown J, Collins JJ, et al. Ovulation suppression for endometriosis. Cochrane Database Syst Rev. 2007;(3):CD000155. [pmid: 17636607].
Hughes E, Fedorkow D, Collins J, et al. Ovulation suppression for endometriosis. Cochrane Database Syst Rev. 2000;(2):CD000155. [pmid: 10796697].
Hughes E, Fedorkow D, Collins J, et al. Ovulation suppression for endometriosis. Cochrane Database Syst Rev. 2003;(3):CD000155. [pmid: 12917884].
Iyer V, Farquhar C, Jepson R. Oral contraceptive pills for heavy menstrual bleeding. Cochrane Database Syst Rev. 2000;(2):CD000154. [pmid: 10796696].
Jensen JT, Parke S, Mellinger U, et al. Effective treatment of heavy menstrual bleeding with estradiol valerate and dienogest: a randomized controlled trial. Obstet Gynecol. 2011;117(4):777-87. [pmid: 21422847].
Jick SS, Hagberg KW, Kaye JA. ORTHO EVRA(registered trademark) and venous thromboembolism: an update. Contraception. 2010;81(5):452-453. [pmid: 20399954].
Joffe H, Petrillo LF, Viguera AC, et al. Treatment of premenstrual worsening of depression with adjunctive oral contraceptive pills: a preliminary report. J Clin Psychiatry. 2007;68(12):1954-62. [pmid: 18162029].
Johnson N, Farquhar C. Endometriosis. Clin Evid (Online). 2007;2007. pii: 0802. [pmid: 19454060].
Katz HI, Kempers S, Akin MD, et al. Effect of a desogestrel-containing oral contraceptive on the skin. Eur J Contracept Reprod Health Care. 2000;5(4):248-55. [pmid: 11245552].
Kelekci KH, Kelekci S, Yengel I, et al. Cyproterone acetate or drospirenone containing combined oral contraceptives plus spironolactone or cyproterone acetate for hirsutism: Randomized comparison of three regimens. Journal of Dermatological Treatment. 2012;23(3):177-183. [pmid: 21254871].
Kemmeren JM, Algra A, Meijers JC, et al. Effect of second- and third-generation oral contraceptives on fibrinolysis in the absence or presence of the factor V Leiden mutation. Blood Coagul Fibrinolysis. 2002;13(5):373-81. [pmid: 12138364].
Kemmeren JM, Algra A, Meijers JC, et al. Effects of second and third generation oral contraceptives and their respective progestagens on the coagulation system in the absence or presence of the factor V Leiden mutation. Thromb Haemost. 2002;87(2):199-205. [pmid: 11859850].
Kives S, Brown J, Prentice A, et al. Progestagens and anti-progestagens for pain associated with endometriosis. Cochrane Database Syst Rev. 2000;(2):CD002122. [pmid: 10796864].
Knight JA, Lesosky M, Blackmore KM, et al. Ovarian cysts and breast cancer: results from the Women's Contraceptive and Reproductive Experiences Study. Breast Cancer Res Treat. 2008;109(1):157-64. [pmid: 17616808].
Koltun W, Lucky AW, Thiboutot D, et al. Efficacy and safety of 3 mg drospirenone/20 mcg ethinylestradiol oral contraceptive administered in 24/4 regimen in the treatment of acne vulgaris: a randomized, double-blind, placebo-controlled trial. Contraception. 2008;77(4):249-56. [pmid: 18342647].
Koltun W, Maloney JM, Marr J, et al. Treatment of moderate acne vulgaris using a combined oral contraceptive containing ethinylestradiol 20 mug plus drospirenone 3mg administered in a 24/4 regimen: a pooled analysis. Eur J Obstet Gynecol Reprod Biol. 2011;155(2):171-5. [pmid: 21288628].
Kuyoh MA, Toroitich-Ruto C, Grimes DA, et al. Sponge versus diaphragm for contraception. Cochrane Database Syst Rev. 2002;(3):CD003172. [pmid: 12137678].
Kuyoh MA, Toroitich-Ruto C, Grimes DA, et al. Sponge versus diaphragm for contraception: a Cochrane review. Contraception. 2003;67(1):15-8. [pmid: 12521652].
Kwan I, Onwude JL. Premenstrual syndrome. Clin Evid (Online). 2007;2007. pii: 0806. [pmid: 19454075].
La Vecchia C, Negri E, Franceschi S, et al. Long-term impact of reproductive factors on cancer risk. Int J Cancer. 1993;53(2):215-9. [pmid: 8425757].
Lai JN, Wu CT, Chen PC, et al. Increased risk for invasive breast cancer associated with hormonal therapy: a nation-wide random sample of 65,723 women followed from 1997 to 2008. PLoS One. 2011;6(10):e25183. [pmid: 21998640].
Latthe PM, Champaneria R, Khan KS. Dysmenorrhoea. Clin Evid (Online). 2011;2011. pii: 0813. [pmid: 21718556].
Le J, Tsourounis C. Implanon: a critical review. Ann Pharmacother. 2001;35(3):329-36. [pmid: 11261531].
Lello S, Primavera G, Colonna L, et al. Effects of two estroprogestins containing ethynilestradiol 30 microg and drospirenone 3 mg and ethynilestradiol 30 microg and chlormadinone 2 mg on skin and hormonal hyperandrogenic manifestations. Gynecol Endocrinol. 2008;24(12):718-23. [pmid: 19172543].
Lethaby A, Irvine G, Cameron I. Cyclical progestogens for heavy menstrual bleeding. Cochrane Database of Systematic Reviews. 2008;(1).
Leyden J, Shalita A, Hordinsky M, et al. Efficacy of a low-dose oral contraceptive containing 20 microg of ethinyl estradiol and 100 microg of levonorgestrel for the treatment of moderate acne: A randomized, placebo-controlled trial. J Am Acad Dermatol. 2002;47(3):399-409. [pmid: 12196750].
Li CI, Beaber EF, Tang MT, et al. Effect of depo-medroxyprogesterone acetate on breast cancer risk among women 20 to 44 years of age. Cancer Res. 2012;72(8):2028-35. [pmid: 22369929].
Li H, Thomas DB. Tubal ligation and risk of cervical cancer. The World Health Organiztion Collaborative Study of Neoplasia and Steroid Contraceptives. Contraception. 2000;61(5):323-8. [pmid: 10906503].
Lidegaard O, Nielsen LH, Skovlund CW, et al. Venous thrombosis in users of non-oral hormonal contraception: follow-up study, Denmark 2001-10. BMJ. 2012;344:e2990. [pmid: 22577198].
Linet MS, Gridley G, Cnattingius S, et al. Maternal and perinatal risk factors for childhood brain tumors (Sweden). Cancer Causes Control. 1996;7(4):437-48. [pmid: 8813432].
Loerbroks A, Schouten LJ, Goldbohm RA, et al. Alcohol consumption, cigarette smoking, and endometrial cancer risk: results from the Netherlands Cohort Study. Cancer Causes Control. 2007;18(5):551-60. [pmid: 17437180].
London RS. A comparison of levonorgestrel implants with depo-medroxyprogesterone acetate injections for contraception. J SOGC. 1993;15(8):925-8. 32. [pmid: 12318530].
Lopez Laureen M, Kaptein Adrian A, Helmerhorst Frans M. Oral contraceptives containing drospirenone for premenstrual syndrome. Cochrane Database Syst Rev. 2012;(2):CD006586. [pmid: 22336820].
Lopez LM, Tolley EE, Grimes DA, et al. Theory-based interventions for contraception. Cochrane Database Syst Rev. 2009;(1):CD007249. [pmid: 19160330].
Lucky AW, Henderson TA, Olson WH, et al. Effectiveness of norgestimate and ethinyl estradiol in treating moderate acne vulgaris. J Am Acad Dermatol. 1997;37(5 Pt 1):746-54. [pmid: 9366821].
Lucky AW, Koltun W, Thiboutot D, et al. A combined oral contraceptive containing 3-mg drospirenone/20-microg ethinyl estradiol in the treatment of acne vulgaris: a randomized, double-blind, placebo-controlled study evaluating lesion counts and participant self-assessment. Cutis. 2008;82(2):143-50. [pmid: 18792547].
Luisi S, Ciani V, Gabbanini M, et al. Oral contraceptives after myomectomy: a short term trial. Int J Endocrinol. 2009;2009:476897. [pmid: 19946429].
Mabrouk M, Frasca C, Geraci E, et al. Combined oral contraceptive therapy in women with posterior deep infiltrating endometriosis. J Minim Invasive Gynecol. 2011;18(4):470-4. [pmid: 21777836].
MacKenna A, Fabres C, Alam V, et al. Clinical management of functional ovarian cysts: a prospective and randomized study. Hum Reprod. 2000;15(12):2567-9. [pmid: 11098028].
MacLennan AH, MacLennan A, Wenzel S, et al. Continuous low-dose oestrogen and progestogen hormone replacement therapy: a randomised trial. Med J Aust. 1993;159(2):102-6. [pmid: 8336583].
Mainwaring R, Hales HA, Stevenson K, et al. Metabolic parameter, bleeding, and weight changes in U.S. women using progestin only contraceptives. Contraception. 1995;51(3):149-53. [pmid: 7621683].
Maloney JM, Dietze P Jr, Watson D, et al. A randomized controlled trial of a low-dose combined oral contraceptive containing 3 mg drospirenone plus 20 microg ethinylestradiol in the treatment of acne vulgaris: lesion counts, investigator ratings and subject self-assessment. J Drugs Dermatol. 2009;8(9):837-44. [pmid: 19746676].
Maloney JM, Dietze P Jr, Watson D, et al. Treatment of acne using a 3-milligram drospirenone/20-microgram ethinyl estradiol oral contraceptive administered in a 24/4 regimen: a randomized controlled trial. Obstet Gynecol. 2008;112(4):773-81. [pmid: 18827119].
Manchikanti A, Grimes DA, Lopez LM, et al. Steroid hormones for contraception in women with sickle cell disease. Cochrane Database Syst Rev. 2007;(2):CD006261. [pmid: 17443618].
Mansour D, Verhoeven C, Sommer W, et al. Efficacy and tolerability of a monophasic combined oral contraceptive containing nomegestrol acetate and 17beta-oestradiol in a 24/4 regimen, in comparison to an oral contraceptive containing ethinylestradiol and drospirenone in a 21/7 regimen. Eur J Contracept Reprod Health Care. 2011;16(6):430-43. [pmid: 21995590].
Marr J, Niknian M, Shulman LP, et al. Premenstrual dysphoric disorder symptom cluster improvement by cycle with the combined oral contraceptive ethinylestradiol 20 mcg plus drospirenone 3 mg administered in a 24/4 regimen. Contraception. 2011;84(1):81-6. [pmid: 21664515].
Mascarenhas L, van Beek A, Bennink HC, et al. A 2-year comparative study of endometrial histology and cervical cytology of contraceptive implant users in Birmingham, UK. Hum Reprod. 1998;13(11):3057-60. [pmid: 9853856].
McCredie M, Paul C, Skegg DC, et al. Reproductive factors and breast cancer in New Zealand. Int J Cancer. 1998;76(2):182-8. [pmid: 9537578].
McMullen JP, Schooff M. Self-administering emergency hormonal contraception. J Fam Pract. 1998;47(4):252. [pmid: 9841254].
Middleton LJ, Champaneria R, Daniels JP, et al. Hysterectomy, endometrial destruction, and levonorgestrel releasing intrauterine system (Mirena) for heavy menstrual bleeding: systematic review and meta-analysis of data from individual patients. BMJ. 2010;341:c3929. [pmid: 20713583].
Miller L, Verhoeven CH, Hout J. Extended regimens of the contraceptive vaginal ring: a randomized trial. Obstet Gynecol. 2005;106(3):473-82. [pmid: 16135576].
Misra JS, Engineer AD, Das K, et al. Cervical carcinogenesis and contraception. Diagn Cytopathol. 1991;7(4):346-52. [pmid: 1935511].
Moodley JR, Hoffman M, Carrara H, et al. HIV and pre-neoplastic and neoplastic lesions of the cervix in South Africa: a case-control study. BMC Cancer. 2006;6:135. [pmid: 16719902].
Moodley M, Sewart S, Herrington CS, et al. The interaction between steroid hormones, human papillomavirus type 16, E6 oncogene expression, and cervical cancer. Int J Gynecol Cancer. 2003;13(6):834-42. [pmid: 14675321].
Moore J, Kennedy S, Prentice A. Modern combined oral contraceptives for pain associated with endometriosis. Cochrane Database Syst Rev. 2000;(2):CD001019. [pmid: 10796731].
Munro MG, Mainor N, Basu R, et al. Oral medroxyprogesterone acetate and combination oral contraceptives for acute uterine bleeding: a randomized controlled trial. Obstet Gynecol. 2006;108(4):924-9. [pmid: 17012455].
Muzii L, Marana R, Caruana P, et al. Postoperative administration of monophasic combined oral contraceptives after laparoscopic treatment of ovarian endometriomas: a prospective, randomized trial. Am J Obstet Gynecol. 2000;183(3):588-92. [pmid: 10992178].
Mydlo JH, Chawla S, Dorn S, et al. Renal cancer and pregnancy in two different female cohorts. Can J Urol. 2002;9(5):1634-6. [pmid: 12431324].
Naessen S, Carlstrom K, Bystrom B, et al. Effects of an antiandrogenic oral contraceptive on appetite and eating behavior in bulimic women. Psychoneuroendocrinology. 2007;32(5):548-54. [pmid: 17475412].
Negri E, Tzonou A, Beral V, et al. Hormonal therapy for menopause and ovarian cancer in a collaborative re-analysis of European studies. Int J Cancer. 1999;80(6):848-51. [pmid: 10074916].
Nezhat CH, Nezhat F, Borhan S, et al. Is hormonal treatment efficacious in the management of ovarian cysts in women with histories of endometriosis?. Hum Reprod. 1996;11(4):874-7. [pmid: 8671343].
O'Connell K, Davis AR, Kerns J. Oral contraceptives: side effects and depression in adolescent girls. Contraception. 2007;75(4):299-304. [pmid: 17362710].
Ohira T, Folsom AR, Cushman M, et al. Reproductive history, hormone replacement, and incidence of venous thromboembolism: The longitudinal investigation of thromboembolism etiology. British Journal of Haematology. 2010;149(4):606-612. [pmid: 20230397].
Olshan AF, Breslow NE, Falletta JM, et al. Risk factors for Wilms tumor. Report from the National Wilms Tumor Study. Cancer. 1993;72(3):938-44. [pmid: 8392906].
Olshan AF, Smith J, Cook MN, et al. Hormone and fertility drug use and the risk of neuroblastoma: a report from the Children's Cancer Group and the Pediatric Oncology Group. Am J Epidemiol. 1999;150(9):930-8. [pmid: 10547138].
Olson WH, Lippman JS, Robisch DM. The duration of response to norgestimate and ethinyl estradiol in the treatment of acne vulgaris. Int J Fertil Womens Med. 1998;43(6):286-90. [pmid: 9920537].
Osman MF, Black C, Jick S, et al. Previous maternal oral contraception and the risk among subsequent offspring of asthma diagnosis in early childhood. Paediatr Perinat Epidemiol. 2009;23(6):567-73. [pmid: 19840293].
Palombo-Kinne E, Schellschmidt I, Schumacher U, et al. Efficacy of a combined oral contraceptive containing 0.030 mg ethinylestradiol/2 mg dienogest for the treatment of papulopustular acne in comparison with placebo and 0.035 mg ethinylestradiol/2 mg cyproterone acetate. Contraception. 2009;79(4):282-9. [pmid: 19272497].
Parazzini F, Di Cintio E, Chatenoud L, et al. Estroprogestin vs. gonadotrophin agonists plus estroprogestin in the treatment of endometriosis-related pelvic pain: a randomized trial. Gruppo Italiano per lo Studio dell'Endometriosi. Eur J Obstet Gynecol Reprod Biol. 2000;88(1):11-4. [pmid: 10659911].
Parazzini F, La Vecchia C, Negri E, et al. Lifelong menstrual pattern and risk of breast cancer. Oncology. 1993;50(4):222-5. [pmid: 8497374].
Patel P, Lin HC, Feldman SR, et al. Medication choice and associated health care outcomes and costs for patients with acne and acne-related conditions in the United States. J Drugs Dermatol. 2011;10(7):766-71. [pmid: 21720659].
Patton AL, Duncan L, Bloom L, et al. Atypical squamous cells, cannot exclude a high-grade intraepithelial lesion and its clinical significance in postmenopausal, pregnant, postpartum, and contraceptive-use patients. Cancer. 2008;114(6):481-8. [pmid: 18980288].
Paulen ME, Curtis KM. When can a woman have repeat progestogen-only injectables--depot medroxyprogesterone acetate or norethisterone enantate?. Contraception. 2009;80(4):391-408. [pmid: 19751863].
Pearlstein TB, Bachmann GA, Zacur HA, et al. Treatment of premenstrual dysphoric disorder with a new drospirenone-containing oral contraceptive formulation. Contraception. 2005;72(6):414-21. [pmid: 16307962].
Petri M, Kim MY, Kalunian KC, et al. Combined oral contraceptives in women with systemic lupus erythematosus. N Engl J Med. 2005;353(24):2550-8. [pmid: 16354891].
Piya-Anant M, Koetsawang S, Patrasupapong N, et al. Effectiveness of Cyclofem(registered trademark) in the treatment of depot medroxyprogesterone acetate induced amenorrhea. Contraception. 1998;57(1):23-28. [pmid: 9554247].
Plewig G, Cunliffe WJ, Binder N, et al. Efficacy of an oral contraceptive containing EE 0.03 mg and CMA 2 mg (Belara) in moderate acne resolution: a randomized, double-blind, placebo-controlled Phase III trial. Contraception. 2009;80(1):25-33. [pmid: 19501212].
Pomp ER, Lenselink AM, Rosendaal FR, et al. Pregnancy, the postpartum period and prothrombotic defects: risk of venous thrombosis in the MEGA study. J Thromb Haemost. 2008;6(4):632-7. [pmid: 18248600].
Porcile A, Gallardo E, Onetto P, et al. Very low estrogen-desogestrel contraceptive in perimenopausal hormonal replacement. Maturitas. 1994;18(2):93-103. [pmid: 8177098].
Power J, French R, Cowan F. Subdermal implantable contraceptives versus other forms of reversible contraceptives or other implants as effective methods of preventing pregnancy. Cochrane Database Syst Rev. 2007;(3):CD001326. [pmid: 17636668].
Power J, French R, Cowan Frances M. Subdermal implantable contraceptives versus other forms of reversible contraceptives or other implants as effective methods for preventing pregnancy. 2007;(3):CD001326.
Pradat P. A case-control study of major congenital heart defects in Sweden--1981-1986. Eur J Epidemiol. 1992;8(6):789-96. [pmid: 1294383].
Proctor ML, Farquhar CM. Dysmenorrhoea. Clin Evid (Online). 2007. [pmid: 19454059].
Proctor ML, Roberts H, Farquhar CM. Combined oral contraceptive pill (OCP) as treatment for primary dysmenorrhoea. Cochrane Database Syst Rev. 2001;(4):CD002120. [pmid: 11687142].
Puumala SE, Ross JA, Olshan AF, et al. Reproductive history, infertility treatment, and the risk of acute leukemia in children with down syndrome: a report from the Children's Oncology Group. Cancer. 2007;110(9):2067-74. [pmid: 17849462].
Raine TR, Foster-Rosales A, Upadhyay UD, et al. One-year contraceptive continuation and pregnancy in adolescent girls and women initiating hormonal contraceptives. Obstetrics and Gynecology. 2011;117(2 PART 1):363-371. [pmid: 21252751].
Razzi S, Luisi S, Ferretti C, et al. Use of a progestogen only preparation containing desogestrel in the treatment of recurrent pelvic pain after conservative surgery for endometriosis. Eur J Obstet Gynecol Reprod Biol. 2007;135(2):188-90. [pmid: 16963174].
Redmond G, Godwin AJ, Olson W, et al. Use of placebo controls in an oral contraceptive trial: methodological issues and adverse event incidence. Contraception. 1999;60(2):81-5. [pmid: 10592854].
Redmond GP, Olson WH, Lippman JS, et al. Norgestimate and ethinyl estradiol in the treatment of acne vulgaris: a randomized, placebo-controlled trial. Obstet Gynecol. 1997;89(4):615-22. [pmid: 9083323].
Rickenlund A, Eriksson MJ, Schenck-Gustafsson K, et al. Oral contraceptives improve endothelial function in amenorrheic athletes. J Clin Endocrinol Metab. 2005;90(6):3162-7. [pmid: 15769986].
Rookus MA, van Leeuwen FE. Induced abortion and risk for breast cancer: reporting (recall) bias in a Dutch case-control study. J Natl Cancer Inst. 1996;88(23):1759-64. [pmid: 8944006].
Rosen MP, Breitkopf DM, Nagamani M. A randomized controlled trial of second- versus third-generation oral contraceptives in the treatment of acne vulgaris. Am J Obstet Gynecol. 2003;188(5):1158-60. [pmid: 12748463].
Rosenblatt KA, Gao DL, Ray RM, et al. Monthly injectable contraceptives and the risk of all cancers combined and site-specific cancers in Shanghai. Contraception. 2007;76(1):40-4. [pmid: 17586135].
Rowan JP, Simon JA, Speroff L, et al. Effects of low-dose norethindrone acetate plus ethinyl estradiol (0.5 mg/2.5 microg) in women with postmenopausal symptoms: updated analysis of three randomized, controlled trials. Clin Ther. 2006;28(6):921-32. [pmid: 16860174].
Ruan X, Seeger H, Mueck AO. Breast cancer risk during hormone therapy: experimental versus clinical data. Minerva Endocrinol. 2012;37(1):59-74. [pmid: 22382615].
Saadatnia M, Naghavi N, Fatehi F, et al. Oral contraceptive misuse as a risk factor for cerebral venous and sinus thrombosis. Journal of Research in Medical Sciences. 2012;17(6):344-347. [pmid: 23267395].
Sanam M, Ziba O. Desogestrel+ethinylestradiol versus levonorgestrel+ethinylestradiol. Which one has better affect on acne, hirsutism, and weight change. Saudi Med J. 2011;32(1):23-6. [pmid: 21212911].
Sanersak S, Wattanakumtornkul S, Korsakul C. Comparison of low-dose monophasic oral contraceptive pills and expectant management in treatment of functional ovarian cysts. J Med Assoc Thai. 2006;89(6):741-7. [pmid: 16850671].
Schildkraut JM, Schwingl PJ, Bastos E, et al. Epithelial ovarian cancer risk among women with polycystic ovary syndrome. Obstet Gynecol. 1996;88(4 Pt 1):554-9. [pmid: 8841217].
Schroder AK, Diedrich K, Ludwig M. Medical management of endometriosis: a systematic review. IDrugs. 2004;7(5):451-63. [pmid: 15154107].
Schuz J, Kaletsch U, Meinert R, et al. Risk factors for neuroblastoma at different stages of disease. Results from a population-based case-control study in Germany. J Clin Epidemiol. 2001;54(7):702-9. [pmid: 11438411].
Seaman HE, de Vries CS, Farmer RD. The risk of venous thromboembolism in women prescribed cyproterone acetate in combination with ethinyl estradiol: a nested cohort analysis and case-control study. Hum Reprod. 2003;18(3):522-6. [pmid: 12615818].
Seaman HE, de Vries CS, Farmer RD. Venous thromboembolism associated with cyproterone acetate in combination with ethinyloestradiol (Dianette): observational studies using the UK General Practice Research Database. Pharmacoepidemiol Drug Saf. 2004;13(7):427-36. [pmid: 15269926].
Secura GM, Allsworth JE, Madden T, et al. The Contraceptive CHOICE Project: reducing barriers to long-acting reversible contraception. Am J Obstet Gynecol. 2010;203(2):115 e1-7. [pmid: 20541171].
Seeman E, Szmukler GI, Formica C, et al. Osteoporosis in anorexia nervosa: the influence of peak bone density, bone loss, oral contraceptive use, and exercise. J Bone Miner Res. 1992;7(12):1467-74. [pmid: 1481732].
Seracchioli R, Mabrouk M, Frasca C, et al. Long-term cyclic and continuous oral contraceptive therapy and endometrioma recurrence: a randomized controlled trial. Fertil Steril. 2010;93(1):52-6. [pmid: 18973896].
Seracchioli R, Mabrouk M, Frasca C, et al. Long-term oral contraceptive pills and postoperative pain management after laparoscopic excision of ovarian endometrioma: a randomized controlled trial. Fertil Steril. 2010;94(2):464-71. [pmid: 19442968].
Seracchioli R, Mabrouk M, Manuzzi L, et al. Post-operative use of oral contraceptive pills for prevention of anatomical relapse or symptom-recurrence after conservative surgery for endometriosis. Hum Reprod. 2009;24(11):2729-35. [pmid: 19625310].
Sesti F, Capozzolo T, Pietropolli A, et al. Recurrence rate of endometrioma after laparoscopic cystectomy: a comparative randomized trial between post-operative hormonal suppression treatment or dietary therapy vs. placebo. Eur J Obstet Gynecol Reprod Biol. 2009;147(1):72-7. [pmid: 19665279].
Sesti F, Pietropolli A, Capozzolo T, et al. Hormonal suppression treatment or dietary therapy versus placebo in the control of painful symptoms after conservative surgery for endometriosis stage III-IV. A randomized comparative trial. Fertil Steril. 2007;88(6):1541-7. [pmid: 17434511].
Shantakumar S, Terry MB, Teitelbaum SL, et al. Reproductive factors and breast cancer risk among older women. Breast Cancer Res Treat. 2007;102(3):365-74. [pmid: 17033925].
Shaw RW, Symonds IM, Tamizian O, et al. Randomised comparative trial of thermal balloon ablation and levonorgestrel intrauterine system in patients with idiopathic menorrhagia. Aust N Z J Obstet Gynaecol. 2007;47(4):335-40. [pmid: 17627692].
Shulman LP. A review of drospirenone for safety and tolerability and effects on endometrial safety and lipid parameters contrasted with medroxyprogesterone acetate, levonorgestrel, and micronized progesterone. J Womens Health (Larchmt). 2006;15(5):584-90. [pmid: 16796485].
Skegg DC, Noonan EA, Paul C, et al. Depot medroxyprogesterone acetate and breast cancer A pooled analysis of the World Health Organization and New Zealand studies. JAMA. 1995;273(10):799-804. [pmid: 7861575].
Spicer DV, Ursin G, Parisky YR, et al. Changes in mammographic densities induced by a hormonal contraceptive designed to reduce breast cancer risk. J Natl Cancer Inst. 1994;86(6):431-6. [pmid: 8120917].
Steiner MJ, Dalebout S, Condon S, et al. Understanding risk: a randomized controlled trial of communicating contraceptive effectiveness. Obstet Gynecol. 2003;102(4):709-17. [pmid: 14551000].
Steiner MJ, Lopez LM, Grimes DA, et al. Sino-implant (II)--a levonorgestrel-releasing two-rod implant: systematic review of the randomized controlled trials. Contraception. 2010;81(3):197-201. [pmid: 20159174].
Strom BL, Berlin JA, Weber AL, et al. Absence of an effect of injectable and implantable progestin-only contraceptives on subsequent risk of breast cancer. Contraception. 2004;69(5):353-60. [pmid: 15105056].
Strowitzki T, Faustmann T, Gerlinger C, et al. Dienogest in the treatment of endometriosis-associated pelvic pain: a 12-week, randomized, double-blind, placebo-controlled study. Eur J Obstet Gynecol Reprod Biol. 2010;151(2):193-8. [pmid: 20444534].
Strowitzki T, Marr J, Gerlinger C, et al. Dienogest is as effective as leuprolide acetate in treating the painful symptoms of endometriosis: a 24-week, randomized, multicentre, open-label trial. Hum Reprod. 2010;25(3):633-41. [pmid: 20089522].
Sweeney C, Baumgartner KB, Byers T, et al. Reproductive history in relation to breast cancer risk among Hispanic and non-Hispanic white women. Cancer Causes Control. 2008;19(4):391-401. [pmid: 18080775].
Tan JKL, Ediriweera C. Efficacy and safety of combined ethinyl estradiol/drospirenone oral contraceptives in the treatment of acne. International Journal of Women's Health. 2009;1(1):213-221.
Taner C, Inal M, Basogul O, et al. Comparison of the clinical efficacy and safety of flutamide versus flutamide plus an oral contraceptive in the treatment of hirsutism. Gynecol Obstet Invest. 2002;54(2):105-8. [pmid: 12566753].
Taskin O, Young DC, Mangal R, et al. Prevention and treatment of ovarian cysts with oral contraceptives: A prospective randomized study. Journal of Gynecologic Surgery. 1996;12(1):21-24.
Thiboutot D, Archer DF, Lemay A, et al. A randomized, controlled trial of a low-dose contraceptive containing 20 microg of ethinyl estradiol and 100 microg of levonorgestrel for acne treatment. Fertil Steril. 2001;76(3):461-8. [pmid: 11532465].
Thomas DB, Ye Z, Ray RM. Cervical carcinoma in situ and use of depot-medroxyprogesterone acetate (DMPA). WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Contraception. 1995;51(1):25-31. [pmid: 7750280].
Thorneycroft H, Gollnick H, Schellschmidt I. Superiority of a combined contraceptive containing drospirenone to a triphasic preparation containing norgestimate in acne treatment. Cutis. 2004;74(2):123-30. [pmid: 15379365].
Thorneycroft IH, Stanczyk FZ, Bradshaw KD, et al. Effect of low-dose oral contraceptives on androgenic markers and acne. Contraception. 1999;60(5):255-62. [pmid: 10717776].
Titus-Ernstoff L, Hatch EE, Hoover RN, et al. Long-term cancer risk in women given diethylstilbestrol (DES) during pregnancy. Br J Cancer. 2001;84(1):126-33. [pmid: 11139327].
Tokushige N, Markham R, Russell P, et al. Effect of progestogens and combined oral contraceptives on nerve fibers in peritoneal endometriosis. Fertil Steril. 2009;92(4):1234-9. [pmid: 18976764].
Turan C, Zorlu CG, Ugur M, et al. Expectant management of functional ovarian cysts: an alternative to hormonal therapy. Int J Gynaecol Obstet. 1994;47(3):257-60. [pmid: 7705531].
Udoff L, Langenberg P, Adashi EY. Combined continuous hormone replacement therapy: a critical review. Obstet Gynecol. 1995;86(2):306-16. [pmid: 7617369].
Urbancsek J. An integrated analysis of nonmenstrual adverse events with Implanon. Contraception. 10. 1998;58(6 Suppl):9S-115S. [pmid: 9807687].
van Hylckama Vlieg A, Helmerhorst FM, Rosendaal FR. The risk of deep venous thrombosis associated with injectable depot-medroxyprogesterone acetate contraceptives or a levonorgestrel intrauterine device. Arterioscler Thromb Vasc Biol. 2010;30(11):2297-300. [pmid: 20798377].
van Vloten WA, Sigurdsson V. Selecting an oral contraceptive agent for the treatment of acne in women. Am J Clin Dermatol. 2004;5(6):435-41. [pmid: 15663340].
van Vloten WA, van Haselen CW, van Zuuren EJ, et al. The effect of 2 combined oral Contraceptives containing either drospirenone or cyproterone acetate on acne and seborrhea. Cutis. 2002;69(4 Suppl):2-15. [pmid: 12096825].
Vartiainen M, de Gezelle H, Broekmeulen CJ. Comparison of the effect on acne with a combiphasic desogestrel-containing oral contraceptive and a preparation containing cyproterone acetate. Eur J Contracept Reprod Health Care. 2001;6(1):46-53. [pmid: 11334476].
Vegetti W, Testa G, Maggioni P, et al. An open randomized comparative study of an oral contraceptive containing ethinyl estradiol and cyproterone acetate with and without the GnRH analogue goserelin in the long-term treatment of hirsutism. Gynecol Obstet Invest. 1996;41(4):260-8. [pmid: 8793497].
Verbost PM, Hanssen RG, Korver GH, et al. ORG 33628 and ORG 31710 to control vaginal bleeding in progestin-only contraceptive regimens. Semin Reprod Med. 2005;23(1):101-11. [pmid: 15714394].
Vercellini P, Crosignani PG, Somigliana E, et al. Medical treatment for rectovaginal endometriosis: what is the evidence?. Hum Reprod. 2009;24(10):2504-14. [pmid: 19574277].
Vercellini P, De Giorgi O, Mosconi P, et al. Cyproterone acetate versus a continuous monophasic oral contraceptive in the treatment of recurrent pelvic pain after conservative surgery for symptomatic endometriosis. Fertil Steril. 2002;77(1):52-61. [pmid: 11779591].
Vercellini P, De Giorgi O, Oldani S, et al. Depot medroxyprogesterone acetate versus an oral contraceptive combined with very-low-dose danazol for long-term treatment of pelvic pain associated with endometriosis. Am J Obstet Gynecol. 1996;175(2):396-401. [pmid: 8765259].
Vercellini P, Pietropaolo G, De Giorgi O, et al. Treatment of symptomatic rectovaginal endometriosis with an estrogen-progestogen combination versus low-dose norethindrone acetate. Fertil Steril. 2005;84(5):1375-87. [pmid: 16275232].
Vercellini P, Trespidi L, Colombo A, et al. A gonadotropin-releasing hormone agonist versus a low-dose oral contraceptive for pelvic pain associated with endometriosis. Fertil Steril. 1993;60(1):75-9. [pmid: 8513962].
von Schoultz B. Clinical efficacy and safety of combined estradiol valerate and dienogest: a new no-bleed treatment. Climacteric. Suppl 2. 2003;6:24-32. [pmid: 14669841].
Wan YL, Holland C. The efficacy of levonorgestrel intrauterine systems for endometrial protection: a systematic review. Climacteric. 2011;14(6):622-32. [pmid: 22017273].
Weisberg E, Hickey M, Palmer D, et al. A pilot study to assess the effect of three short-term treatments on frequent and/or prolonged bleeding compared to placebo in women using. Implanon Hum Reprod. 2006;21(1):295-302. [pmid: 16284061].
West CP. Inhibition of ovulation with oral progestins--effectiveness in premenstrual syndrome. Eur J Obstet Gynecol Reprod Biol. 1990;34(1-2):119-28. [pmid: 2303145].
Whiteman MK, Zapata LB, Tepper NK, et al. Use of contraceptive methods among women with endometrial hyperplasia: a systematic review. Contraception. 2010;82(1):56-63. [pmid: 20682143].
Wishart JM. An open study of Triphasil and Diane 50 in the treatment of acne. Australas J Dermatol. 1991;32(1):51-4. [pmid: 1834045].
Wong CL, Farquhar C, Roberts H, et al. Oral contraceptive pill as treatment for primary dysmenorrhoea. Cochrane Database Syst Rev. 2009;(2):CD002120. [pmid: 19370576].
Wong CL, Farquhar C, Roberts H, et al. Oral contraceptive pill for primary dysmenorrhoea. Cochrane Database Syst Rev. 2009;(4):CD002120. [pmid: 19821293].
Wong WSF, Lim CED. Hormonal treatment for endometriosis associated pelvic pain. Iranian Journal of Reproductive Medicine. 2011;9(3):163-170.
Worret I, Arp W, Zahradnik HP, et al. Acne resolution rates: results of a single-blind, randomized, controlled, parallel phase III trial with EE/CMA (Belara) and EE/LNG (Microgynon). Dermatology. 2001;203(1):38-44. [pmid: 11549798].
Wu-Williams AH, Lee M, Whittemore AS, et al. Reproductive factors and colorectal cancer risk among Chinese females. Cancer Res. 1991;51(9):2307-11. [pmid: 2015594].
Young RL, Snabes MC, Frank ML, et al. A randomized, double-blind, placebo-controlled comparison of the impact of low-dose and triphasic oral contraceptives on follicular development. Am J Obstet Gynecol. 1992;167(3):678-82. [pmid: 1530022].
Yuen J, Persson I, Bergkvist L, et al. Hormone replacement therapy and breast cancer mortality in Swedish women: results after adjustment for ‘healthy drug-user’ effect. Cancer Causes Control. 1993;4(4):369-74. [pmid: 8394149].
Zapata LB, Whiteman MK, Marchbanks PA, et al. Intrauterine device use among women with ovarian cancer: a systematic review. Contraception. 2010;82(1):38-40. [pmid: 20682141].
Ziaei S, Rajaei L, Faghihzadeh S, et al. Comparative study and evaluation of side effects of low-dose contraceptive pills administered by the oral and vaginal route. Contraception. 2002;65(5):329-31. [pmid: 12057783].

## Does not provide a description of either OC formulation or length of OC use (not required for studies reporting ovarian cancer outcomes or conducted in a population taking OCs for primary prevention of ovarian cancer)

Abdollahi M, Cushman M, Rosendaal FR. Obesity: risk of venous thrombosis and the interaction with coagulation factor levels and oral contraceptive use. Thromb Haemost. 2003;89(3):493-8. [pmid: 12624633].
Abdul-Samad AA, Al-Kamil EA, Al-Sodani AH. Breast cancer and selected lifestyle variables: A case-control study. Bahrain Medical Bulletin. 2009;31(4).
Akhter M, Inoue M, Kurahashi N, et al. Reproductive factors, exogenous female hormone use and colorectal cancer risk: the Japan Public Health Center-based Prospective Study. Eur J Cancer Prev. 2008;17(6):515-24. [pmid: 18941373].
Albucher JF, Ferrieres J, Ruidavets JB, et al. Serum lipids in young patients with ischaemic stroke: a case-control study. J Neurol Neurosurg Psychiatry. 2000;69(1):29-33. [pmid: 10864600].
Althuis MD, Fergenbaum JH, Garcia-Closas M, et al. Etiology of hormone receptor-defined breast cancer: a systematic review of the literature. Cancer Epidemiol Biomarkers Prev. 2004;13(10):1558-68. [pmid: 15466970].
Altshuler LL, Hendrick V, Parry B. Pharmacological management of premenstrual disorder. Harv Rev Psychiatry. 1995;2(5):233-45. [pmid: 9384908].
Ambrosone CB, Moysich KB, Furberg H, et al. CYP17 genetic polymorphism, breast cancer, and breast cancer risk factors. Breast Cancer Res. 2003;5(2):R45-51. [pmid: 12631398].
Andersson HM, Siegerink B, Luken BM, et al. High VWF, low ADAMTS13, and oral contraceptives increase the risk of ischemic stroke and myocardial infarction in young women. Blood. 2012;119(6):1555-60. [pmid: 22110247].
Aznar J, Mira Y, Vaya A, et al. Factor V Leiden and prothrombin G20210A mutations in young adults with cryptogenic ischemic stroke. Thromb Haemost. 2004;91(5):1031-4. [pmid: 15116266].
Aznar J, Vaya A, Estelles A, et al. Risk of venous thrombosis in carriers of the prothrombin G20210A variant and factor V Leiden and their interaction with oral contraceptives. Haematologica. 2000;85(12):1271-6. [pmid: 11114134].
Baccarelli A, Martinelli I, Zanobetti A, et al. Exposure to particulate air pollution and risk of deep vein thrombosis. Arch Intern Med. 2008;168(9):920-7. [pmid: 18474755].
Beji NK, Reis N. Risk factors for breast cancer in Turkish women: a hospital-based case-control study. Eur J Cancer Care (Engl). 2007;16(2):178-84. [pmid: 17371428].
Benshushan A, Paltiel O, Rojansky N, et al. IUD use and the risk of endometrial cancer. Eur J Obstet Gynecol Reprod Biol. 2002;105(2):166-9. [pmid: 12381481].
Bernatsky S, Clarke A, Ramsey-Goldman R, et al. Hormonal exposures and breast cancer in a sample of women with systemic lupus erythematosus. Rheumatology (Oxford). 2004;43(9):1178-81. [pmid: 15226516].
Binder B, Lackner HK, Salmhofer W, et al. Risk factors for deep vein thrombosis in women aged 18 to 50: a retrospective analysis. Dermatol Surg. 2009;35(3):451-6. [pmid: 19243404].
Bloemenkamp KW, Helmerhorst FM, Rosendaal FR, et al. Venous thrombosis, oral contraceptives and high factor VIII levels. Thromb Haemost. 1999;82(3):1024-7. [pmid: 10494758].
Bombeli T, Basic A, Fehr J. Prevalence of hereditary thrombophilia in patients with thrombosis in different venous systems. Am J Hematol. 2002;70(2):126-32. [pmid: 12111785].
Bostick RM, Potter JD, Kushi LH, et al. Sugar, meat, and fat intake, and non-dietary risk factors for colon cancer incidence in Iowa women (United States). Cancer Causes Control. 1994;5(1):38-52. [pmid: 8123778].
Brinton LA, Barrett RJ, Berman ML, et al. Cigarette smoking and the risk of endometrial cancer. Am J Epidemiol. 1993;137(3):281-91. [pmid: 8452136].
Brouwer JL, Veeger NJ, Kluin-Nelemans HC, et al. The pathogenesis of venous thromboembolism: evidence for multiple interrelated causes. Ann Intern Med. 2006;145(11):807-15. [pmid: 17146065].
Budai B, Szamel I, Sulyok Z, et al. Characteristics of cystic breast disease with special regard to breast cancer development. Anticancer Res. 2001;21(1B):749-52. [pmid: 11299838].
Butterworth CE Jr, Hatch KD, Macaluso M, et al. Folate deficiency and cervical dysplasia. JAMA. 1992;267(4):528-33. [pmid: 1729576].
Cannegieter SC, Doggen CJ, van Houwelingen HC, et al. Travel-related venous thrombosis: results from a large population-based case control study (MEGA study). PLoS Med. 2006;3(8):e307. [pmid: 16933962].
Chan KT, Tye GA, Popat RA, et al. Common iliac vein stenosis: a risk factor for oral contraceptive-induced deep vein thrombosis. Am J Obstet Gynecol. 2011;205(6):537 e1-6. [pmid: 21893308].
Chang CK, Astrakianakis G, Thomas DB, et al. Occupational exposures and risks of liver cancer among Shanghai female textile workers--a case-cohort study. Int J Epidemiol. 2006;35(2):361-9. [pmid: 16373377].
Charneco E, Ortiz AP, Venegas-Rios HL, et al. Clinic-based case-control study of the association between body mass index and endometrial cancer in Puerto Rican women. P R Health Sci J. 2010;29(3):272-8. [pmid: 20799515].
Chaudary MA, Hayward JL, Bulbrook RD, et al. A comparison of epidemiological characteristics in breast cancer patients and normal women in Great Britain and Japan: results of a prospective study. Breast Cancer Res Treat. Suppl 1. 1991;18:S19-22. [pmid: 1873552].
Chen Y, Pei J. Factors influencing the association between CYP17 T34C polymorphism and the risk of breast cancer: meta-regression and subgroup analysis. Breast Cancer Res Treat. 2010;122(2):471-81. [pmid: 20043206].
Chen Y, Pei J. Possible risk modifications in the association between MnSOD Ala-9Val polymorphism and breast cancer risk: subgroup analysis and evidence-based sample size calculation for a future trial. Breast Cancer Res Treat. 2011;125(2):495-504. [pmid: 20567899].
Colditz GA, Rosner BA, Speizer FE. Risk factors for breast cancer according to family history of breast cancer. For the Nurses' Health Study Research Group. J Natl Cancer Inst. 1996;88(6):365-71. [pmid: 8609646].
Cooper D, Hoffman M, Carrara H, et al. Determinants of sexual activity and its relation to cervical cancer risk among South African women. BMC Public Health. 2007;7:341. [pmid: 18042284].
Cronin-Fenton DP, Murray LJ, Whiteman DC, et al. Reproductive and sex hormonal factors and oesophageal and gastric junction adenocarcinoma: a pooled analysis. Eur J Cancer. 2010;46(11):2067-76. [pmid: 20456945].
Dayan N, Holcroft CA, Tagalakis V. The risk of venous thrombosis, including cerebral vein thrombosis, among women with thrombophilia and oral contraceptive use: A meta-analysis. Clinical and Applied Thrombosis/Hemostasis. 2011;17(6):E141-E152. [pmid: 21220364].
de Bruijn SF, Stam J, Koopman MM, et al. Case-control study of risk of cerebral sinus thrombosis in oral contraceptive users and in [correction of who are] carriers of hereditary prothrombotic conditions. The Cerebral Venous Sinus Thrombosis Study Group. BMJ. 1998;316(7131):589-92. [pmid: 9518910].
de Visser MC, Poort SR, Vos HL, et al. Factor X levels, polymorphisms in the promoter region of factor X, and the risk of venous thrombosis. Thromb Haemost. 2001;85(6):1011-7. [pmid: 11434677].
Delgado-Rodriguez M, Sillero-Arenas M, Martin-Moreno JM, et al. Oral contraceptives and cancer of the cervix uteri. A meta-analysis. Acta Obstet Gynecol Scand. 1992;71(5):368-76. [pmid: 1326213].
Dentali F, Crowther M, Ageno W. Thrombophilic abnormalities, oral contraceptives, and risk of cerebral vein thrombosis: a meta-analysis. Blood. 2006;107(7):2766-73. [pmid: 16397131].
Di Cintio E, Parazzini F, Tozzi L, et al. Dietary habits, reproductive and menstrual factors and risk of dysmenorrhoea. Eur J Epidemiol. 1997;13(8):925-30. [pmid: 9476823].
Ehrenforth S, Nemes L, Mannhalter C, et al. Impact of environmental and hereditary risk factors on the clinical manifestation of thrombophilia in homozygous carriers of factor V:G. 1691A. J Thromb Haemost. 2004;2(3):430-6. [pmid: 15009459].
Emmerich J, Rosendaal FR, Cattaneo M, et al. Combined effect of factor V Leiden and prothrombin 20210A on the risk of venous thromboembolism--pooled analysis of 8 case-control studies including 2310 cases and 3204 controls. Study Group for Pooled-Analysis in Venous Thromboembolism. Thromb Haemost. 2001;86(3):809-16. [pmid: 11583312].
Epplein M, Reed SD, Voigt LF, et al. Endometrial hyperplasia risk in relation to recent use of oral contraceptives and hormone therapy. Ann Epidemiol. 2009;19(1):1-7. [pmid: 19064186].
Etminan M, Takkouche B, Isorna FC, et al. Risk of ischaemic stroke in people with migraine: systematic review and meta-analysis of observational studies. BMJ. 2005;330(7482):63. [pmid: 15596418].
Feigin VL, Rinkel GJ, Lawes CM, et al. Risk factors for subarachnoid hemorrhage: an updated systematic review of epidemiological studies. Stroke. 2005;36(12):2773-80. [pmid: 16282541].
Flinterman LE, Van Hylckama Vlieg A, Rosendaal FR, et al. Venous thrombosis of the upper extremity: Effect of blood group and coagulation factor levels on risk. British Journal of Haematology. 2010;149(1):118-123. [pmid: 20096009].
Gammon MD, Schoenberg JB, Teitelbaum SL, et al. Cigarette smoking and breast cancer risk among young women (United States). Cancer Causes Control. 1998;9(6):583-90. [pmid: 10189043].
Gefeller O, Hassan K, Wille L. Cutaneous malignant melanoma in women and the role of oral contraceptives. Br J Dermatol. 1998;138(1):122-4. [pmid: 9536234].
Ghiasvand R, Maram ES, Tahmasebi S, et al. Risk factors for breast cancer among young women in southern Iran. Int J Cancer. 2010. [pmid: 21064105].
Gillanders WE, Simon Jr PO. Oral contraceptive use and the risk of early-onset breast cancer in carriers and noncarriers of BRCA1 and BRCA2 mutations. Women's Oncology Review. 2005;5(2):127-128.
Granella F, Sances G, Pucci E, et al. Migraine with aura and reproductive life events: a case control study. Cephalalgia. 2000;20(8):701-7. [pmid: 11167898].
Haapaniemi H, Hillbom M, Juvela S. Lifestyle-associated risk factors for acute brain infarction among persons of working age. Stroke. 1997;28(1):26-30. [pmid: 8996483].
Hadjisavvas A, Loizidou MA, Middleton N, et al. An investigation of breast cancer risk factors in Cyprus: A case control study. BMC Cancer. 2010;10:447. [pmid: 20727220].
Haile RW, Witte JS, Ursin G, et al. A case-control study of reproductive variables, alcohol, and smoking in premenopausal bilateral breast cancer. Breast Cancer Res Treat. 1996;37(1):49-56. [pmid: 8750527].
Hemminki E, Luostarinen T, Pukkala E, et al. Oral contraceptive use before first birth and risk of breast cancer: A case control study. BMC Women's Health. 2002;2(1):9. [pmid: 12160467].
Hippisley-Cox J, Coupland C. Development and validation of risk prediction algorithm (QThrombosis) to estimate future risk of venous thromboembolism: prospective cohort study. BMJ. 2011;343:d4656. [pmid: 21846713].
Jhawar BS, Fuchs CS, Colditz GA, et al. Sex steroid hormone exposures and risk for meningioma. J Neurosurg. 2003;99(5):848-53. [pmid: 14609164].
Kamarudin R, Shah SA, Hidayah N. Lifestyle factors and breast cancer: a case-control study in Kuala Lumpur, Malaysia. Asian Pac J Cancer Prev. 2006;7(1):51-4. [pmid: 16629515].
Katerndahl DA, Realini JP, Cohen PA. Oral contraceptive use and cardiovascular disease: is the relationship real or due to study bias?. J Fam Pract. 1992;35(2):147-57. [pmid: 1386621].
Kisjanto J, Bonneux L, Prihartono J, et al. Risk factors for stroke among urbanised Indonesian women of reproductive age: a hospital-based case-control study. Cerebrovasc Dis. 2005;19(1):18-22. [pmid: 15528880].
Kuipers S, Cannegieter SC, Doggen CJ, et al. Effect of elevated levels of coagulation factors on the risk of venous thrombosis in long-distance travelers. Blood. 2009;113(9):2064-9. [pmid: 19029445].
Kuipers S, Cannegieter SC, Middeldorp S, et al. The absolute risk of venous thrombosis after air travel: a cohort study of 8,755 employees of international organisations. PLoS Med. 2007;4(9):e290. [pmid: 17896862].
Kuru B, Ozaslan C, Ozdemir P, et al. Risk factors for breast cancer in Turkish women with early pregnancies and long-lasting lactation--a case-control study. Acta Oncol. 2002;41(6):556-61. [pmid: 12546529].
Kwan ML, Kushi LH, Weltzien E, et al. Epidemiology of breast cancer subtypes in two prospective cohort studies of breast cancer survivors. Breast Cancer Res. 2009;11(3):R31. [pmid: 19463150].
Kyrle PA, Minar E, Bialonczyk C, et al. The risk of recurrent venous thromboembolism in men and women. N Engl J Med. 2004;350(25):2558-63. [pmid: 15201412].
La Vecchia C, D'Avanzo B, Franceschi S, et al. Menstrual and reproductive factors and gastric-cancer risk in women. Int J Cancer. 1994;59(6):761-4. [pmid: 7989115].
La Vecchia C, Negri E, Franceschi S, et al. Reproductive factors and the risk of hepatocellular carcinoma in women. Int J Cancer. 1992;52(3):351-4. [pmid: 1328066].
Lam CM, Yong JL, Chan AO, et al. Better survival in female patients with hepatocellular carcinoma: oral contraceptive pills related?. J Clin Gastroenterol. 2005;39(6):533-9. [pmid: 15942442].
Langevin SM, Grandis JR, Taioli E. Female hormonal and reproductive factors and head and neck squamous cell carcinoma risk. Cancer Lett. 2011;310(2):216-21. [pmid: 21802839].
Latthe P, Mignini L, Gray R, et al. Factors predisposing women to chronic pelvic pain: systematic review. BMJ. 2006;332(7544):749-55. [pmid: 16484239].
Libourel EJ, ten Kate MK, Brouwer JL, et al. Contribution of multiple thrombophilic and transient risk factors in the development of cerebral venous thrombosis. Thromb Res. 2007;121(3):301-7. [pmid: 17543373].
Lindqvist PG, Epstein E, Olsson H. The relationship between lifestyle factors and venous thromboembolism among women: a report from the MISS study. Br J Haematol. 2009;144(2):234-40. [pmid: 19036105].
Liu Y, Inoue M, Sobue T, et al. Reproductive factors, hormone use and the risk of lung cancer among middle-aged never-smoking Japanese women: a large-scale population-based cohort study. Int J Cancer. 2005;117(4):662-6. [pmid: 15929081].
Lodha R, Joshi A, Paul D, et al. Association between reproductive factors and breast cancer in an urban set up at central India: a case-control study. Indian J Cancer. 2011;48(3):303-7. [pmid: 21921328].
Longstreth WT, Nelson LM, Koepsell TD, et al. Subarachnoid hemorrhage and hormonal factors in women. A population-based case-control study. Ann Intern Med. 1994;121(3):168-73. [pmid: 8017743].
Lucenteforte E, Zucchetto A, Bosetti C, et al. Reproductive and hormonal factors and pancreatic cancer risk in women. Pancreas. 2011;40(3):460-3. [pmid: 21343831].
MacClellan LR, Giles W, Cole J, et al. Probable migraine with visual aura and risk of ischemic stroke: the stroke prevention in young women study. Stroke. 2007;38(9):2438-45. [pmid: 17690308].
Martinelli I, Battaglioli T, Bucciarelli P, et al. Risk factors and recurrence rate of primary deep vein thrombosis of the upper extremities. Circulation. 2004;110(5):566-70. [pmid: 15262837].
Martinelli I, Cattaneo M, Panzeri D, et al. Risk factors for deep venous thrombosis of the upper extremities. Ann Intern Med. 1997;126(9):707-11. [pmid: 9139557].
Martinelli I, Taioli E, Battaglioli T, et al. Risk of venous thromboembolism after air travel: interaction with thrombophilia and oral contraceptives. Arch Intern Med. 2003;163(22):2771-4. [pmid: 14662632].
Matias-Guiu J, Alvarez J, Insa R, et al. Ischemic stroke in young adults. II. Analysis of risk factors in the etiological subgroups. Acta Neurol Scand. 1990;81(4):314-7. [pmid: 2360398].
Matos A, Moutinho J, Pinto D, et al. The influence of smoking and other cofactors on the time to onset to cervical cancer in a southern European population. Eur J Cancer Prev. 2005;14(5):485-91. [pmid: 16175054].
Mayans MV, Calvet X, Bruix J, et al. Risk factors for hepatocellular carcinoma in Catalonia, Spain. Int J Cancer. 1990;46(3):378-81. [pmid: 2168342].
McLay RN, Maki PM, Lyketsos CG. Nulliparity and late menopause are associated with decreased cognitive decline. J Neuropsychiatry Clin Neurosci. 2003;15(2):161-7. [pmid: 12724456].
Meltzer ME, Lisman T, Doggen CJ, et al. Synergistic effects of hypofibrinolysis and genetic and acquired risk factors on the risk of a first venous thrombosis. PLoS Med. 2008;5(5):e97. [pmid: 18462012].
Mhurchu CN, Anderson C, Jamrozik K, et al. Hormonal factors and risk of aneurysmal subarachnoid hemorrhage: an international population-based, case-control study. Stroke. 2001;32(3):606-12. [pmid: 11239175].
Middeldorp S, Henkens CM, Koopman MM, et al. The incidence of venous thromboembolism in family members of patients with factor V Leiden mutation and venous thrombosis. Ann Intern Med. 1998;128(1):15-20. [pmid: 9424976].
Milan T, Verkasalo PK, Kaprio J, et al. Lifestyle differences in twin pairs discordant for basal cell carcinoma of the skin. Br J Dermatol. 2003;149(1):115-23. [pmid: 12890204].
Moreno V, Munoz N, Bosch FX, et al. Risk factors for progression of cervical intraepithelial neoplasm grade III to invasive cervical cancer. Cancer Epidemiol Biomarkers Prev. 1995;4(5):459-67. [pmid: 7549800].
Munoz N, Bosch FX, de Sanjose S, et al. The role of HPV in the etiology of cervical cancer. Mutat Res. 1994;305(2):293-301. [pmid: 8121439].
Murray FE, Logan RF, Hannaford PC, et al. Cigarette smoking and parity as risk factors for the development of symptomatic gall bladder disease in women: results of the Royal College of General Practitioners' oral contraception study. Gut. 1994;35(1):107-11. [pmid: 8307429].
Myburgh KH, Hutchins J, Fataar AB, et al. Low bone density is an etiologic factor for stress fractures in athletes. Ann Intern Med. 1990;113(10):754-9. [pmid: 1978620].
Naldi L, Altieri A, Imberti GL, et al. Cutaneous malignant melanoma in women. Phenotypic characteristics, sun exposure, and hormonal factors: a case-control study from Italy. Ann Epidemiol. 2005;15(7):545-50. [pmid: 16029848].
Nelson HD, Zakher B, Cantor A, et al. Risk factors for breast cancer for women aged 40 to 49 years: a systematic review and meta-analysis. Ann Intern Med. 2012;156(9):635-48. [pmid: 22547473].
Nelson ZC, Ray RM, Wu C, et al. Fruit and vegetable intakes are associated with lower risk of breast fibroadenomas in Chinese women. J Nutr. 2010;140(7):1294-301. [pmid: 20484549].
Nicoletti A, Nicoletti G, Arabia G, et al. Reproductive factors and Parkinson's disease: a multicenter case-control study. Mov Disord. 2011;26(14):2563-6. [pmid: 21956541].
Nightingale AL, Farmer RD. Ischemic stroke in young women: a nested case-control study using the UK General Practice Research Database. Stroke. 2004;35(7):1574-8. [pmid: 15143296].
Norsa'adah B, Rusli BN, Imran AK, et al. Risk factors of breast cancer in women in Kelantan Malaysia. Singapore Med J. 2005;46(12):698-705. [pmid: 16308643].
Owen-Smith V, Hannaford PC, Warskyj M, et al. Effects of changes in smoking status on risk estimates for myocardial infarction among women recruited for the Royal College of General Practitioners' Oral Contraception Study in the UK. J Epidemiol Community Health. 1998;52(7):420-4. [pmid: 9799875].
Parazzini F, Chatenoud L, La Vecchia C, et al. Determinants of risk of invasive cervical cancer in young women. Br J Cancer. 1998;77(5):838-41. [pmid: 9514067].
Parazzini F, La Vecchia C, Negri E, et al. Risk factors for benign ovarian teratomas. Br J Cancer. 1995;71(3):644-6. [pmid: 7880752].
Parazzini F, La Vecchia C, Negri E, et al. Risk factors for cervical intraepithelial neoplasia. Cancer. 1992;69(9):2276-82. [pmid: 1562973].
Petro-Nustas W, Norton ME, al-Masarweh I. Risk factors for breast cancer in Jordanian women. J Nurs Scholarsh. 2002;34(1):19-25. [pmid: 11901963].
Pezzini A, Grassi M, Iacoviello L, et al. Inherited thrombophilia and stratification of ischaemic stroke risk among users of oral contraceptives. J Neurol Neurosurg Psychiatry. 2007;78(3):271-6. [pmid: 17098841].
Pfahlberg A, Hassan K, Wille L, et al. Systematic review of case-control studies: oral contraceptives show no effect on melanoma risk. Public Health Rev. 1997;25(3-4):309-15. [pmid: 9553446].
Pisa FE, Bovenzi M, Romeo L, et al. Reproductive factors and the risk of scleroderma: an Italian case-control study. Arthritis Rheum. 2002;46(2):451-6. [pmid: 11840448].
Pomp ER, Doggen CJ, Vos HL, et al. Polymorphisms in the protein C gene as risk factor for venous thrombosis. Thromb Haemost. 2009;101(1):62-7. [pmid: 19132190].
Pomp ER, le Cessie S, Rosendaal FR, et al. Risk of venous thrombosis: obesity and its joint effect with oral contraceptive use and prothrombotic mutations. Br J Haematol. 2007;139(2):289-96. [pmid: 17897305].
Pomp ER, Rosendaal FR, Doggen CJ. Smoking increases the risk of venous thrombosis and acts synergistically with oral contraceptive use. Am J Hematol. 2008;83(2):97-102. [pmid: 17726684].
Poromaa IS, Segebladh B. Adverse mood symptoms with oral contraceptives. Acta Obstetricia et Gynecologica Scandinavica. 2012;91(4):420-427. [pmid: 22136510].
Pruissen DM, Slooter AJ, Rosendaal FR, et al. Coagulation factor XIII gene variation, oral contraceptives, and risk of ischemic stroke. Blood. 2008;111(3):1282-6. [pmid: 18006701].
Quinn DA, Thompson BT, Terrin ML, et al. A prospective investigation of pulmonary embolism in women and men. JAMA. 1992;268(13):1689-96. [pmid: 1527878].
Realini JP, Encarnacion CE, Chintapalli KN, et al. Oral contraceptives and venous thromboembolism: a case-control study designed to minimize detection bias. J Am Board Fam Pract. 1997;10(5):315-21. [pmid: 9297655].
Reeves GK, Patterson J, Vessey MP, et al. Hormonal and other factors in relation to survival among breast cancer patients. Int J Cancer. 2000;89(3):293-9. [pmid: 10861507].
Reuter KL, Baker SP, Krolikowski FJ. Risk factors for breast cancer in women undergoing mammography. AJR Am J Roentgenol. 1992;158(2):273-8. [pmid: 1729780].
Richardson WS, Carter KM, Helm B, et al. Risk factors for gallstone disease in the laparoscopic era. Surg Endosc. 2002;16(3):450-2. [pmid: 11928026].
Roddam AW, Pirie K, Pike MC, et al. Active and passive smoking and the risk of breast cancer in women aged 36-45 years: a population based case-control study in the UK. Br J Cancer. 2007;97(3):434-9. [pmid: 17579618].
Rodriguez LA, Tolosa LB, Ruigomez A, et al. Rheumatoid arthritis in UK primary care: incidence and prior morbidity. Scand J Rheumatol. 2009;38(3):173-7. [pmid: 19117247].
Ross JD. Is oral contraceptive associated with genital warts?. Genitourin Med. 1996;72(5):330-3. [pmid: 8976847].
Rylander-Rudqvist T, Wedren S, Jonasdottir G, et al. Cytochrome P450 1B1 gene polymorphisms and postmenopausal endometrial cancer risk. Cancer Epidemiol Biomarkers Prev. 2004;13(9):1515-20. [pmid: 15342454].
Samanta A, Jones A, Regan M, et al. Is osteoarthritis in women affected by hormonal changes or smoking?. Br J Rheumatol. 1993;32(5):366-70. [pmid: 8495255].
Schurks M, Rist PM, Bigal ME, et al. Migraine and cardiovascular disease: systematic review and meta-analysis. BMJ. 2009;339:b3914. [pmid: 19861375].
Schwaag S, Nabavi DG, Frese A, et al. The association between migraine and juvenile stroke: a case-control study. Headache. 2003;43(2):90-5. [pmid: 12558760].
Shekari M, Kordi-Tamandani DM, Malekzadeh K, et al. Effect of Anti-inflammatory (IL-4, IL-10) Cytokine Genes in Relation to Risk of Cervical Carcinoma. Am J Clin Oncol. 2011. Dec. 30. [pmid: 22157213].
Sidoni A, Cavaliere A, Bellezza G, et al. Breast cancer in young women: clinicopathological features and biological specificity. Breast. 2003;12(4):247-50. [pmid: 14659308].
Siegerink B, Meltzer ME, de Groot PG, et al. Clot lysis time and the risk of myocardial infarction and ischaemic stroke in young women; results from the RATIO case-control study. Br J Haematol. 2012;156(2):252-8. [pmid: 22082241].
Simioni P, Sanson BJ, Prandoni P, et al. Incidence of venous thromboembolism in families with inherited thrombophilia. Thromb Haemost. 1999;81(2):198-202. [pmid: 10063991].
Slooter AJ, Rosendaal FR, Tanis BC, et al. Prothrombotic conditions, oral contraceptives, and the risk of ischemic stroke. J Thromb Haemost. 2005;3(6):1213-7. [pmid: 15946211].
Sobti RC, Shekari M, Kordi Tamandani DM, et al. Effect of NBS1 gene polymorphism on the risk of cervix carcinoma in a northern Indian population. Int J Biol Markers. 2008;23(3):133-9. [pmid: 18949738].
Sveindottir H, Backstrom T. Prevalence of menstrual cycle symptom cyclicity and premenstrual dysphoric disorder in a random sample of women using and not using oral contraceptives. Acta Obstet Gynecol Scand. 2000;79(5):405-13. [pmid: 10830769].
Swanson CA, Wilbanks GD, Twiggs LB, et al. Moderate alcohol consumption and the risk of endometrial cancer. Epidemiology. 1993;4(6):530-6. [pmid: 8268282].
Syrjanen K, Shabalova I, Petrovichev N, et al. Oral contraceptives are not an independent risk factor for cervical intraepithelial neoplasia or high-risk human papillomavirus infections. Anticancer Res. 2006;26(6C):4729-40. [pmid: 17214333].
Talbott EO, Norman SA, Kuller LH, et al. Refining preventive strategies for invasive cervical cancer: A population-based case-control study. Journal of Women's Health. 1995;4(4):387-395.
Teunissen LL, Rinkel GJ, Algra A, et al. Risk factors for subarachnoid hemorrhage: a systematic review. Stroke. 1996;27(3):544-9. [pmid: 8610327].
Thomas DB, Ray RM, Koetsawang A, et al. Human papillomaviruses and cervical cancer in Bangkok. I. Risk factors for invasive cervical carcinomas with human papillomavirus types 16 and 18 DNA. Am J Epidemiol. 2001;153(8):723-31. [pmid: 11296143].
Thorogood M, Mann J, Murphy M, et al. Fatal stroke and use of oral contraceptives: findings from a case-control study. Am J Epidemiol. 1992;136(1):35-45. [pmid: 1415130].
Tichelaar VY, Sprenger HG, Makelburg AB, et al. Active cytomegalovirus infection in patients with acute venous thrombosis: a case-control study. Am J Hematol. 2011;86(6):510-2. [pmid: 21509792].
Troisi R, Schairer C, Chow WH, et al. Reproductive factors, oral contraceptive use, and risk of colorectal cancer. Epidemiology. 1997;8(1):75-9. [pmid: 9116100].
Urbanus RT, Siegerink B, Roest M, et al. Antiphospholipid antibodies and risk of myocardial infarction and ischaemic stroke in young women in the RATIO study: a case-control study. Lancet Neurol. 2009;8(11):998-1005. [pmid: 19783216].
Vaillant-Roussel H, Ouchchane L, Dauphin C, et al. Risk factors for recurrence of venous thromboembolism associated with the use of oral contraceptives. Contraception. 2011;84(5):e23-30. [pmid: 22018134].
van Hylckama Vlieg A, van der Linden IK, Bertina RM, et al. High levels of factor IX increase the risk of venous thrombosis. Blood. 2000;95(12):3678-82. [pmid: 10845896].
Vaya A, Mira Y, Mateo J, et al. Prothrombin G20210A mutation and oral contraceptive use increase upper-extremity deep vein thrombotic risk. Thromb Haemost. 2003;89(3):452-7. [pmid: 12624627].
Vercellini P, Eskenazi B, Consonni D, et al. Oral contraceptives and risk of endometriosis: a systematic review and meta-analysis. Hum Reprod Update. 2010. Sep. 10. [pmid: 20833638].
Vessey M, Painter R. Hospital referral for headache and oral contraceptive use: Findings in a large cohort study. British Journal of Family Planning. 1995;21(3):91-92.
Wolpert BJ, Amr S, Ezzat S, et al. Estrogen exposure and bladder cancer risk in Egyptian women. Maturitas. 2010;67(4):353-7. [pmid: 20813471].
Worralurt C, Taneepanichskul S. Risk factors of venous thromboembolism (VTE) in Thai reproductive aged female: King Chulalongkorn Memorial Hospital experience. J Med Assoc Thai. 2005;88(11):1502-5. [pmid: 16471093].
Wu FY, Lee YJ, Chen DR, et al. Association of DNA-protein crosslinks and breast cancer. Mutat Res. 2002;501(1-2):69-78. [pmid: 11934439].
Xu YL, Sun Q, Shan GL, et al. A case-control study on risk factors of breast cancer in China. Arch Med Sci. 2012;8(2):303-9. [pmid: 22662004].
Yavari P, Mosavizadeh M, Sadrol-Hefazi B, et al. Reproductive characteristics and the risk of breast cancer--a case-control study in Iran. Asian Pac J Cancer Prev. 2005;6(3):370-5. [pmid: 16236002].
Zelmanowicz A, Hildesheim A, Sherman ME, et al. Evidence for a common etiology for endometrial carcinomas and malignant mixed mullerian tumors. Gynecol Oncol. 1998;69(3):253-7. [pmid: 9648597].
Zivaljevic V, Vlajinac H, Jankovic R, et al. Case-control study of female thyroid cancer--menstrual, reproductive and hormonal factors. Eur J Cancer Prev. 2003;12(1):63-6. [pmid: 12548112].
Zodpey SP, Tiwari RR, Kulkarni HR. Risk factors for haemorrhagic stroke: a case-control study. Public Health. 2000;114(3):177-82. [pmid: 10878744].
Zucchetto A, Talamini R, Dal Maso L, et al. Reproductive, menstrual, and other hormone-related factors and risk of renal cell cancer. Int J Cancer. 2008;123(9):2213-6. [pmid: 18711701].

## Does not include outcomes of interest within specified date parameters

Abdel-Aziz AM, el-Amrawy SM, el-Din AG, et al. Urinary calculi and pattern of fertility among women. A retrospective study. J Egypt Public Health Assoc. 1990;65(5-6):451-62. [pmid: 2134085].
Abraham S, Luscombe G, Soo I. Oral contraception and cyclic changes in premenstrual and menstrual experiences. J Psychosom Obstet Gynaecol. 2003;24(3):185-93. [pmid: 14584305].
Adami HO, Bergstrom R, Persson I, et al. The incidence of ovarian cancer in Sweden, 1960-1984. Am J Epidemiol. 1990;132(3):446-52. [pmid: 2389749].
Adesanya OO, Colie CF. Evaluating oral contraceptive use at 6 and 12 months. J Reprod Med. 1996;41(6):431-4. [pmid: 8799920].
Ahrendt HJ, Nisand I, Bastianelli C, et al. Efficacy, acceptability and tolerability of the combined contraceptive ring, NuvaRing, compared with an oral contraceptive containing 30 microg of ethinyl estradiol and 3 mg of drospirenone. Contraception. 2006;74(6):451-7. [pmid: 17157101].
Allen S, Stephenson R, Weiss H, et al. Pregnancy, hormonal contraceptive use, and HIV-related death in Rwanda. J Womens Health (Larchmt). 2007;16(7):1017-27. [pmid: 17903079].
Almagor M, Ben-Porath YS. Mood changes during the menstrual cycle and their relation to the use of oral contraceptive. J Psychosom Res. 1991;35(6):721-8. [pmid: 1791586].
Alonso A, Jick SS, Olek MJ, et al. Recent use of oral contraceptives and the risk of multiple sclerosis. Arch Neurol. 2005;62(9):1362-5. [pmid: 16157743].
Ameziane N, Seguin C, Borgel D, et al. The -33T--> C polymorphism in intron 7 of the TFPI gene influences the risk of venous thromboembolism, independently of the factor V leiden and prothrombin mutations. Thrombosis and Haemostasis. 2002;88(2):195-199. [pmid: 12195688].
Anderson FD, Feldman R, Reape KZ. Endometrial effects of a 91-day extended-regimen oral contraceptive with low-dose estrogen in place of placebo. Contraception. 2008;77(2):91-6. [pmid: 18226671].
Anderson JE, Santelli JS, Morrow B. Trends in adolescent contraceptive use, unprotected and poorly protected sex, 1991-2003. J Adolesc Health. 2006;38(6):734-9. [pmid: 16730603].
Anonymous. Breast cancer and hormonal contraceptives: collaborative reanalysis of individual data on 53 297 women with breast cancer and 100 239 women without breast cancer from 54 epidemiological studies. Collaborative Group on Hormonal Factors in Breast Cancer. Lancet. 1996;347(9017):1713-27. [pmid: 8656904].
Anonymous. An open label, randomized study to evaluate the effects of seven monophasic oral contraceptive regimens on hemostatic variables. Outline of the protocol. Oral Contraceptive and Hemostasis Study Group. Contraception. 1999;59(6):345-55. [pmid: 10518228].
Anonymous. Breast cancer and combined oral contraceptives: results from a multinational study. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Br J Cancer. 1990;61(1):110-9. [pmid: 2404507].
Anonymous. Breast cancer and hormonal contraceptives: further results. Collaborative Group on Hormonal Factors in Breast Cancer. Contraception. 1996;54(3 Suppl):1S-106S. [pmid: 8899264].
Anonymous. Invasive squamous-cell cervical carcinoma and combined oral contraceptives: results from a multinational study. WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Cancer. 1993;55(2):228-36. [pmid: 8370621].
Anonymous. Oral contraceptive use and breast cancer risk in young women: subgroup analyses. UK National Case-Control Study Group. Lancet. 1990;335(8704):1507-9. [pmid: 1972441].
Anonymous. Oral contraceptives and liver cancer. Results of the Multicentre International Liver Tumor Study (MILTS). Contraception. 1997;56(5):275-84. [pmid: 9437555].
Anonymous. Ovarian cancer and body size: individual participant meta-analysis including 25,157 women with ovarian cancer from 47 epidemiological studies. PLoS Med. 2012;9(4):e1001200. [pmid: 22606070].
Anonymous. The effects of seven monophasic oral contraceptive regimens on hemostatic variables: conclusions from a large randomized multicenter study. Contraception. 2003;67(3):173-85. [pmid: 12618251].
Anthuber S, Schramm GA, Heskamp ML. Six-month evaluation of the benefits of the low-dose combined oral contraceptive chlormadinone acetate 2 mg/ethinylestradiol 0.03 mg in young women: results of the prospective, observational, non-interventional, multicentre TeeNIS study. Clin Drug Investig. 2010;30(4):211-20. [pmid: 20225905].
Anttila L, Neunteufel W, Petraglia F, et al. Cycle control and bleeding pattern of a 24/4 regimen of drospirenone 3 mg/ethinylestradiol 20 mug compared with a 21/7 regimen of desogestrel 150 mug/ethinylestradiol 20 mug: a pooled analysis. Clin Drug Investig. 2011;31(8):519-25. [pmid: 21721590].
Appleby P, Beral V, Berrington de Gonzalez A, et al. Carcinoma of the cervix and tobacco smoking: collaborative reanalysis of individual data on 13,541 women with carcinoma of the cervix and 23,017 women without carcinoma of the cervix from 23 epidemiological studies. Int J Cancer. 2006;118(6):1481-95. [pmid: 16206285].
Aubeny E, Buhler M, Colau JC, et al. Oral contraception: patterns of non-compliance. The Coraliance study. Eur J Contracept Reprod Health Care. 2002;7(3):155-61. [pmid: 12428935].
Audet MC, Moreau M, Koltun WD, et al. Evaluation of contraceptive efficacy and cycle control of a transdermal contraceptive patch vs an oral contraceptive: a randomized controlled trial. JAMA. 2001;285(18):2347-54. [pmid: 11343482].
Axmon A, Rylander L, Albin M, et al. Factors affecting time to pregnancy. Hum Reprod. 2006;21(5):1279-84. [pmid: 16410331].
Azarpazhooh MR, Rafi S, Etemadi MM, et al. The relation between short-term oral contraceptive consumption and cerebrovascular, cardiovascular disorders in Iranian women attending Hajj. Saudi Med J. 2008;29(7):1024-7. [pmid: 18626534].
Bakhru A, Stanwood N. Performance of contraceptive patch compared with oral contraceptive pill in a high-risk population. Obstet Gynecol. 2006;108(2):378-86. [pmid: 16880309].
Balasch J, Creus M, Fabregues F, et al. Visible and non-visible endometriosis at laparoscopy in fertile and infertile women and in patients with chronic pelvic pain: a prospective study. Hum Reprod. 1996;11(2):387-91. [pmid: 8671229].
Bancroft J, Rennie D. The impact of oral contraceptives on the experience of perimenstrual mood, clumsiness, food craving and other symptoms. J Psychosom Res. 1993;37(2):195-202. [pmid: 8463994].
Becker TM, Wheeler CM, McGough NS, et al. Contraceptive and reproductive risks for cervical dysplasia in southwestern Hispanic and non-Hispanic white women. Int J Epidemiol. 1994;23(5):913-22. [pmid: 7860171].
Behrens T, Kaerlev L, Cree I, et al. Hormonal exposures and the risk of uveal melanoma. Cancer Causes Control. 2010;21(10):1625-34. [pmid: 20524054].
Benagiano G, Primiero FM, Bastianelli C, et al. Comparative clinical evaluation of the effect on carbohydrate and lipid metabolism of two norethisterone-containing hormonal contraceptives:Mesigyna and TriNovum. Contraception. 1997;55(5):295-300. [pmid: 9220226].
Berenson AB, Wiemann CM. Use of levonorgestrel implants versus oral contraceptives in adolescence: a case-control study. Am J Obstet Gynecol. 1995;172(4 Pt 1):1128-35. discussion 1135-7. [pmid: 7726249].
Berenson AB, Odom SD, Breitkopf CR, et al. Physiologic and psychologic symptoms associated with use of injectable contraception and 20 microg oral contraceptive pills. Am J Obstet Gynecol. 2008;199(4):351 e1-12. [pmid: 18599013].
Berenson AB, Wiemann CM, Rickerr VI, et al. Contraceptive outcomes among adolescents prescribed Norplant implants versus oral contraceptives after one year of use. Am J Obstet Gynecol. 1997;176(3):586-92. [pmid: 9077611].
Bernard-Gallon D, Bosviel R, Delort L, et al. DNA repair gene ERCC2 polymorphisms and associations with breast and ovarian cancer risk. Molecular Cancer. 2008;7:36. [pmid: 18454848].
Bernatsky S, Boivin JF, Joseph L, et al. Prevalence of factors influencing cancer risk in women with lupus: social habits, reproductive issues, and obesity. J Rheumatol. 2002;29(12):2551-4. [pmid: 12465150].
Birch-Johansen F, Jensen A, Olesen AB, et al. Does hormone replacement therapy and use of oral contraceptives increase the risk of non-melanoma skin cancer?. Cancer Causes Control. 2012;23(2):379-88. [pmid: 22215431].
Bjarnadottir RI, Tuppurainen M, Killick SR. Comparison of cycle control with a combined contraceptive vaginal ring and oral levonorgestrel/ethinyl estradiol. Am J Obstet Gynecol. 2002;186(3):389-95. [pmid: 11904596].
Black C, Kaye JA, Jick H. Clinical risk factors for venous thromboembolus in users of the combined oral contraceptive pill. Br J Clin Pharmacol. 2002;53(6):637-40. [pmid: 12047488].
Bloemenkamp KW, Rosendaal FR, Helmerhorst FM, et al. Hemostatic effects of oral contraceptives in women who developed deep-vein thrombosis while using oral contraceptives. Thromb Haemost. 1998;80(3):382-7. [pmid: 9759614].
Boonyarangkul A, Taneepanichskul S. Comparison of cycle control and side effects between transdermal contraceptive patch and an oral contraceptive in women older than 35 years. J Med Assoc Thai. 2007;90(9):1715-9. [pmid: 17957909].
Booth M, Beral V, Maconochie N, et al. A case-control study of benign ovarian tumours. J Epidemiol Community Health. 1992;46(5):528-31. [pmid: 1479325].
Borenstein J, Yu HT, Wade S, et al. Effect of an oral contraceptive containing ethinyl estradiol and drospirenone on premenstrual symptomatology and health-related quality of life. J Reprod Med. 2003;48(2):79-85. [pmid: 12621790].
Bosch FX, Munoz N, de Sanjose S, et al. Risk factors for cervical cancer in Colombia and Spain. Int J Cancer. 1992;52(5):750-8. [pmid: 1330934].
Boyd NF, Melnichouk O, Martin LJ, et al. Mammographic density, response to hormones, and breast cancer risk. J Clin Oncol. 2011;29(22):2985-92. [pmid: 21709206].
Boyko EJ, Theis MK, Vaughan TL, et al. Increased risk of inflammatory bowel disease associated with oral contraceptive use. Am J Epidemiol. 1994;140(3):268-78. [pmid: 8030630].
Bracken MB. Oral contraception and congenital malformations in offspring: a review and meta-analysis of the prospective studies. Obstet Gynecol. 1990;76(3 Pt 2):552-7. [pmid: 2143279].
Brennan P, Silman AJ. An investigation of gene-environment interaction in the etiology of rheumatoid arthritis. Am J Epidemiol. 1994;140(5):453-60. [pmid: 8067337].
Brinton LA, Hoover RN. Estrogen replacement therapy and endometrial cancer risk: unresolved issues. The Endometrial Cancer Collaborative Group. Obstet Gynecol. 1993;81(2):265-71. [pmid: 8380913].
Brinton LA, Benichou J, Gammon MD, et al. Ethnicity and variation in breast cancer incidence. Int J Cancer. 1997;73(3):349-55. [pmid: 9359481].
Brinton LA, Brogan DR, Coates RJ, et al. Breast cancer risk among women under 55 years of age by joint effects of usage of oral contraceptives and hormone replacement therapy. Menopause. 1998;5(3):145-51. [pmid: 9774759].
Brinton LA, Daling JR, Liff JM, et al. Oral contraceptives and breast cancer risk among younger women. J Natl Cancer Inst. 1995;87(11):827-35. [pmid: 7791232].
Brinton LA, Gammon MD, Malone KE, et al. Modification of oral contraceptive relationships on breast cancer risk by selected factors among younger women. Contraception. 1997;55(4):197-203. [pmid: 9179450].
Brinton LA, Reeves WC, Brenes MM, et al. Oral contraceptive use and risk of invasive cervical cancer. Int J Epidemiol. 1990;19(1):4-11. [pmid: 2351522].
Brisson J, Morin C, Fortier M, et al. Risk factors for cervical intraepithelial neoplasia: differences between low- and high-grade lesions. Am J Epidemiol. 1994;140(8):700-10. [pmid: 7942772].
Broder MS, Spalding J. Treatment patterns for women with new episodes of uterine myomas in an insured population in the US. Curr Med Res Opin. 2006;22(1):95-100. [pmid: 16393435].
Brooks K, Samms-Vaughan M, Karmaus W. Are oral contraceptive use and pregnancy complications risk factors for atopic disorders among offspring?. Pediatr Allergy Immunol. 2004;15(6):487-96. [pmid: 15610361].
Brucker C. Controlled trial with a monthly combination injectable contraceptive in Europe. Gynecol Endocrinol. Suppl 3. 2001;15:11-4. [pmid: 11570312].
Brummel-Ziedins KE, Vossen CY, Butenas S, et al. Thrombin generation profiles in deep venous thrombosis. J Thromb Haemost. 2005;3(11):2497-505. [pmid: 16241948].
Brunner Huber LR, Toth JL. Obesity and oral contraceptive failure: findings from the 2002 National Survey of Family Growth. Am J Epidemiol. 2007;166(11):1306-11. [pmid: 17785712].
Brunner Huber LR, Hogue CJ, Stein AD, et al. Body mass index and risk for oral contraceptive failure: a case-cohort study in South Carolina. Ann Epidemiol. 2006;16(8):637-43. [pmid: 16516489].
Brunner LR, Hogue CJ. The role of body weight in oral contraceptive failure: results from the 1995 national survey of family growth. Ann Epidemiol. 2005;15(7):492-9. [pmid: 16029841].
Brynhildsen J, Lennartsson H, Klemetz M, et al. Oral contraceptive use among female elite athletes and age-matched controls and its relation to low back pain. Acta Obstet Gynecol Scand. 1997;76(9):873-8. [pmid: 9351415].
Brynhildsen JO, Hammar J, Hammar ML. Does the menstrual cycle and use of oral contraceptives influence the risk of low back pain? A prospective study among female soccer players. Scand J Med Sci Sports. 1997;7(6):348-53. [pmid: 9458501].
Burkett BJ, Peterson CM, Birch LM, et al. The relationship between contraceptives, sexual practices, and cervical human papillomavirus infection among a college population. J Clin Epidemiol. 1992;45(11):1295-302. [pmid: 1331341].
Burkman RT, Fisher AC, Wan GJ, et al. Association between efficacy and body weight or body mass index for two low-dose oral contraceptives. Contraception. 2009;79(6):424-7. [pmid: 19442776].
Bustan MN, Coker AL, Addy CL, et al. Oral contraceptive use and breast cancer in Indonesia. Contraception. 1993;47(3):241-9. [pmid: 8462315].
Caird LE, Reid-Thomas V, Hannan WJ, et al. Oral progestogen-only contraception may protect against loss of bone mass in breast-feeding women. Clin Endocrinol (Oxf). 1994;41(6):739-45. [pmid: 7889609].
Cantwell MM, Lacey JV Jr, Schairer C, et al. Reproductive factors, exogenous hormone use and bladder cancer risk in a prospective study. Int J Cancer. 2006;119(10):2398-401. [pmid: 16894568].
Carr BR, DelConte A. Using a low-dose contraceptive in women 35 years of age and over: 20 microg estradiol/100 microg levonorgestrel. Contraception. 2002;65(6):397-402. [pmid: 12127636].
Castelo-Branco C, Martinez de Osaba MJ, Pons F, et al. Effects on bone mass of two oral contraceptives containing ethinylestradiol and cyproterone acetate or desogestrel: results of a 2-year follow-up. Eur J Contracept Reprod Health Care. 1998;3(2):79-84. [pmid: 9710711].
Castle PE, Walker JL, Schiffman M, et al. Hormonal contraceptive use, pregnancy and parity, and the risk of cervical intraepithelial neoplasia 3 among oncogenic HPV DNA-positive women with equivocal or mildly abnormal cytology. Int J Cancer. 2005;117(6):1007-12. [pmid: 15986443].
Cea-Soriano L, Blenk T, Wallander MA, et al. Hormonal therapies and meningioma: is there a link?. Cancer Epidemiol. 2012;36(2):198-205. [pmid: 21943794].
Celentano E, Galasso R, Berrino F, et al. Correlates of age at natural menopause in the cohorts of EPIC-Italy. Tumori. 2003;89(6):608-14. [pmid: 14870825].
Chacko MR, Kozinetz CA, Smith PB. Assessment of oral contraceptive pill continuation in young women. J Pediatr Adolesc Gynecol. 1999;12(3):143-8. [pmid: 10546906].
Chang-Claude J, Dunning A, Schnitzbauer U, et al. The patched polymorphism Pro1315Leu (C3944T) may modulate the association between use of oral contraceptives and breast cancer risk. Int J Cancer. 2003;103(6):779-83. [pmid: 12516098].
Chao A, Hsu KH, Lai CH, et al. Cervical cancer screening program integrating Pap smear and HPV DNA testing: a population-based study. Int J Cancer. 2008;122(12):2835-41. [pmid: 18338752].
Chaouki N, Bosch FX, Munoz N, et al. The viral origin of cervical cancer in Rabat, Morocco. Int J Cancer. 1998;75(4):546-54. [pmid: 9466654].
Charreau I, Plu-Bureau G, Bachelot A, et al. Oral contraceptive use and risk of benign breast disease in a French case-control study of young women. Eur J Cancer Prev. 1993;2(2):147-54. [pmid: 8461865].
Chasan-Taber L, Willett WC, Manson JE, et al. Prospective study of oral contraceptives and hypertension among women in the United States. Circulation. 1996;94(3):483-9. [pmid: 8759093].
Chasan-Taber L, Willett WC, Stampfer MJ, et al. A prospective study of oral contraceptives and NIDDM among U.S. women. Diabetes Care. 1997;20(3):330-5. [pmid: 9051382].
Chasan-Taber L, Willett WC, Stampfer MJ, et al. Oral contraceptives and ovulatory causes of delayed fertility. Am J Epidemiol. 1997;146(3):258-65. [pmid: 9247010].
Chen XK, Wen SW, Sun LM, et al. Recent oral contraceptive use and adverse birth outcomes. Eur J Obstet Gynecol Reprod Biol. 2009;144(1):40-3. [pmid: 19233538].
Chiaffarino F, Parazzini F, La Vecchia C, et al. Use of oral contraceptives and uterine fibroids: results from a case-control study. Br J Obstet Gynaecol. 1999;106(8):857-60. [pmid: 10453838].
Chie WC, Li CY, Huang CS, et al. Oral contraceptives and breast cancer risk in Taiwan, a country of low incidence of breast cancer and low use of oral contraceptives. Int J Cancer. 1998;77(2):219-23. [pmid: 9650556].
Chilvers CE, Smith SJ. The effect of patterns of oral contraceptive use on breast cancer risk in young women. The UK National Case-Control Study Group. Br J Cancer. 1994;69(5):922-3. [pmid: 8180025].
Chow WH, McLaughlin JK, Mandel JS, et al. Reproductive factors and the risk of renal cell cancer among women. Int J Cancer. 1995;60(3):321-4. [pmid: 7829237].
Chute CG, Willett WC, Colditz GA, et al. A prospective study of reproductive history and exogenous estrogens on the risk of colorectal cancer in women. Epidemiology. 1991;2(3):201-7. [pmid: 2054402].
Clavel F, Andrieu N, Gairard B, et al. Oral contraceptives and breast cancer: a French case-control study. Int J Epidemiol. 1991;20(1):32-8. [pmid: 2066241].
Coenen CM, Thomas CM, Borm GF, et al. Changes in androgens during treatment with four low-dose contraceptives. Contraception. 1996;53(3):171-6. [pmid: 8689882].
Coenen CM, Thomas CM, Borm GF, et al. Comparative evaluation of the androgenicity of four low-dose, fixed-combination oral contraceptives. Int J Fertil Menopausal Stud. Suppl 2. 1995;40:92-7. [pmid: 8574256].
Coker AL, McCann MF, Hulka BS, et al. Oral contraceptive use and cervical intraepithelial neoplasia. J Clin Epidemiol. 1992;45(10):1111-8. [pmid: 1474407].
Coker AL, Sanders LC, Bond SM, et al. Hormonal and barrier methods of contraception, oncogenic human papillomaviruses, and cervical squamous intraepithelial lesion development. J Womens Health Gend Based Med. 2001;10(5):441-9. [pmid: 11445043].
Colditz GA, Feskanich D, Chen WY, et al. Physical activity and risk of breast cancer in premenopausal women. Br J Cancer. 2003;89(5):847-51. [pmid: 12942116].
Conway K, Parrish E, Edmiston SN, et al. Risk factors for breast cancer characterized by the estrogen receptor alpha A908G (K303R) mutation. Breast Cancer Res. 2007;9(3):R36. [pmid: 17553133].
Cooper GS, Dooley MA, Treadwell EL, et al. Hormonal and reproductive risk factors for development of systemic lupus erythematosus: results of a population-based, case-control study. Arthritis Rheum. 2002;46(7):1830-9. [pmid: 12124867].
Corpechot C, Chretien Y, Chazouilleres O, et al. Demographic, lifestyle, medical and familial factors associated with primary biliary cirrhosis. J Hepatol. 2010;53(1):162-9. [pmid: 20471130].
Costenbader KH, Feskanich D, Stampfer MJ, et al. Reproductive and menopausal factors and risk of systemic lupus erythematosus in women. Arthritis Rheum. 2007;56(4):1251-62. [pmid: 17393454].
Cromer BA, Smith RD, Blair JM, et al. A prospective study of adolescents who choose among levonorgestrel implant (Norplant), medroxyprogesterone acetate (Depo-Provera), or the combined oral contraceptive pill as contraception. Pediatrics. 1994;94(5):687-94. [pmid: 7936897].
Cronin M, Schellschmidt I, Dinger J. Rate of pregnancy after using drospirenone and other progestin-containing oral contraceptives. Obstet Gynecol. 2009;114(3):616-22. [pmid: 19701043].
Curtis KM, Nanda K, Kapp N. Safety of hormonal and intrauterine methods of contraception for women with HIV/AIDS: a systematic review. AIDS. Suppl 1. 2009;23:S55-67. [pmid: 20081389].
Custer B, Longstreth WT Jr, Phillips LE, et al. Hormonal exposures and the risk of intracranial meningioma in women: a population-based case-control study. BMC Cancer. 2006;6:152. [pmid: 16759391].
Cuzick J, Singer A, De Stavola BL, et al. Case-control study of risk factors for cervical intraepithelial neoplasia in young women. Eur J Cancer. 1990;26(6):684-90. [pmid: 2144155].
Dal Maso L, Canzonieri V, Talamini R, et al. Origin of ovarian cancer from benign cysts. Eur J Cancer Prev. 2001;10(2):197-9. [pmid: 11330466].
Daling JR, Madeleine MM, McKnight B, et al. The relationship of human papillomavirus-related cervical tumors to cigarette smoking, oral contraceptive use, and prior herpes simplex virus type 2 infection. Cancer Epidemiol Biomarkers Prev. 1996;5(7):541-8. [pmid: 8827359].
D'Avanzo B, La Vecchia C, Negri E, et al. Oral contraceptive use and risk of myocardial infarction: an Italian case-control study. J Epidemiol Community Health. 1994;48(3):324-5. [pmid: 8051537].
Dawson SI, Smith WC, Watson MS, et al. A cohort study of reproductive risk factors, weight and weight change and the development of diabetes mellitus. Diabetes Obes Metab. 2003;5(4):244-50. [pmid: 12795657].
de Cetina TC, Reyes LP, Gamboa LV, et al. A comparative clinical trial of Norinyl 1 + 35 versus Norinyl 1 + 50 in Merida, Yucatan, Mexico. Adv Contracept. 1990;6(2):125-39. [pmid: 2206018].
de Mos M, Huygen FJ, Stricker BH, et al. Estrogens and the risk of complex regional pain syndrome (CRPS). Pharmacoepidemiol Drug Saf. 2009;18(1):44-52. [pmid: 19111016].
De Stefano V, Rossi E, Paciaroni K, et al. Different circumstances of the first venous thromboembolism among younger or older heterozygous carriers of the G20210A polymorphism in the prothrombin gene. Haematologica. 2003;88(1):61-6. [pmid: 12551828].
de Vet HC, Sturmans F. Risk factors for cervical dysplasia: implications for prevention. Public Health. 1994;108(4):241-9. [pmid: 8066168].
de Vries E, den Tonkelaar I, van Noord PA, et al. Oral contraceptive use in relation to age at menopause in the DOM cohort. Hum Reprod. 2001;16(8):1657-62. [pmid: 11473959].
Deans EI, Grimes DA. Intrauterine devices for adolescents: a systematic review. Contraception. 2009;79(6):418-23. [pmid: 19442775].
Deicas RE, Miller DS, Rademaker AW, et al. The role of contraception in the development of postmolar gestational trophoblastic tumor. Obstet Gynecol. 1991;78(2):221-6. [pmid: 1648697].
DelConte A, Loffer F, Grubb GS. Cycle control with oral contraceptives containing 20 micrograms of ethinyl estradiol. A multicenter, randomized comparison of levonorgestrel/ethinyl estradiol (100 micrograms/20 micrograms) and norethindrone/ethinyl estradiol (1000 micrograms/20 micrograms). Contraception. 1999;59(3):187-93. [pmid: 10382082].
den Tonkelaar I, te Velde ER, Looman CW. Menstrual cycle length preceding menopause in relation to age at menopause. Maturitas. 1998;29(2):115-23. [pmid: 9651900].
Diaz S, Zepeda A, Maturana X, et al. Fertility regulation in nursing women. IX. Contraceptive performance, duration of lactation, infant growth, and bleeding patterns during use of progesterone vaginal rings, progestin-only pills, Norplant implants, and Copper T 380-A intrauterine devices. Contraception. 1997;56(4):223-32. [pmid: 9408703].
Dinerman LM, Wilson MD, Duggan AK, et al. Outcomes of adolescents using levonorgestrel implants vs oral contraceptives or other contraceptive methods. Arch Pediatr Adolesc Med. 1995;149(9):967-72. [pmid: 7655600].
Dinger J, Do Minh T, Buttmann N, et al. Effectiveness of oral contraceptive pills in a large U.S. cohort comparing progestogen and regimen. Obstetrics and Gynecology. 2011;117(1):33-40. [pmid: 21213475].
Dinger JC, Cronin M, Mohner S, et al. Oral contraceptive effectiveness according to body mass index, weight, age, and other factors. Am J Obstet Gynecol. 2009;201(3):263 e1-9. [pmid: 19481720].
Dmitrovic R, Kunselman AR, Legro RS. Continuous compared with cyclic oral contraceptives for the treatment of primary dysmenorrhea: a randomized controlled trial. Obstet Gynecol. 2012;119(6):1143-50. [pmid: 22617578].
Doll H, Vessey M, Painter R. Return of fertility in nulliparous women after discontinuation of the intrauterine device: comparison with women discontinuing other methods of contraception. BJOG. 2001;108(3):304-14. [pmid: 11281473].
Donaghy M, Chang CL, Poulter N. Duration, frequency, recency, and type of migraine and the risk of ischaemic stroke in women of childbearing age. J Neurol Neurosurg Psychiatry. 2002;73(6):747-50. [pmid: 12438482].
Doyle P, Brown A, Beral V, et al. Incidence of and risk factors for Motor NeuroneDisease in UK women: A prospective study. BMC Neurology. 2012;12(1):25. [pmid: 22559076].
Drossaers-Bakker KW, Zwinderman AH, van Zeben D, et al. Pregnancy and oral contraceptive use do not significantly influence outcome in long term rheumatoid arthritis. Ann Rheum Dis. 2002;61(5):405-8. [pmid: 11959763].
Duijkers IJM, Klipping C, Grob P, et al. Effects of a monophasic combined oral contraceptive containing nomegestrol acetate and 17(beta)-oestradiol on ovarian function in comparison to a monophasic combined oral contraceptive containing drospirenone and ethinylestradiol. European Journal of Contraception and Reproductive Health Care. 2010;15(5):314-325. [pmid: 20695770].
Dunson TR, McLaurin VL, Aguayo EL, et al. A multicenter comparative trial of triphasic and monophasic, low-dose combined oral contraceptives. Contraception. 1993;47(6):515-25. [pmid: 8334888].
Dunson TR, McLaurin VL, Grubb GS, et al. A multicenter clinical trial of a progestin-only oral contraceptive in lactating women. Contraception. 1993;47(1):23-35. [pmid: 8435999].
Dunson TR, McLaurin VL, Israngkura B, et al. A comparative study of two low-dose combined oral contraceptives: results from a multicenter trial. Contraception. 1993;48(2):109-19. [pmid: 8403908].
Ebeling K, Ray R, Nischan P, et al. Combined oral contraceptives containing chlormadinone acetate and breast cancer: results of a case-control study. Br J Cancer. 1991;63(5):804-8. [pmid: 1710136].
Edelman A, Gallo MF, Nichols MD, et al. Continuous versus cyclic use of combined oral contraceptives for contraception: systematic Cochrane review of randomized controlled trials. Hum Reprod. 2006;21(3):573-8. [pmid: 16489210].
Edelman AB, Gallo MF, Jensen JT, et al. Continuous or extended cycle vs. cyclic use of combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2005;(3):CD004695. [pmid: 16034942].
Edelman AB, Koontz SL, Nichols MD, et al. Continuous oral contraceptives: are bleeding patterns dependent on the hormones given?. Obstet Gynecol. 2006;107(3):657-65. [pmid: 16507938].
Edwards SM, Zieman M, Jones K, et al. Initiation of oral contraceptives--start now!. J Adolesc Health. 2008;43(5):432-6. [pmid: 18848670].
Eisen A, Lubinski J, Klijn J, et al. Breast cancer risk following bilateral oophorectomy in BRCA1 and BRCA2 mutation carriers: an international case-control study. J Clin Oncol. 2005;23(30):7491-6. [pmid: 16234515].
Elliott AM, Hannaford PC. Use of exogenous hormones by women and lung cancer: evidence from the Royal College of General Practitioners' Oral Contraception Study. Contraception. 2006;73(4):331-5. [pmid: 16531161].
Eluf-Neto J, Booth M, Munoz N, et al. Human papillomavirus and invasive cervical cancer in Brazil. Br J Cancer. 1994;69(1):114-9. [pmid: 8286192].
Endrikat J, Cronin M, Gerlinger C, et al. Double-blind, multicenter comparison of efficacy, cycle control, and tolerability of a 23-day versus a 21-day low-dose oral contraceptive regimen containing 20 microg ethinyl estradiol and 75 microg gestodene. Contraception. 2001;64(2):99-105. [pmid: 11704086].
Endrikat J, Cronin M, Gerlinger C, et al. Open, multicenter comparison of efficacy, cycle control, and tolerability of a 23-day oral contraceptive regimen with 20 microg ethinyl estradiol and 75 microg gestodene and a 21-day regimen with 20 microg ethinyl estradiol and 150 microg desogestrel. Contraception. 2001;64(3):201-7. [pmid: 11704101].
Endrikat J, Dusterberg B, Ruebig A, et al. Comparison of efficacy, cycle control, and tolerability of two low-dose oral contraceptives in a multicenter clinical study. Contraception. 1999;60(5):269-74. [pmid: 10717778].
Endrikat J, Hite R, Bannemerschult R, et al. Multicenter, comparative study of cycle control, efficacy and tolerability of two low-dose oral contraceptives containing 20 microg ethinylestradiol/100 microg levonorgestrel and 20 microg ethinylestradiol/500 microg norethisterone. Contraception. 2001;64(1):3-10. [pmid: 11535206].
Endrikat J, Jaques MA, Mayerhofer M, et al. A twelve-month comparative clinical investigation of two low-dose oral contraceptives containing 20 micrograms ethinylestradiol/75 micrograms gestodene and 20 micrograms ethinylestradiol/150 micrograms desogestrel, with respect to efficacy, cycle control and tolerance. Contraception. 1995;52(4):229-35. [pmid: 8605781].
Endrikat J, Klipping C, Gerlinger C, et al. A double-blind comparative study of the effects of a 23-day oral contraceptive regimen with 20 microg ethinyl estradiol and 75 microg gestodene and a 21-day regimen with 30 microg ethinyl estradiol and 75 microg gestodene on hemostatic variables, lipids, and carbohydrate metabolism. Contraception. 2001;64(4):235-41. [pmid: 11747873].
Endrikat J, Muller U, Dusterberg B. A twelve-month comparative clinical investigation of two low-dose oral contraceptives containing 20 micrograms ethinylestradiol/75 micrograms gestodene and 30 micrograms ethinylestradiol/75 micrograms gestodene, with respect to efficacy, cycle control, and tolerance. Contraception. 1997;55(3):131-7. [pmid: 9115000].
Endrikat J, Noah M, Gerlinger C, et al. Impact of oral contraceptive use on APC-resistance: a prospective, randomized clinical trial with three low-dose preparations. Contraception. 2001;64(4):217-22. [pmid: 11747870].
Endrikat J, Sandri M, Gerlinger C, et al. A Canadian multicentre prospective study on the effects of an oral contraceptive containing 3 mg drospirenone and 30 microg ethinyl oestradiol on somatic and psychological symptoms related to water retention and on body weight. Eur J Contracept Reprod Health Care. 2007;12(3):220-8. [pmid: 17763260].
Endrikat J, Shapiro H, Lukkari-Lax E, et al. A Canadian, multicentre study comparing the efficacy of a levonorgestrel-releasing intrauterine system to an oral contraceptive in women with idiopathic menorrhagia. J Obstet Gynaecol Can. 2009;31(4):340-7. [pmid: 19497153].
Endrikat JS, Milchev NP, Kapamadzija A, et al. Bleeding pattern, tolerance and patient satisfaction with a drospirenone-containing oral contraceptive evaluated in 3488 women in Europe, the Middle East and Canada. Contraception. 2009;79(6):428-32. [pmid: 19442777].
Eng PM, Seeger JD, Loughlin J, et al. Supplementary data collection with case-cohort analysis to address potential confounding in a cohort study of thromboembolism in oral contraceptive initiators matched on claims-based propensity scores. Pharmacoepidemiol Drug Saf. 2008;17(3):297-305. [pmid: 18215000].
Etminan M, Delaney JA, Bressler B, et al. Oral contraceptives and the risk of gallbladder disease: a comparative safety study. CMAJ. 2011;183(8):899-904. [pmid: 21502354].
Ewertz M. Oral contraceptives and breast cancer risk in Denmark. Eur J Cancer. 1992;28A(6-7):1176-81. [pmid: 1627391].
Fernandez E, La Vecchia C, D'Avanzo B, et al. Oral contraceptives, hormone replacement therapy and the risk of colorectal cancer. Br J Cancer. 1996;73(11):1431-5. [pmid: 8645593].
Fernandez E, La Vecchia C, Franceschi S, et al. Oral contraceptive use and risk of colorectal cancer. Epidemiology. 1998;9(3):295-300. [pmid: 9583422].
Ferry S, Hannaford P, Warskyj M, et al. Carpal tunnel syndrome: a nested case-control study of risk factors in women. Am J Epidemiol. 2000;151(6):566-74. [pmid: 10733038].
Feskanich D, Hunter DJ, Willett WC, et al. Oral contraceptive use and risk of melanoma in premenopausal women. Br J Cancer. 1999;81(5):918-23. [pmid: 10555769].
Fioretti F, Tavani A, Bosetti C, et al. Risk factors for breast cancer in nulliparous women. Br J Cancer. 1999;79(11-12):1923-8. [pmid: 10206315].
Fitzgerald C, Feichtinger W, Spona J, et al. A comparison of the effects of two monophasic low dose oral contraceptives on the inhibition of ovulation. Adv Contracept. 1994;10(1):5-18. [pmid: 8030454].
Foidart JM, Wuttke W, Bouw GM, et al. A comparative investigation of contraceptive reliability, cycle control and tolerance of two monophasic oral contraceptives containing either drospirenone or desogestrel. Eur J Contracept Reprod Health Care. 2000;5(2):124-34. [pmid: 10943575].
Ford JH, MacCormac L. Pregnancy and lifestyle study: the long-term use of the contraceptive pill and the risk of age-related miscarriage. Hum Reprod. 1995;10(6):1397-402. [pmid: 7593504].
Forsmo S, Schei B, Langhammer A, et al. How do reproductive and lifestyle factors influence bone density in distal and ultradistal radius of early postmenopausal women? The Nord-Trondelag Health Survey, Norway. Osteoporos Int. 2001;12(3):222-9. [pmid: 11315241].
Franceschi S, Fassina A, Talamini R, et al. The influence of reproductive and hormonal factors on thyroid cancer in women. Rev Epidemiol Sante Publique. 1990;38(1):27-34. [pmid: 2320776].
Franchi M, Ghezzi F, Buttarelli M, et al. Low-dose oral contraceptives in perimenopausal women: Effects on metabolism and symptoms. Italian Journal of Gynaecology and Obstetrics. 2001;13(3):107-111.
Fraser IS, Romer T, Parke S, et al. Effective treatment of heavy and/or prolonged menstrual bleeding with an oral contraceptive containing estradiol valerate and dienogest: a randomized, double-blind Phase III trial. Hum Reprod. 2011;26(10):2698-708. [pmid: 21784734].
Frega A, Scardamaglia P, Piazze J, et al. Oral contraceptives and clinical recurrence of human papillomavirus lesions and cervical intraepithelial neoplasia following treatment. Int J Gynaecol Obstet. 2008;100(2):175-8. [pmid: 18001738].
French R, Sorhaindo Annik M, Van Vliet Huib AAM, et al. Progestogen-releasing intrauterine systems versus other forms of reversible contraceptives for contraception. Cochrane Database of Systematic Reviews. 2004;(3):CD001776. [pmid: 15266453].
Friedman AJ, Wheeler J. Efficacy and safety of ethynodiol diacetate, 1 mg, with ethinyl estradiol, 35 micrograms, with an emphasis on contraceptive efficacy. A phase IV trial. J Reprod Med. 1991;36(4 Suppl):328-33. [pmid: 2046081].
Friedman AJ, Wheeler JM. Incidence of ovarian cyst formation in women taking ethynodiol diacetate, 1 mg, with ethinyl estradiol, 35 micrograms. J Reprod Med. 1991;36(4 Suppl):345-9. [pmid: 2046084].
Frise S, Kreiger N, Gallinger S, et al. Menstrual and reproductive risk factors and risk for gastric adenocarcinoma in women: findings from the canadian national enhanced cancer surveillance system. Ann Epidemiol. 2006;16(12):908-16. [pmid: 16843679].
Fruzzetti F, Lazzarini V, Ricci C, et al. Effect of an oral contraceptive containing 30 (mu)g ethinylestradiol plus 3 mg drospirenone on body composition of young women affected by premenstrual syndrome with symptoms of water retention. Contraception. 2007;76(3):190-194. [pmid: 17707715].
Furberg H, Millikan RC, Geradts J, et al. Reproductive factors in relation to breast cancer characterized by p53 protein expression (United States). Cancer Causes Control. 2003;14(7):609-18. [pmid: 14575358].
Gaffield ME, Kapp N, Ravi A. Use of combined oral contraceptives post abortion. Contraception. 2009;80(4):355-62. [pmid: 19751858].
Galanti MR, Hansson L, Lund E, et al. Reproductive history and cigarette smoking as risk factors for thyroid cancer in women: a population-based case-control study. Cancer Epidemiol Biomarkers Prev. 1996;5(6):425-31. [pmid: 8781737].
Gallo Maria F, Lopez Laureen M, Grimes David A, et al. Combination contraceptives: effects on weight. Cochrane Database Syst Rev. (4):CD003987. [pmid: 18843652].
Gallo Maria F, Lopez Laureen M, Grimes David A, et al. Combination contraceptives: effects on weight. Cochrane Database Syst Rev. 2011;(9):CD003987. [pmid: 21901687].
Gammon MD, Hibshoosh H, Terry MB, et al. Oral contraceptive use and other risk factors in relation to HER-2/neu overexpression in breast cancer among young women. Cancer Epidemiol Biomarkers Prev. 1999;8(5):413-9. [pmid: 10350436].
Gangat N, Wolanskyj AP, Schwager SM, et al. Estrogen-based hormone therapy and thrombosis risk in women with essential thrombocythemia. Cancer. 2006;106(11):2406-11. [pmid: 16628652].
Garcia-Enguidanos A, Martinez D, Calle ME, et al. Long-term use of oral contraceptives increases the risk of miscarriage. Fertil Steril. 2005;83(6):1864-6. [pmid: 15950668].
Garza-Flores J, Martinez M, Valles De, Bourges V, et al. Comparative assessment of two low-dose oral contraceptives, Lo-Femenal and Lo-Estrin, in Mexican women. Adv Contracept. 1992;8(4):291-301. [pmid: 1290331].
Gateley CA, Bundred NJ, West RR, et al. A case control study of factors associated with macroscopic breast cysts. Eur J Cancer. 1992;28(1):125-7. [pmid: 1567663].
Gemer O, Moscovici O, Ben-Horin CL, et al. Oral contraceptives and liver hemangioma: a case-control study. Acta Obstet Gynecol Scand. 2004;83(12):1199-201. [pmid: 15548156].
Gemzell-Danielsson K, van Heusden AM, Killick SR, et al. Improving cycle control in progestogen-only contraceptive pill users by intermittent treatment with a new anti-progestogen. Hum Reprod. 2002;17(10):2588-93. [pmid: 12351534].
Ghanem KG, Datta SD, Unger ER, et al. The association of current hormonal contraceptive use with type-specific HPV detection. Sex Transm Infect. 2011;87(5):385-8. [pmid: 21772042].
Gheit SA. Bleeding patterns associated with progestin-only contraceptives: A prospective controlled trial comparing Mirena versus progestin-only pill. Middle East Fertility Society Journal. 2009;14(3):216-219.
Gill JK, Press MF, Patel AV, et al. Oral contraceptive use and risk of breast carcinoma in situ (United States). Cancer Causes Control. 2006;17(9):1155-62. [pmid: 17006721].
Golbs S, Domhardt R, Presl J, et al. Clinical findings with the oral contraceptive combination ethinylestradiol/dienogest in the Czech Republic. Methods Find Exp Clin Pharmacol. 2002;24(10):689-96. [pmid: 12616963].
Gomes AL, Guimaraes MD, Gomes CC, et al. A case-control study of risk factors for breast cancer in Brazil, 1978-1987. Int J Epidemiol. 1995;24(2):292-9. [pmid: 7635588].
Graff-Iversen S, Hammar N, Thelle DS, et al. Use of oral contraceptives and mortality during 14 years' follow-up of Norwegian women. Scand J Public Health. 2006;34(1):11-6. [pmid: 16449039].
Gram IT, Macaluso M, Stalsberg H. Oral contraceptive use and the incidence of cervical intraepithelial neoplasia. Am J Obstet Gynecol. 1992;167(1):40-4. [pmid: 1442952].
Greeley C, Schroeder S, Silverberg SG. Microglandular hyperplasia of the cervix: a true “pill” lesion?. Int J Gynecol Pathol. 1995;14(1):50-4. [pmid: 7883426].
Green A, Purdie D, Bain C, et al. Tubal sterilisation, hysterectomy and decreased risk of ovarian cancer. Survey of Women's Health Study Group. Int J Cancer. 1997;71(6):948-51. [pmid: 9185694].
Green J, Berrington de Gonzalez A, Smith JS, et al. Human papillomavirus infection and use of oral contraceptives. Br J Cancer. 2003;88(11):1713-20. [pmid: 12771986].
Grodstein F, Colditz GA, Hunter DJ, et al. A prospective study of symptomatic gallstones in women: relation with oral contraceptives and other risk factors. Obstet Gynecol. 1994;84(2):207-14. [pmid: 8041531].
Gruber DM, Huber JC, Melis GB, et al. A comparison of the cycle control, safety, and efficacy profile of a 21-day regimen of ethinylestradiol 20(mu)g and drospirenone 3mg with a 21-day regimen of ethinylestradiol 20(mu)g and desogestrel 150(mu)g. Treatments in Endocrinology. 2006;5(2):115-121. [pmid: 16542051].
Guillemette C, Millikan RC, Newman B, et al. Genetic polymorphisms in uridine diphospho-glucuronosyltransferase 1A1 and association with breast cancer among. African Americans Cancer Res. 2000;60(4):950-6. [pmid: 10706110].
Haddad LB, Curtis KM, Legardy-Williams JK, et al. Contraception for individuals with sickle cell disease: A systematic review of the literature. Contraception. 2012;85(6):527-537. [pmid: 22152587].
Halbe HW, de Melo NR, Bahamondes L, et al. Efficacy and acceptability of two monophasic oral contraceptives containing ethinylestradiol and either desogestrel or gestodene. Eur J Contracept Reprod Health Care. 1998;3(3):113-20. [pmid: 9853201].
Hallquist A, Hardell L, Degerman A, et al. Thyroid cancer: reproductive factors, previous diseases, drug intake, family history and diet. A case-control study. Eur J Cancer Prev. 1994;3(6):481-8. [pmid: 7858480].
Halpern V, Grimes DA, Lopez L, et al. Strategies to improve adherence and acceptability of hormonal methods for contraception. Cochrane Database Syst Rev. 2006;(1):CD004317. [pmid: 16437483].
Halpern V, Raymond EG, Lopez LM. Repeated use of pre- and postcoital hormonal contraception for prevention of pregnancy. Cochrane Database Syst Rev. 2010;(1):CD007595. [pmid: 20091641].
Hampton RM, Fisher AC, Pagano S, et al. Scheduled and unscheduled bleeding patterns with two combined hormonal contraceptives: application of new recommendations for standardization. Fertil Steril. 2009;92(2):434-40. [pmid: 18930189].
Hampton RM, Short M, Bieber E, et al. Comparison of a novel norgestimate/ethinyl estradiol oral contraceptive (Ortho Tri-Cyclen Lo) with the oral contraceptive Loestrin Fe 1/20. Contraception. 2001;63(6):289-95. [pmid: 11672549].
Hampton RM, Zhang HF, Barnowski C, et al. Bleeding patterns with monophasic and triphasic low-dose ethinyl estradiol combined oral contraceptives. Contraception. 2008;77(6):415-9. [pmid: 18477490].
Hancock DB, Haberg SE, Furu K, et al. Oral contraceptive pill use before pregnancy and respiratory outcomes in early childhood. Pediatr Allergy Immunol. 2011;22(5):528-36. [pmid: 21294776].
Hankinson SE, Colditz GA, Manson JE, et al. A prospective study of oral contraceptive use and risk of breast cancer (Nurses' Health Study, United States). Cancer Causes Control. 1997;8(1):65-72. [pmid: 9051324].
Hannaford PC, Croft PR, Kay CR. Oral contraception and stroke. Evidence from the Royal College of General Practitioners' Oral Contraception Study. Stroke. 1994;25(5):935-42. [pmid: 8165687].
Harris RE, Zang EA, Wynder EL. Oral contraceptives and breast cancer risk: a case-control study. Int J Epidemiol. 1990;19(2):240-6. [pmid: 2376430].
Harris TG, Miller L, Kulasingam SL, et al. Depot-medroxyprogesterone acetate and combined oral contraceptive use and cervical neoplasia among women with oncogenic human papillomavirus infection. Am J Obstet Gynecol. 2009;200(5):489 e1-8. [pmid: 19375566].
Hatch EE, Linet MS, Zhang J, et al. Reproductive and hormonal factors and risk of brain tumors in adult females. Int J Cancer. 2005;114(5):797-805. [pmid: 15609304].
Hedderson MM, Ferrara A, Williams MA, et al. Androgenicity of progestins in hormonal contraceptives and the risk of gestational diabetes mellitus. Diabetes Care. 2007;30(5):1062-8. [pmid: 17303784].
Heinemann LA, Assmann A, Spannagl M, et al. Normalized activated protein C ratio itself not associated with increased risk of venous thromboembolism. Contraception. 1998;58(5):321-2. [pmid: 9883389].
Heinemann LA, Kluft C, Spannagl M, et al. The association between extrinsic activated protein C resistance and venous thromboembolism in women. Contraception. 2002;66(5):297-304. [pmid: 12443958].
Heinemann LA, Weimann A, Gerken G, et al. Modern oral contraceptive use and benign liver tumors: the German Benign Liver Tumor Case-Control Study. Eur J Contracept Reprod Health Care. 1998;3(4):194-200. [pmid: 10036602].
Hernan MA, Hohol MJ, Olek MJ, et al. Oral contraceptives and the incidence of multiple sclerosis. Neurology. 2000;55(6):848-54. [pmid: 10994007].
Heuser P, Tonga K, Hopkins R, et al. Specific oral contraceptive use and venous thromboembolism resulting in hospital admission. N Z Med J. 2004;117(1206):U1176. [pmid: 15570345].
Hickson SS, Miles KL, McDonnell BJ, et al. Use of the oral contraceptive pill is associated with increased large artery stiffness in young women: the ENIGMA study. J Hypertens. 2011;29(6):1155-9. [pmid: 21505350].
Hildesheim A, Herrero R, Castle PE, et al. HPV co-factors related to the development of cervical cancer: results from a population-based study in Costa Rica. Br J Cancer. 2001;84(9):1219-26. [pmid: 11336474].
Hoekstra AV, Kosinski A, Huh WK. Hormonal contraception and false-positive cervical cytology: is there an association?. J Low Genit Tract Dis. 2006;10(2):102-6. [pmid: 16633239].
Holly EA, Aston DA, Ahn DK, et al. Uveal melanoma, hormonal and reproductive factors in women. Cancer Res. 1991;51(5):1370-2. [pmid: 1997174].
Holly EA, Cress RD, Ahn DK. Cutaneous melanoma in women. III. Reproductive factors and oral contraceptive use. Am J Epidemiol. 1995;141(10):943-50. [pmid: 7741124].
Holmberg L, Lund E, Bergstrom R, et al. Oral contraceptives and prognosis in breast cancer: effects of duration, latency, recency, age at first use and relation to parity and body mass index in young women with breast cancer. Eur J Cancer. 1994;30A(3):351-4. [pmid: 8204358].
Holt VL, Cushing-Haugen KL, Daling JR. Oral contraceptives, tubal sterilization, and functional ovarian cyst risk. Obstet Gynecol. 2003;102(2):252-8. [pmid: 12907096].
Holt VL, Daling JR, McKnight B, et al. Functional ovarian cysts in relation to the use of monophasic and triphasic oral contraceptives. Obstet Gynecol. 1992;79(4):529-33. [pmid: 1553170].
Hoyo C, Cousins DS, Bisgrove EZ, et al. Depo medroxyprogesterone acetate (DMPA) and combined oral contraceptives and cervical carcinoma in-situ in women aged 50 years and under. West Indian Med J. 2004;53(6):406-12. [pmid: 15816269].
Hsing AW, Hoover RN, McLaughlin JK, et al. Oral contraceptives and primary liver cancer among young women. Cancer Causes Control. 1992;3(1):43-8. [pmid: 1536912].
Hsing AW, McLaughlin JK, Hoover RN, et al. Parity and primary liver cancer among young women. J Natl Cancer Inst. 1992;84(14):1118-9. [pmid: 1619686].
Hsing AW, Nam JM, Co Chien HT, et al. Risk factors for adrenal cancer: an exploratory study. Int J Cancer. 1996;65(4):432-6. [pmid: 8621222].
Huber J, Foidart JM, Wuttke W, et al. Efficacy and tolerability of a monophasic oral contraceptive containing ethinylestradiol and drospirenone. Eur J Contracept Reprod Health Care. 2000;5(1):25-34. [pmid: 10836660].
Iliadou A, Milsom I, Pedersen NL, et al. Risk of urinary incontinence symptoms in oral contraceptive users: a national cohort study from the Swedish Twin Register. Fertil Steril. 2009;92(2):428-33. [pmid: 18706546].
Ireland B, Corbett JJ, Wallace RB. The search for causes of idiopathic intracranial hypertension. A preliminary case-control study. Arch Neurol. 1990;47(3):315-20. [pmid: 2310315].
Ismail MT. A randomised comparative study of Triquilar versus Marvelon: the Malaysian experience. Malays J Reprod Health. 1991;9(1):9-17. [pmid: 12317444].
Iversen L, Hannaford PC, Elliott AM, et al. Long term effects of hysterectomy on mortality: nested cohort study. BMJ. 2005;330(7506):1482. [pmid: 15930026].
Iversen L, Hannaford PC, Lee AJ, et al. Impact of lifestyle in middle-aged women on mortality: evidence from the Royal College of General Practitioners' Oral Contraception Study. Br J Gen Pract. 2010;60(577):563-9. [pmid: 20822689].
Jacobs EJ, White E, Weiss NS. Exogenous hormones, reproductive history, and colon cancer (Seattle, Washington, USA). Cancer Causes Control. 1994;5(4):359-66. [pmid: 8080948].
Jacobson JS, Neugut AI, Garbowski GC, et al. Reproductive risk factors for colorectal adenomatous polyps (New York City, NY, United States). Cancer Causes Control. 1995;6(6):513-8. [pmid: 8580299].
Jakubowska A, Gronwald J, Menkiszak J, et al. Ovarian cancer risk in Polish BRCA1 mutation carriers is not associated with the prohibitin 3' untranslated region polymorphism. BMC Cancer. 2008;8:90. [pmid: 18397521].
Jamieson DJ, Terrell ML, Aguocha NN, et al. Dietary exposure to brominated flame retardants and abnormal Pap test results. J Womens Health (Larchmt). 2011;20(9):1269-78. [pmid: 21797757].
Jellesen R, Strandberg-Larsen K, Jorgensen T, et al. Maternal use of oral contraceptives and risk of fetal death. Paediatr Perinat Epidemiol. 2008;22(4):334-40. [pmid: 18578746].
Ji BT, Hatch MC, Chow WH, et al. Anthropometric and reproductive factors and the risk of pancreatic cancer: a case-control study in Shanghai, China. Int J Cancer. 1996;66(4):432-7. [pmid: 8635856].
Jick SS, Walker AM, Jick H. Oral contraceptives and endometrial cancer. Obstet Gynecol. 1993;82(6):931-5. [pmid: 8233267].
Joffe H, Cohen LS, Harlow BL. Impact of oral contraceptive pill use on premenstrual mood: predictors of improvement and deterioration. Am J Obstet Gynecol. 2003;189(6):1523-30. [pmid: 14710055].
Jones CJ, Brinton LA, Hamman RF, et al. Risk factors for in situ cervical cancer: results from a case-control study. Cancer Res. 1990;50(12):3657-62. [pmid: 2340514].
Jorgensen C, Picot MC, Bologna C, et al. Oral contraception, parity, breast feeding, and severity of rheumatoid arthritis. Ann Rheum Dis. 1996;55(2):94-8. [pmid: 8712873].
Jukkola TM, Makivaara LA, Luukkaala T, et al. The effects of parity, oral contraceptive use and hormone replacement therapy on the incidence of varicose veins. J Obstet Gynaecol. 2006;26(5):448-51. [pmid: 16846875].
Jung SY, Bae HJ, Park BJ, et al. Parity and risk of hemorrhagic strokes. Neurology. 2010;74(18):1424-9. [pmid: 20335561].
Kabat GC, Silvera SA, Miller AB, et al. A cohort study of reproductive and hormonal factors and renal cell cancer risk in women. Br J Cancer. 2007;96(5):845-9. [pmid: 17311018].
Kallen B, Mastroiacovo P, Lancaster PA, et al. Oral contraceptives in the etiology of isolated hypospadias. Contraception. 1991;44(2):173-82. [pmid: 1893709].
Kaplan B, Nahum R, Yairi Y, et al. Use of various contraceptive methods and time of conception in a community-based population. Eur J Obstet Gynecol Reprod Biol. 2005;123(1):72-6. [pmid: 16054284].
Kapp N, Curtis KM. Hormonal contraceptive use among women with liver tumors: a systematic review. Contraception. 2009;80(4):387-90. [pmid: 19751862].
Karagas MR, Stukel TA, Dykes J, et al. A pooled analysis of 10 case-control studies of melanoma and oral contraceptive use. Br J Cancer. 2002;86(7):1085-92. [pmid: 11953854].
Karlson EW, Mandl LA, Hankinson SE, et al. Do breast-feeding and other reproductive factors influence future risk of rheumatoid arthritis? Results from the Nurses' Health Study. Arthritis Rheum. 2004;50(11):3458-67. [pmid: 15529351].
Kew MC, Song E, Mohammed A, et al. Contraceptive steroids as a risk factor for hepatocellular carcinoma: a case/control study in South African black women. Hepatology. 1990;11(2):298-302. [pmid: 2155169].
Kishk NA. Breast cancer in relation to some reproductive factors. J Egypt Public Health Assoc. 1999;74(5-6):547-66. [pmid: 17219863].
Kjaer SK, Engholm G, Dahl C, et al. Case-control study of risk factors for cervical squamous-cell neoplasia in Denmark. III. Role of oral contraceptive use. Cancer Causes Control. 1993;4(6):513-9. [pmid: 8280828].
Kjaer SK. Risk factors for cervical neoplasia in Denmark. APMIS Suppl. 1998;80:1-41. [pmid: 9693662].
Kjellberg L, Hallmans G, Ahren AM, et al. Smoking, diet, pregnancy and oral contraceptive use as risk factors for cervical intra-epithelial neoplasia in relation to human papillomavirus infection. Br J Cancer. 2000;82(7):1332-8. [pmid: 10755410].
Kjos SL, Peters RK, Xiang A, et al. Contraception and the risk of type 2 diabetes mellitus in Latina women with prior gestational diabetes mellitus. JAMA. 1998;280(6):533-8. [pmid: 9707143].
Kjos SL, Shoupe D, Douyan S, et al. Effect of low-dose oral contraceptives on carbohydrate and lipid metabolism in women with recent gestational diabetes: results of a controlled, randomized, prospective study. Am J Obstet Gynecol. 1990;163(6 Pt 1):1822-7. [pmid: 2256489].
Klein BE, Klein R, Moss SE. Mortality and hormone-related exposures in women with diabetes. Diabetes Care. 1999;22(2):248-52. [pmid: 10333941].
Koltyn KF, Landis JA, Dannecker EA. Influence of oral contraceptive use on pain perception and blood pressure. Health Care Women Int. 2003;24(3):221-9. [pmid: 12746013].
Koomen ER, Joosse A, Herings RM, et al. Does use of estrogens decrease the Breslow thickness of melanoma of the skin? Oral contraceptives and hormonal replacement therapy. Melanoma Res. 2009;19(5):327-32. [pmid: 19593232].
Koomen ER, Joosse A, Herings RM, et al. Estrogens, oral contraceptives and hormonal replacement therapy increase the incidence of cutaneous melanoma: a population-based case-control study. Ann Oncol. 2009;20(2):358-64. [pmid: 18725391].
Kordi Tamandani DM, Sobti RC, Shekari M, et al. No association of TAP1 and TAP2 genes polymorphism with risk of cervical cancer in north Indian population. J Assist Reprod Genet. 2009;26(4):173-8. [pmid: 19263211].
Korhonen K, Raitanen J, Isola J, et al. Exogenous sex hormone use and risk of meningioma: a population-based case-control study in Finland. Cancer Causes Control. 2010;21(12):2149-56. [pmid: 20730482].
Kreiger N, Lacroix J, Sloan M. Hormonal factors and pancreatic cancer in women. Ann Epidemiol. 2001;11(8):563-7. [pmid: 11709276].
Kruger-Kjaer S, van den Brule AJ, Svare EI, et al. Different risk factor patterns for high-grade and low-grade intraepithelial lesions on the cervix among HPV-positive and HPV-negative young women. Int J Cancer. 1998;76(5):613-9. [pmid: 9610715].
Kulier R, Helmerhorst FM, Maitra N, et al. Effectiveness and acceptability of progestogens in combined oral contraceptives - A systematic review. Reproductive Health. 2004;1(1):1. [pmid: 15357865].
Kune GA, Kune S, Watson LF. Oral contraceptive use does not protect against large bowel cancer. Contraception. 1990;41(1):19-25. [pmid: 2302944].
Kwiecien M, Edelman A, Nichols MD, et al. Bleeding patterns and patient acceptability of standard or continuous dosing regimens of a low-dose oral contraceptive: a randomized trial. Contraception. 2003;67(1):9-13. [pmid: 12521651].
La Vecchia C, Negri E, Franceschi S, et al. Oral contraceptives and breast cancer: a cooperative Italian study. Int J Cancer. 1995;60(2):163-7. [pmid: 7829209].
La Vecchia C, Ron E, Franceschi S, et al. A pooled analysis of case-control studies of thyroid cancer. III. Oral contraceptives, menopausal replacement therapy and other female hormones. Cancer Causes Control. 1999;10(2):157-66. [pmid: 10231164].
Lacey JV Jr, Brinton LA, Abbas FM, et al. Oral contraceptives as risk factors for cervical adenocarcinomas and squamous cell carcinomas. Cancer Epidemiol Biomarkers Prev. 1999;8(12):1079-85. [pmid: 10613340].
LaGuardia KD, Shangold G, Fisher A, et al. Efficacy, safety and cycle control of five oral contraceptive regimens containing norgestimate and ethinyl estradiol. Contraception. 2003;67(6):431-7. [pmid: 12814811].
Lakha F, Ho PC, Van der Spuy ZM, et al. A novel estrogen-free oral contraceptive pill for women: multicentre, double-blind, randomized controlled trial of mifepristone and progestogen-only pill (levonorgestrel). Hum Reprod. 2007;22(9):2428-36. [pmid: 17609247].
Lammers P, op ten Berg M. Phase III clinical trial with a new oral contraceptive containing 150 micrograms desogestrel and 20 micrograms ethinylestradiol. Acta Obstet Gynecol Scand. 1991;70(6):497-500. [pmid: 1837199].
Lancaster JM, Wenham RM, Halabi S, et al. No relationship between ovarian cancer risk and progesterone receptor gene polymorphism in a population-based, case-control study in North Carolina. Cancer Epidemiol Biomarkers Prev. 2003;12(3):226-7. [pmid: 12646513].
Lanes SF, Birmann B, Walker AM, et al. Oral contraceptive type and functional ovarian cysts. Am J Obstet Gynecol. 1992;166(3):956-61. [pmid: 1550172].
Lao TT, Chan OK, Suen SSH, et al. Do prior contraceptive methods impact maternal carriage in patients with Hepatitis B?. Hepatitis Monthly. 2011;11(10):829-834. [pmid: 22224082].
Lavreys L, Chohan V, Overbaugh J, et al. Hormonal contraception and risk of cervical infections among HIV-1-seropositive Kenyan women. AIDS. 2004;18(16):2179-84. [pmid: 15577651].
Lawrie TA, Helmerhorst FM, Maitra NK, et al. Types of progestogens in combined oral contraception: effectiveness and side-effects. Cochrane Database Syst Rev. 2011;(5):CD004861. [pmid: 21563141].
Le MG, Cabanes PA, Desvignes V, et al. Oral contraceptive use and risk of cutaneous malignant melanoma in a case-control study of French women. Cancer Causes Control. 1992;3(3):199-205. [pmid: 1610966].
Lea CS, Holly EA, Hartge P, et al. Reproductive risk factors for cutaneous melanoma in women: a case-control study. Am J Epidemiol. 2007;165(5):505-13. [pmid: 17158470].
Lee E, Grutsch J, Persky V, et al. Association of meningioma with reproductive factors. Int J Cancer. 2006;119(5):1152-7. [pmid: 16570277].
Lee JE, Hankinson SE, Cho E. Reproductive factors and risk of renal cell cancer: the Nurses' Health Study. Am J Epidemiol. 2009;169(10):1243-50. [pmid: 19329527].
Lee JS, Bracci PM, Holly EA. Non-Hodgkin lymphoma in women: reproductive factors and exogenous hormone use. Am J Epidemiol. 2008;168(3):278-88. [pmid: 18550561].
Leibenluft E. Women with bipolar illness: clinical and research issues. Am J Psychiatry. 1996;153(2):163-73. [pmid: 8561195].
LeResche L, Mancl L, Sherman JJ, et al. Changes in temporomandibular pain and other symptoms across the menstrual cycle. Pain. 2003;106(3):253-61. [pmid: 14659508].
Levi F, Franceschi S, Gulie C, et al. Female thyroid cancer: the role of reproductive and hormonal factors in Switzerland. Oncology. 1993;50(4):309-15. [pmid: 8497382].
Levi F, La Vecchia C, Gulie C, et al. Oral contraceptives and the risk of endometrial cancer. Cancer Causes Control. 1991;2(2):99-103. [pmid: 1873443].
Levi F, Lucchini F, Pasche C, et al. Oral contraceptives, menopausal hormone replacement treatment and breast cancer risk. Eur J Cancer Prev. 1996;5(4):259-66. [pmid: 8894563].
Lewis DP, Van Dyke DC, Stumbo PJ, et al. Drug and environmental factors associated with adverse pregnancy outcomes. Part I: Antiepileptic drugs, contraceptives, smoking, and folate. Ann Pharmacother. 1998;32(7-8):802-17. [pmid: 9681097].
Li DK, Daling JR, Mueller BA, et al. Oral contraceptive use after conception in relation to the risk of congenital urinary tract anomalies. Teratology. 1995;51(1):30-6. [pmid: 7597655].
Lidegaard O. Oral contraception and risk of a cerebral thromboembolic attack: results of a case-control study. BMJ. 1993;306(6883):956-63. [pmid: 8490470].
Lindblad P, Mellemgaard A, Schlehofer B, et al. International renal-cell cancer study. V. Reproductive factors, gynecologic operations and exogenous hormones. Int J Cancer. 1995;61(2):192-8. [pmid: 7705947].
Lindh I, Ellstrom AA, Milsom I. The effect of combined oral contraceptives and age on dysmenorrhoea: an epidemiological study. Hum Reprod. 2012;27(3):676-82. [pmid: 22252090].
Lipworth L, Katsouyanni K, Stuver S, et al. Oral contraceptives, menopausal estrogens, and the risk of breast cancer: a case-control study in Greece. Int J Cancer. 1995;62(5):548-51. [pmid: 7665225].
Liu SL, Lebrun CM. Effect of oral contraceptives and hormone replacement therapy on bone mineral density in premenopausal and perimenopausal women: a systematic review. Br J Sports Med. 2006;40(1):11-24. [pmid: 16371485].
Longatto-Filho A, Hammes LS, Sarian LO, et al. Hormonal Contraceptives and the Length of Their Use Are Not Independent Risk Factors for High-Risk HPV Infections or High-Grade CIN. Gynecol Obstet Invest. 2010. Dec. 9. [pmid: 21150159].
Lopez Laureen M, Grimes David A, Schulz Kenneth F. Steroidal contraceptives: effect on carbohydrate metabolism in women without diabetes mellitus. Cochrane Database Syst Rev. 2009;(4):CD006133. [pmid: 19821355].
Lopez Laureen M, Grimes David A, Schulz Kenneth F. Steroidal contraceptives: effect on carbohydrate metabolism in women without diabetes mellitus. Cochrane Database Syst Rev. 2012;(4):CD006133. [pmid: 22513937].
Lopez Laureen M, Grimes David A, Schulz Kenneth F, et al. Steroidal contraceptives: effect on bone fractures in women. Cochrane Database Syst Rev. 2009;(2):CD006033. [pmid: 19370623].
Lopez Laureen M, Grimes David A, Schulz Kenneth F, et al. Steroidal contraceptives: effect on bone fractures in women. Cochrane Database Syst Rev. 2011;(7):CD006033. [pmid: 21735401].
Lopez Laureen M, Steiner M, Grimes David A, et al. Strategies for communicating contraceptive effectiveness. Cochrane Database Syst Rev. 2008;(2):CD006964. [pmid: 18425974].
Lopez LM, Edelman A, Chen-Mok M, et al. Progestin-only contraceptives: effects on weight. Cochrane Database Syst Rev. 2011;(4):CD008815. [pmid: 21491411].
Lopez LM, Grimes DA, Chen-Mok M, et al. Hormonal contraceptives for contraception in overweight or obese women. Cochrane Database Syst Rev. 2010;(7):CD008452. [pmid: 20614470].
Loughlin J, Seeger JD, Eng PM, et al. Risk of hyperkalemia in women taking ethinylestradiol/drospirenone and other oral contraceptives. Contraception. 2008;78(5):377-83. [pmid: 18929734].
Louvanto K, Rintala MA, Syrjanen KJ, et al. Incident cervical infections with high- and low-risk human papillomavirus (HPV) infections among mothers in the prospective Finnish Family HPV Study. BMC Infect Dis. 2011;11:179. [pmid: 21696607].
Ludicke F, Gaspard UJ, Demeyer F, et al. Randomized controlled study of the influence of two low estrogen dose oral contraceptives containing gestodene or desogestrel on carbohydrate metabolism. Contraception. 2002;66(6):411-5. [pmid: 12499033].
Lund E. Oral contraceptives and premenopausal breast cancer. Acta Obstet Gynecol Scand. 1990;69(4):355-6. [pmid: 2244470].
Machado RB, de Melo NR, Maia H Jr. Bleeding patterns and menstrual-related symptoms with the continuous use of a contraceptive combination of ethinylestradiol and drospirenone: a randomized study. Contraception. 2010;81(3):215-22. [pmid: 20159177].
Mack WJ, Preston-Martin S, Bernstein L, et al. Reproductive and hormonal risk factors for thyroid cancer in Los Angeles County females. Cancer Epidemiol Biomarkers Prev. 1999;8(11):991-7. [pmid: 10566554].
Magnusson CM, Persson IR, Baron JA, et al. The role of reproductive factors and use of oral contraceptives in the aetiology of breast cancer in women aged 50 to 74 years. Int J Cancer. 1999;80(2):231-6. [pmid: 9935204].
Makelburg ABU, Veeger NJGM, Middeldorp S, et al. Different risk of deep vein thrombosis and pulmonary embolism in carriers with factor V Leiden compared with non-carriers, but not in other thrombophilic defects. results from a large retrospective family cohort study. Haematologica. 2010;95(6):1030-1033. [pmid: 20007142].
Marais DJ, Constant D, Allan B, et al. Cervical human papillomavirus (HPV) infection and HPV type 16 antibodies in South African women. J Clin Microbiol. 2008;46(2):732-9. [pmid: 18077644].
Marchbanks PA, McDonald JA, Wilson HG, et al. The NICHD Women's Contraceptive and Reproductive Experiences Study: methods and operational results. Ann Epidemiol. 2002;12(4):213-21. [pmid: 11988408].
Marchbanks PA, Wilson H, Bastos E, et al. Cigarette smoking and epithelial ovarian cancer by histologic type. Obstet Gynecol. 2000;95(2):255-60. [pmid: 10674590].
Marcus PM, Baird DD, Millikan RC, et al. Adolescent reproductive events and subsequent breast cancer risk. Am J Public Health. 1999;89(8):1244-7. [pmid: 10432916].
Marks M, Gravitt PE, Gupta SB, et al. Combined oral contraceptive use increases HPV persistence but not new HPV detection in a cohort of women from Thailand. J Infect Dis. 2011;204(10):1505-13. [pmid: 21964399].
Marshall LM, Spiegelman D, Goldman MB, et al. A prospective study of reproductive factors and oral contraceptive use in relation to the risk of uterine leiomyomata. Fertil Steril. 1998;70(3):432-9. [pmid: 9757871].
Martinelli I, Sacchi E, Landi G, et al. High risk of cerebral-vein thrombosis in carriers of a prothrombin-gene mutation and in users of oral contraceptives. N Engl J Med. 1998;338(25):1793-7. [pmid: 9632445].
Martinez ME, Grodstein F, Giovannucci E, et al. A prospective study of reproductive factors, oral contraceptive use, and risk of colorectal cancer. Cancer Epidemiol Biomarkers Prev. 1997;6(1):1-5. [pmid: 8993789].
Martinez-Frias ML, Bermejo E, Rodriguez-Pinilla E, et al. Periconceptional exposure to contraceptive pills and risk for Down syndrome. J Perinatol. 2001;21(5):288-92. [pmid: 11536021].
Masson S, Franssen E, Hilditch JR, et al. A clinical comparison of two triphasic oral contraceptives with levonorgestrel or norethindrone: a prospective, randomized, single-blind study. Contraception. 1993;47(1):43-54. [pmid: 8436001].
Mastrantonio M, Minhas H, Gammon A. Antibiotics, the pill, and pregnancy. J Accid Emerg Med. 1999;16(4):268-70. [pmid: 10417934].
Mavranezouli I. The cost-effectiveness of long-acting reversible contraceptive methods in the UK: analysis based on a decision-analytic model developed for a National Institute for Health and Clinical Excellence (NICE) clinical practice guideline. Hum Reprod. 2008;23(6):1338-45. [pmid: 18372257].
Mayberry RM. Age-specific patterns of association between breast cancer and risk factors in black women, ages 20 to 39 and 40 to 54. Ann Epidemiol. 1994;4(3):205-13. [pmid: 8055121].
McCredie MR, Dite GS, Giles GG, et al. Breast cancer in Australian women under the age of 40. Cancer Causes Control. 1998;9(2):189-98. [pmid: 9578296].
McFarlane-Anderson N, Bazuaye PE, Jackson MD, et al. Cervical dysplasia and cancer and the use of hormonal contraceptives in Jamaican women. BMC Womens Health. 2008;8:9. [pmid: 18513406].
McGrath M, Michaud DS, De Vivo I. Hormonal and reproductive factors and the risk of bladder cancer in women. Am J Epidemiol. 2006;163(3):236-44. [pmid: 16319290].
McLaurin VL, Dunson BA, Dunson TR. A comparative study of 35 mcg and 50 mcg combined oral contraceptives: results from a multicenter clinical trial. Contraception. 1991;44(5):489-503. [pmid: 1797464].
Memon S, Iversen L, Hannaford PC. Is the oral contraceptive pill associated with fracture in later life? New evidence from the Royal College of General Practitioners Oral Contraception Study. Contraception. 2011;84(1):40-7. [pmid: 21664509].
Merki-Feld GS, Rosselli M, Dubey RK, et al. Long-term effects of combined oral contraceptives on markers of endothelial function and lipids in healthy premenopausal women. Contraception. 2002;65(3):231-6. [pmid: 11929645].
Michaelsson K, Baron JA, Farahmand BY, et al. Influence of parity and lactation on hip fracture risk. Am J Epidemiol. 2001;153(12):1166-72. [pmid: 11415951].
Michaud DS, Gallo V, Schlehofer B, et al. Reproductive factors and exogenous hormone use in relation to risk of glioma and meningioma in a large European cohort study. Cancer Epidemiol Biomarkers Prev. 2010;19(10):2562-9. [pmid: 20802020].
Middeldorp S, Meijers JC, van den Ende AE, et al. Effects on coagulation of levonorgestrel- and desogestrel-containing low dose oral contraceptives: a cross-over study. Thromb Haemost. 2000;84(1):4-8. [pmid: 10928461].
Miller L, Hughes JP. Continuous combination oral contraceptive pills to eliminate withdrawal bleeding: a randomized trial. Obstet Gynecol. 2003;101(4):653-61. [pmid: 12681866].
Milsom I, Ekelund P, Molander U, et al. The influence of age, parity, oral contraception, hysterectomy and menopause on the prevalence of urinary incontinence in women. J Urol. 1993;149(6):1459-62. [pmid: 8501788].
Milsom I, Lete I, Bjertnaes A, et al. Effects on cycle control and bodyweight of the combined contraceptive ring, NuvaRing, versus an oral contraceptive containing 30 (mu)g ethinyl estradiol and 3 mg drospirenone. Human Reproduction. 2006;21(9):2304-2311. [pmid: 16763008].
Milsom I, Sundell G, Andersch B. The influence of different combined oral contraceptives on the prevalence and severity of dysmenorrhea. Contraception. 1990;42(5):497-506. [pmid: 2125545].
Mohamed AM, El-Sherbiny WS, Mostafa WA. Combined contraceptive ring versus combined oral contraceptive (30-mug ethinylestradiol and 3-mg drospirenone). Int J Gynaecol Obstet. 2011;114(2):145-8. [pmid: 21669426].
Mokhtar MM, Abdel-Fattah M. Major birth defects among infants with Down syndrome in Alexandria, Egypt (1995-2000) trends and risk factors. East Mediterr Health J. 2001;7(3):441-51. [pmid: 12690765].
Mol BW, Ankum WM, Bossuyt PM, et al. Contraception and the risk of ectopic pregnancy: a meta-analysis. Contraception. 1995;52(6):337-41. [pmid: 8749596].
Molano M, Van den Brule A, Plummer M, et al. Determinants of clearance of human papillomavirus infections in Colombian women with normal cytology: a population-based, 5-year follow-up study. Am J Epidemiol. 2003;158(5):486-94. [pmid: 12936904].
Moore C, Feichtinger W, Klinger G, et al. Clinical findings with the dienogest-containing oral contraceptive Valette(registered trademark). Drugs of Today. 1999;35(SUPPL. C):53-68.
Morabia A, Szklo M, Stewart W, et al. Consistent lack of association between breast cancer and oral contraceptives using either hospital or neighborhood controls. Prev Med. 1993;22(2):178-86. [pmid: 8483857].
Moreau C, Trussell J, Gilbert F, et al. Oral contraceptive tolerance: does the type of pill matter?. Obstet Gynecol. 2007;109(6):1277-85. [pmid: 17540798].
Morimoto LM, Newcomb PA, Hampton JM, et al. Cholecystectomy and endometrial cancer: A marker of long-term elevated estrogen exposure?. International Journal of Gynecological Cancer. 2006;16(3):1348-1353. [pmid: 16803528].
Morrison C, Prokorym P, Piquero C, et al. Oral contraceptive pills are associated with artifacts in ThinPrep Pap smears that mimic low-grade squamous intraepithelial lesions. Cancer. 2003;99(2):75-82. [pmid: 12704686].
Morrison CS, Richardson BA, Mmiro F, et al. Hormonal contraception and the risk of HIV acquisition. AIDS. 2007;21(1):85-95. [pmid: 17148972].
Morton LM, Wang SS, Richesson DA, et al. Reproductive factors, exogenous hormone use and risk of lymphoid neoplasms among women in the National Institutes of Health-AARP Diet and Health Study Cohort. Int J Cancer. 2009;124(11):2737-43. [pmid: 19253366].
Moscicki AB, Hills N, Shiboski S, et al. Risks for incident human papillomavirus infection and low-grade squamous intraepithelial lesion development in young females. JAMA. 2001;285(23):2995-3002. [pmid: 11410098].
Moscicki AB, Ma Y, Wibbelsman C, et al. Risks for cervical intraepithelial neoplasia 3 among adolescents and young women with abnormal cytology. Obstet Gynecol. 2008;112(6):1335-42. [pmid: 19037044].
Moskowitz MA, Jick SS, Burnside S, et al. The relationship of oral contraceptive use to rheumatoid arthritis. Epidemiology. 1990;1(2):153-6. [pmid: 2073503].
Mucci LA, Lagiou P, Hsieh CC, et al. A prospective study of pregravid oral contraceptive use in relation to fetal growth. BJOG. 2004;111(9):989-95. [pmid: 15327615].
Munoz N, Bosch FX, de Sanjose S, et al. Risk factors for cervical intraepithelial neoplasia grade III/carcinoma in situ in Spain and Colombia. Cancer Epidemiol Biomarkers Prev. 1993;2(5):423-31. [pmid: 8220086].
Munoz N, Kato I, Bosch FX, et al. Risk factors for HPV DNA detection in middle-aged women. Sex Transm Dis. 1996;23(6):504-10. [pmid: 8946637].
Myer L, Denny L, Wright TC, et al. Prospective study of hormonal contraception and women's risk of HIV infection in South Africa. Int J Epidemiol. 2007;36(1):166-74. [pmid: 17175547].
Nakajima ST, Archer DF, Ellman H. Efficacy and safety of a new 24-day oral contraceptive regimen of norethindrone acetate 1 mg/ethinyl estradiol 20 micro g (Loestrin 24 Fe). Contraception. 2007;75(1):16-22. [pmid: 17161118].
Nelson AL, Le MH, Musherraf Z, et al. Intermediate-term glucose tolerance in women with a history of gestational diabetes: natural history and potential associations with breastfeeding and contraception. Am J Obstet Gynecol. 2008;198(6):699 e1-7. discussion 699 e7-8. [pmid: 18439553].
Newcomb PA, Longnecker MP, Storer BE, et al. Recent oral contraceptive use and risk of breast cancer (United States). Cancer Causes Control. 1996;7(5):525-32. [pmid: 8877050].
Nielsen A, Kjaer SK, Munk C, et al. Persistence of high-risk human papillomavirus infection in a population-based cohort of Danish women. J Med Virol. 2010;82(4):616-23. [pmid: 20166190].
Norgaard M, Wogelius P, Pedersen L, et al. Maternal use of oral contraceptives during early pregnancy and risk of hypospadias in male offspring. Urology. 2009;74(3):583-7. [pmid: 19592074].
Olivieri O, Friso S, Manzato F, et al. Resistance to activated protein C in healthy women taking oral contraceptives. Br J Haematol. 1995;91(2):465-70. [pmid: 8547095].
Olsson H, Borg A, Ferno M, et al. Early oral contraceptive use and premenopausal breast cancer--a review of studies performed in southern Sweden. Cancer Detect Prev. 1991;15(4):265-71. [pmid: 1794133].
Palmer JR, Anderson D, Helmrich SP, et al. Risk factors for diethylstilbestrol-associated clear cell adenocarcinoma. Obstet Gynecol. 2000;95(6 Pt 1):814-20. [pmid: 10831973].
Palmer JR, Driscoll SG, Rosenberg L, et al. Oral contraceptive use and risk of gestational trophoblastic tumors. J Natl Cancer Inst. 1999;91(7):635-40. [pmid: 10203284].
Palmer JR, Rosenberg L, Rao RS, et al. Oral contraceptive use and breast cancer risk among African-American women. Cancer Causes Control. 1995;6(4):321-31. [pmid: 7548719].
Palmer JR, Rosenberg L, Strom BL, et al. Oral contraceptive use and risk of cutaneous malignant melanoma. Cancer Causes Control. 1992;3(6):547-54. [pmid: 1420858].
Palmer JR, Rosenberg L, Wise LA, et al. Onset of natural menopause in African American women. Am J Public Health. 2003;93(2):299-306. [pmid: 12554590].
Palmer JR. Oral contraceptive use and gestational choriocarcinoma. Cancer Detect Prev. 1991;15(1):45-8. [pmid: 2044074].
Parazzini F, Chatenoud L, La Vecchia C, et al. Time since last use of oral contraceptives and risk of invasive cervical cancer. Eur J Cancer. 1998;34(6):884-8. [pmid: 9797702].
Parazzini F, Cipriani S, Mangili G, et al. Oral contraceptives and risk of gestational trophoblastic disease. Contraception. 2002;65(6):425-7. [pmid: 12127642].
Parazzini F, Ferraroni M, Bocciolone L, et al. Contraceptive methods and risk of pelvic endometriosis. Contraception. 1994;49(1):47-55. [pmid: 8137625].
Parazzini F, Ferraroni M, Tozzi L, et al. Past contraceptive method use and risk of ectopic pregnancy. Contraception. 1995;52(2):93-8. [pmid: 8536453].
Parazzini F, Hildesheim A, Ferraroni M, et al. Relative and attributable risk for cervical cancer: a comparative study in the United States and Italy. Int J Epidemiol. 1990;19(3):539-45. [pmid: 2135870].
Parazzini F, la Vecchia C, Negri E, et al. Oral contraceptive use and invasive cervical cancer. Int J Epidemiol. 1990;19(2):259-63. [pmid: 2376433].
Parazzini F, Moroni S, Negri E, et al. Risk factors for seromucinous benign ovarian cysts in northern Italy. J Epidemiol Community Health. 1997;51(4):449-52. [pmid: 9328556].
Parazzini F, Negri E, La Vecchia C, et al. Oral contraceptive use and risk of uterine fibroids. Obstet Gynecol. 1992;79(3):430-3. [pmid: 1738528].
Pardthaisong T, Gray RH. In utero exposure to steroid contraceptives and outcome of pregnancy. Am J Epidemiol. 1991;134(8):795-803. [pmid: 1835282].
Pasquale LR, Kang JH. Female reproductive factors and primary open-angle glaucoma in the Nurses' Health Study. Eye (Lond). 2011;25(5):633-41. [pmid: 21336255].
Paul C, Skegg DC, Spears GF. Oral contraceptive use and risk of breast cancer in older women (New Zealand). Cancer Causes Control. 1995;6(6):485-91. [pmid: 8580295].
Paul C, Skegg DC, Spears GF. Oral contraceptives and risk of breast cancer. Int J Cancer. 1990;46(3):366-73. [pmid: 2394503].
Paulen ME, Zapata LB, Cansino C, et al. Contraceptive use among women with a history of bariatric surgery: a systematic review. Contraception. 2010;82(1):86-94. [pmid: 20682146].
Pearce HM, Layton D, Wilton LV, et al. Deep vein thrombosis and pulmonary embolism reported in the Prescription Event Monitoring Study of Yasmin. Br J Clin Pharmacol. 2005;60(1):98-102. [pmid: 15963100].
Peipins LA, Newman B, Sandler RS. Reproductive history, use of exogenous hormones, and risk of colorectal adenomas. Cancer Epidemiol Biomarkers Prev. 1997;6(9):671-5. [pmid: 9298573].
Pikwer M, Bergstrom U, Nilsson JA, et al. Breast feeding, but not use of oral contraceptives, is associated with a reduced risk of rheumatoid arthritis. Ann Rheum Dis. 2009;68(4):526-30. [pmid: 18477739].
Ploszaj S, Thornton MH, Stanczyk FZ, et al. Effect of oral contraceptives containing 20 and 35 microg ethinyl estradiol on urinary prostacyclin and thromboxane levels in smokers and non-smokers. Prim Care Update Ob Gyns. 1998;5(4):156. [pmid: 10838290].
Plu-Bureau G, Thalabard JC, Sitruk-Ware R, et al. Cyclical mastalgia as a marker of breast cancer susceptibility: results of a case-control study among French women. Br J Cancer. 1992;65(6):945-9. [pmid: 1616869].
Pokoradi AJ, Iversen L, Hannaford PC. Factors associated with age of onset and type of menopause in a cohort of UK women. Am J Obstet Gynecol. 2011;205(1):34 e1-13. [pmid: 21514918].
Potischman N, Brinton LA, Laiming VA, et al. A case-control study of serum folate levels and invasive cervical cancer. Cancer Res. 1991;51(18):4785-9. [pmid: 1893371].
Potter LS. How effective are contraceptives? The determination and measurement of pregnancy rates. Obstet Gynecol. 1. 1996;88(3 Suppl):3S-23S. [pmid: 8752224].
Preston-Martin S, Jin F, Duda MJ, et al. A case-control study of thyroid cancer in women under age 55 in Shanghai (People's Republic of China). Cancer Causes Control. 1993;4(5):431-40. [pmid: 8218875].
Preston-Martin S, Monroe K, Lee PJ, et al. Spinal meningiomas in women in Los Angeles County: investigation of an etiological hypothesis. Cancer Epidemiol Biomarkers Prev. 1995;4(4):333-9. [pmid: 7655327].
Price MA, Tennant CC, Smith RC, et al. Predictors of breast cancer in women recalled following screening. Aust N Z J Surg. 1999;69(9):639-46. [pmid: 10515336].
Primic-Zakelj M, Evstifeeva T, Ravnihar B, et al. Breast-cancer risk and oral contraceptive use in Slovenian women aged 25 to 54. Int J Cancer. 1995;62(4):414-20. [pmid: 7635567].
Prior J, Burdge D, Maan E, et al. Fragility fractures and bone mineral density in HIV positive women: a case-control population-based study. Osteoporos Int. 2007;18(10):1345-53. [pmid: 17665239].
Procter-Gray E, Cobb KL, Crawford SL, et al. Effect of oral contraceptives on weight and body composition in young female runners. Med Sci Sports Exerc. 2008;40(7):1205-12. [pmid: 18580398].
Purdie DM, Bain CJ, Siskind V, et al. Ovulation and risk of epithelial ovarian cancer. Int J Cancer. 2003;104(2):228-32. [pmid: 12569579].
Quehenberger P, Loner U, Kapiotis S, et al. Increased levels of activated factor VII and decreased plasma protein S activity and circulating thrombomodulin during use of oral contraceptives. Thromb Haemost. 1996;76(5):729-34. [pmid: 8950781].
Raman-Wilms L, Tseng AL, Wighardt S, et al. Fetal genital effects of first-trimester sex hormone exposure: a meta-analysis. Obstet Gynecol. 1995;85(1):141-9. [pmid: 7800312].
Ramsey-Goldman R, Dunn JE, Huang CF, et al. Frequency of fractures in women with systemic lupus erythematosus: comparison with United States population data. Arthritis Rheum. 1999;42(5):882-90. [pmid: 10323443].
Rautalahti M, Albanes D, Virtamo J, et al. Lifetime menstrual activity--indicator of breast cancer risk. Eur J Epidemiol. 1993;9(1):17-25. [pmid: 8472797].
Ray JG, Langman LJ, Vermeulen MJ, et al. Genetics University of Toronto Thrombophilia Study in women (GUTTSI): Genetic and other risk factors for venous thromboembolism in women. Current Controlled Trials in Cardiovascular Medicine. 2001;2(3):141-149. [pmid: 11806787].
Reed SD, Scholes D, LaCroix AZ, et al. Longitudinal changes in bone density in relation to oral contraceptive use. Contraception. 2003;68(3):177-82. [pmid: 14561537].
Reubinoff BE, Grubstein A, Meirow D, et al. Effects of low-dose estrogen oral contraceptives on weight, body composition, and fat distribution in young women. Fertil Steril. 1995;63(3):516-21. [pmid: 7851580].
Rice C, Killick S, Hickling D, et al. Ovarian activity and vaginal bleeding patterns with a desogestrel-only preparation at three different doses. Hum Reprod. 1996;11(4):737-40. [pmid: 8671319].
Risch HA, Howe GR. Menopausal hormone usage and breast cancer in Saskatchewan: a record-linkage cohort study. Am J Epidemiol. 1994;139(7):670-83. [pmid: 8166128].
Risch HA, Howe GR. Menopausal hormone use and colorectal cancer in Saskatchewan: a record linkage cohort study. Cancer Epidemiol Biomarkers Prev. 1995;4(1):21-8. [pmid: 7894320].
Risch HA, Bale AE, Beck PA, et al. PGR +331 A/G and increased risk of epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2006;15(9):1738-41. [pmid: 16985038].
Risch HA, Jain M, Marrett LD, et al. Dietary lactose intake, lactose intolerance, and the risk of epithelial ovarian cancer in southern Ontario (Canada). Cancer Causes Control. 1994;5(6):540-8. [pmid: 7827241].
Rohan TE, Miller AB. A cohort study of oral contraceptive use and risk of benign breast disease. Int J Cancer. 1999;82(2):191-6. [pmid: 10389751].
Rohan TE, L'Abbe KA, Cook MG. Oral contraceptives and risk of benign proliferative epithelial disorders of the breast. Int J Cancer. 1992;50(6):891-4. [pmid: 1555889].
Rookus MA, van Leeuwen FE. Oral contraceptives and risk of breast cancer in women aged 20-54 years. Netherlands Oral Contraceptives and Breast Cancer Study Group. Lancet. 1994;344(8926):844-51. [pmid: 7916400].
Rosenberg L, Palmer JR, Clarke EA, et al. A case-control study of the risk of breast cancer in relation to oral contraceptive use. Am J Epidemiol. 1992;136(12):1437-44. [pmid: 1288273].
Rosenberg L, Palmer JR, Lesko SM, et al. Oral contraceptive use and the risk of myocardial infarction. Am J Epidemiol. 1990;131(6):1009-16. [pmid: 2343853].
Rosenberg L, Palmer JR, Rao RS, et al. Case-control study of oral contraceptive use and risk of breast cancer. Am J Epidemiol. 1996;143(1):25-37. [pmid: 8533744].
Rosenberg MJ, Meyers A, Roy V. Efficacy, cycle control, and side effects of low- and lower-dose oral contraceptives: a randomized trial of 20 micrograms and 35 micrograms estrogen preparations. Contraception. 1999;60(6):321-9. [pmid: 10715366].
Rosenblatt KA, Thomas DB. Hormonal content of combined oral contraceptives in relation to the reduced risk of endometrial carcinoma. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Cancer. 1991;49(6):870-4. [pmid: 1959990].
Rosing J, Middeldorp S, Curvers J, et al. Low-dose oral contraceptives and acquired resistance to activated protein C: a randomised cross-over study. Lancet. 1999;354(9195):2036-40. [pmid: 10636369].
Rossing MA, Stanford JL, Weiss NS, et al. Oral contraceptive use and risk of breast cancer in middle-aged women. Am J Epidemiol. 1996;144(2):161-4. [pmid: 8678047].
Rubin GL, Peterson HB, Lee NC, et al. Estrogen replacement therapy and the risk of endometrial cancer: remaining controversies. Am J Obstet Gynecol. 1990;162(1):148-54. [pmid: 2301483].
Runnebaum IB, Wang-Gohrke S, Vesprini D, et al. Progesterone receptor variant increases ovarian cancer risk in BRCA1 and BRCA2 mutation carriers who were never exposed to oral contraceptives. Pharmacogenetics. 2001;11(7):635-8. [pmid: 11668223].
Sabatini R, Cagiano R. Comparison profiles of cycle control, side effects and sexual satisfaction of three hormonal contraceptives. Contraception. 2006;74(3):220-3. [pmid: 16904415].
Sackoff J, Kline J, Susser M. Previous use of oral contraceptives and spontaneous abortion. Epidemiology. 1994;5(4):422-8. [pmid: 7918812].
Sakoda LC, Horn-Ross PL. Reproductive and menstrual history and papillary thyroid cancer risk: the San Francisco Bay Area thyroid cancer study. Cancer Epidemiol Biomarkers Prev. 2002;11(1):51-7. [pmid: 11815401].
Sampalis JS, Medsger TA Jr, Fries JF, et al. Risk factors for adult Still's disease. J Rheumatol. 1996;23(12):2049-54. [pmid: 8970040].
Sanchez-Guerrero J, Uribe AG, Jimenez-Santana L, et al. A trial of contraceptive methods in women with systemic lupus erythematosus. N Engl J Med. 2005;353(24):2539-49. [pmid: 16354890].
Santamaria A, Mateo J, Oliver A, et al. Risk of thrombosis associated with oral contraceptives of women from 97 families with inherited thrombophilia: high risk of thrombosis in carriers of the G20210A mutation of the prothrombin gene. Haematologica. 2001;86(9):965-71. [pmid: 11532625].
Sauerbrei W, Blettner M, Schmoor C, et al. The effect of oral contraceptive use on the prognosis of node positive breast cancer patients. German Breast Cancer Study Group Eur J Cancer. 1998;34(9):1348-51. [pmid: 9849415].
Sayed GH, Zakherah MS, El-Nashar SA, et al. A randomized clinical trial of a levonorgestrel-releasing intrauterine system and a low-dose combined oral contraceptive for fibroid-related menorrhagia. International Journal of Gynecology and Obstetrics. 2011;112(2):126-130. [pmid: 21092958].
Schiffman MH, Bauer HM, Hoover RN, et al. Epidemiologic evidence showing that human papillomavirus infection causes most cervical intraepithelial neoplasia. J Natl Cancer Inst. 1993;85(12):958-64. [pmid: 8388478].
Schildkraut JM, Hulka BS, Wilkinson WE. Oral contraceptives and breast cancer: a case-control study with hospital and community controls. Obstet Gynecol. 1990;76(3 Pt 1):395-402. [pmid: 2381616].
Schlesselman JJ, Stadel BV, Korper M, et al. Breast cancer detection in relation to oral contraception. J Clin Epidemiol. 1992;45(5):449-59. [pmid: 1588351].
Schmeink CE, Massuger LF, Lenselink CH, et al. Effect of the menstrual cycle and hormonal contraceptives on human papillomavirus detection in young, unscreened women. Obstet Gynecol. 2010;116(1):67-75. [pmid: 20567170].
Schonborn I, Nischan P, Ebeling K. Oral contraceptive use and the prognosis of breast cancer. Breast Cancer Res Treat. 1994;30(3):283-92. [pmid: 7981446].
Schonfeld SJ, Ron E, Kitahara CM, et al. Hormonal and reproductive factors and risk of postmenopausal thyroid cancer in the NIH-AARP Diet and Health Study. Cancer Epidemiol. 2011;35(6):e85-90. [pmid: 21852218].
Schwartz SM, Weiss NS, Daling JR, et al. Exogenous sex hormone use, correlates of endogenous hormone levels, and the incidence of histologic types of sarcoma of the uterus. Cancer. 1996;77(4):717-24. [pmid: 8616764].
Scoditti U, Buccino GP, Pini M, et al. Risk of acute cerebrovascular events related to low oestrogen oral contraceptive treatment. Ital J Neurol Sci. 1998;19(1):15-9. [pmid: 10935854].
Seaman HE, de Vries CS, Farmer RD. Differences in the use of combined oral contraceptives amongst women with and without acne. Hum Reprod. 2003;18(3):515-21. [pmid: 12615817].
Seaman HE, de Vries CS, Farmer RD. The risk of liver disorders in women prescribed cyproterone acetate in combination with ethinyloestradiol (Dianette): a nested case-control study using the GPRD. Pharmacoepidemiol Drug Saf. 2003;12(7):541-50. [pmid: 14558177].
Segebladh B, Borgstrom A, Odlind V, et al. Prevalence of psychiatric disorders and premenstrual dysphoric symptoms in patients with experience of adverse mood during treatment with combined oral contraceptives. Contraception. 2009;79(1):50-5. [pmid: 19041441].
Sellors JW, Karwalajtys TL, Kaczorowski J, et al. Incidence, clearance and predictors of human papillomavirus infection in women. CMAJ. 2003;168(4):421-5. [pmid: 12591782].
Sellors JW, Mahony JB, Kaczorowski J, et al. Prevalence and predictors of human papillomavirus infection in women in Ontario, Canada. Survey of HPV in Ontario Women (SHOW) Group. CMAJ. 2000;163(5):503-8. [pmid: 11006760].
Settnes A, Lange AP, Jorgensen T. Gynaecological correlates of hysterectomy in Danish women. Int J Epidemiol. 1997;26(2):364-70. [pmid: 9169172].
Shaarawy M, Nafea S, Abdel-Aziz O, et al. The cardiovascular safety of triphasic contraceptive steroids. Contraception. 1997;56(3):157-63. [pmid: 9347206].
Shabaan MM, Zakherah MS, El-Nashar SA, et al. Levonorgestrel-releasing intrauterine system compared to low dose combined oral contraceptive pills for idiopathic menorrhagia: A randomized clinical trial. Contraception. 2011;83(1):48-54. [pmid: 21134503].
Shaw AK, Infante-Rivard C, Morrison HI. Use of medication during pregnancy and risk of childhood leukemia (Canada). Cancer Causes Control. 2004;15(9):931-7. [pmid: 15577295].
Shin S, Schneider HB, Cole FJ Jr, et al. Follow-up recommendations for benign breast biopsies. Breast J. 2006;12(5):413-7. [pmid: 16958957].
Shu XO, Brinton LA, Zheng W, et al. A population-based case-control study of endometrial cancer in Shanghai, China. Int J Cancer. 1991;49(1):38-43. [pmid: 1874568].
Siegerink B, Govers-Riemslag JW, Rosendaal FR, et al. Intrinsic coagulation activation and the risk of arterial thrombosis in young women: results from the Risk of Arterial Thrombosis in relation to Oral contraceptives (RATIO) case-control study. Circulation. 2010;122(18):1854-61. [pmid: 20956210].
Sillero-Arenas M, Rodriguez-Contreras R, Delgado-Rodriguez M, et al. Patterns of research. Oral contraceptives and cervical cancer. Acta Obstet Gynecol Scand. 1991;70(2):143-8. [pmid: 1831954].
Simard A, Vobecky J, Vobecky JS, et al. Case-control study of fibrocystic breast disease. Rev Epidemiol Sante Publique. 1993;41(1):84-9. [pmid: 8465069].
Skegg DC, Paul C, Spears GF, et al. Progestogen-only oral contraceptives and risk of breast cancer in New Zealand. Cancer Causes Control. 1996;7(5):513-9. [pmid: 8877048].
Skinner HG, Michaud DS, Colditz GA, et al. Parity, reproductive factors, and the risk of pancreatic cancer in women. Cancer Epidemiol Biomarkers Prev. 2003;12(5):433-8. [pmid: 12750238].
Slattery ML, Potter JD, Curtin K, et al. Estrogens reduce and withdrawal of estrogens increase risk of microsatellite instability-positive colon cancer. Cancer Res. 2001;61(1):126-30. [pmid: 11196149].
Smith EM, Johnson SR, Cripe T, et al. Perinatal transmission and maternal risks of human papillomavirus infection. Cancer Detect Prev. 1995;19(2):196-205. [pmid: 7750107].
Smith EM, Johnson SR, Jiang D, et al. The association between pregnancy and human papilloma virus prevalence. Cancer Detect Prev. 1991;15(5):397-402. [pmid: 1661203].
Smith MA, Fine JA, Barnhill RL, et al. Hormonal and reproductive influences and risk of melanoma in women. Int J Epidemiol. 1998;27(5):751-7. [pmid: 9839729].
Smulders B, van Oirschot SM, Farquhar C, et al. Oral contraceptive pill, progestogen or estrogen pre-treatment for ovarian stimulation protocols for women undergoing assisted reproductive techniques. Cochrane Database Syst Rev. 2010;(1):CD006109. [pmid: 20091585].
Snell-Bergeon JK, Dabelea D, Ogden LG, et al. Reproductive history and hormonal birth control use are associated with coronary calcium progression in women with type 1 diabetes mellitus. J Clin Endocrinol Metab. 2008;93(6):2142-8. [pmid: 18349069].
Song SH, Lee JK, Lee NW, et al. Interferon-gamma (IFN-gamma): a possible prognostic marker for clearance of high-risk human papillomavirus (HPV). Gynecol Oncol. 2008;108(3):543-8. [pmid: 18164379].
Spannagl M, Dick A, Assmann A, et al. Resistance to activated protein C in women using oral contraceptives. Semin Thromb Hemost. 1998;24(5):423-30. [pmid: 9834008].
Spector TD, Roman E, Silman AJ. The pill, parity, and rheumatoid arthritis. Arthritis Rheum. 1990;33(6):782-9. [pmid: 2363734].
Spona J, Elstein M, Feichtinger W, et al. Shorter pill-free interval in combined oral contraceptives decreases follicular development. Contraception. 1996;54(2):71-7. [pmid: 8842582].
Stanford JL, Brinton LA, Berman ML, et al. Oral contraceptives and endometrial cancer: do other risk factors modify the association?. Int J Cancer. 1993;54(2):243-8. [pmid: 8486426].
Steiner MJ, Kwok C, Dominik R, et al. Pregnancy risk among oral contraceptive pill, injectable contraceptive, and condom users in Uganda, zimbabwe, and Thailand. Obstet Gynecol. 2007;110(5):1003-9. [pmid: 17978111].
Stevens-Simon C, Kelly L, Kulick R. A village would be nice but…it takes a long-acting contraceptive to prevent repeat adolescent pregnancies. Am J Prev Med. 2001;21(1):60-5. [pmid: 11418259].
Stevens-Simon C, Kelly L, Singer D. Preventing repeat adolescent pregnancies with early adoption of the contraceptive implant. Fam Plann Perspect. 1999;31(2):88-93. [pmid: 10224547].
Stoll C, Alembik Y, Dott B, et al. An epidemiologic study of environmental and genetic factors in congenital hydrocephalus. Eur J Epidemiol. 1992;8(6):797-803. [pmid: 1294384].
Strayer SM, Couchenour RL. Combined oral contraceptives versus levonorgestrel for emergency contraception. J Fam Pract. 1998;47(6):417. [pmid: 9866661].
Strieder TG, Prummel MF, Tijssen JG, et al. Risk factors for and prevalence of thyroid disorders in a cross-sectional study among healthy female relatives of patients with autoimmune thyroid disease. Clin Endocrinol (Oxf). 2003;59(3):396-401. [pmid: 12919165].
Stringer EM, Giganti M, Carter RJ, et al. Hormonal contraception and HIV disease progression: a multicountry cohort analysis of the MTCT-Plus Initiative. AIDS. Suppl 1. 2009;23:S69-77. [pmid: 20081390].
Stringer EM, Kaseba C, Levy J, et al. A randomized trial of the intrauterine contraceptive device vs hormonal contraception in women who are infected with the human immunodeficiency virus. Am J Obstet Gynecol. 2007;197(2):144 e1-8. [pmid: 17689627].
Stringer EM, Levy J, Sinkala M, et al. HIV disease progression by hormonal contraceptive method: secondary analysis of a randomized trial. AIDS. 2009;23(11):1377-82. [pmid: 19448528].
Suhonen S, Haukkamaa M, Jakobsson T, et al. Clinical performance of a levonorgestrel-releasing intrauterine system and oral contraceptives in young nulliparous women: a comparative study. Contraception. 2004;69(5):407-12. [pmid: 15105064].
Syrjanen K, Shabalova I, Sarian L, et al. Covariates of high-risk human papillomavirus (HPV) infections are distinct for incident CIN1, CIN2 and CIN3 as disclosed by competing-risks regression models. Eur J Gynaecol Oncol. 2012;33(1):5-14. [pmid: 22439398].
Talamini R, Franceschi S, Dal Maso L, et al. The influence of reproductive and hormonal factors on the risk of colon and rectal cancer in women. Eur J Cancer. 1998;34(7):1070-6. [pmid: 9849456].
Taneepanichskul S, Jaisamrarn U, Phupong V. Efficacy of Yasmin in premenstrual symptoms. Arch Gynecol Obstet. 2007;275(6):433-8. [pmid: 17111156].
Tang OS, Gao PP, Cheng L, et al. A randomized double-blind placebo-controlled study to assess the effect of oral contraceptive pills on the outcome of medical abortion with mifepristone and misoprostol. Hum Reprod. 1999;14(3):722-5. [pmid: 10221703].
Tang OS, Xu J, Cheng L, et al. The effect of contraceptive pills on the measured blood loss in medical termination of pregnancy by mifepristone and misoprostol: a randomized placebo controlled trial. Hum Reprod. 2002;17(1):99-102. [pmid: 11756369].
Tanis BC, Bloemenkamp DG, van den Bosch MA, et al. Prothrombotic coagulation defects and cardiovascular risk factors in young women with acute myocardial infarction. Br J Haematol. 2003;122(3):471-8. [pmid: 12877676].
Tanislav C, Puille M, Pabst W, et al. High Frequency of Silent Pulmonary Embolism in Patients With Cryptogenic Stroke and Patent Foramen Ovale. Stroke. 2011;42(3):822-4. [pmid: 21257827].
Tans G, Curvers J, Middeldorp S, et al. A randomized cross-over study on the effects of levonorgestrel- and desogestrel-containing oral contraceptives on the anticoagulant pathways. Thromb Haemost. 2000;84(1):15-21. [pmid: 10928463].
Tans G, van Hylckama Vlieg A, Thomassen MC, et al. Activated protein C resistance determined with a thrombin generation-based test predicts for venous thrombosis in men and women. Br J Haematol. 2003;122(3):465-70. [pmid: 12877675].
Tantbirojn P, Taneepanichskul S. Clinical comparative study of oral contraceptives containing 30 microg ethinylestradiol/150 microg levonorgestrel, and 35 microg ethinylestradiol/250 microg norgestimate in Thai women. Contraception. 2002;66(6):401-5. [pmid: 12499031].
Tavani A, Gallus S, La Vecchia C, et al. Risk factors for breast cancer in women under 40 years. Eur J Cancer. 1999;35(9):1361-7. [pmid: 10658528].
Tavani A, Negri E, Franceschi S, et al. Oral contraceptives and breast cancer in northern Italy. Final report from a case-control study. Br J Cancer. 1993;68(3):568-71. [pmid: 8353047].
Tavani A, Negri E, Parazzini F, et al. Female hormone utilisation and risk of hepatocellular carcinoma. Br J Cancer. 1993;67(3):635-7. [pmid: 8382515].
Teichert M, Visser LE, Dufour M, et al. Isotretinoin use and compliance with the Dutch Pregnancy Prevention Programme: a retrospective cohort study in females of reproductive age using pharmacy dispensing data. Drug Saf. 2010;33(4):315-26. [pmid: 20297863].
Teichmann A, Apter D, Emerich J, et al. Continuous, daily levonorgestrel/ethinyl estradiol vs. 21-day, cyclic levonorgestrel/ethinyl estradiol: efficacy, safety and bleeding in a randomized, open-label trial. Contraception. 2009;80(6):504-11. [pmid: 19913143].
Teichmann AT, Brill K, Albring M, et al. The influence of the dose of ethinylestradiol in oral contraceptives on follicle growth. Gynecol Endocrinol. 1995;9(4):299-305. [pmid: 8629458].
Templeman CL, Cook V, Goldsmith LJ, et al. Postpartum contraceptive use among adolescent mothers. Obstet Gynecol. 2000;95(5):770-6. [pmid: 10775745].
Terry MB, Gammon MD, Schoenberg JB, et al. Oral contraceptive use and cyclin D1 overexpression in breast cancer among young women. Cancer Epidemiol Biomarkers Prev. 2002;11(10 Pt 1):1100-3. [pmid: 12376514].
Testa G, Chiaffarino F, Vegetti W, et al. Case-control study on risk factors for premature ovarian failure. Gynecol Obstet Invest. 2001;51(1):40-3. [pmid: 11150874].
Tewari M, Pradhan S, Singh U, et al. Estrogen and progesterone receptor status in breast cancer: effect of oral contraceptive pills and hormone replacement therapy. Breast. 2007;16(5):540-5. [pmid: 17587581].
Thadhani R, Stampfer MJ, Chasan-Taber L, et al. A prospective study of pregravid oral contraceptive use and risk of hypertensive disorders of pregnancy. Contraception. 1999;60(3):145-50. [pmid: 10640157].
Thijs C, Knipschild P. Oral contraceptives and the risk of gallbladder disease: a meta-analysis. Am J Public Health. 1993;83(8):1113-20. [pmid: 8342719].
Thomas DB, Noonan EA. Breast cancer and specific types of combined oral contraceptives. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Br J Cancer. 1992;65(1):108-13. [pmid: 1733433].
Thomas DB, Noonan EA. Risk of breast cancer in relation to use of combined oral contraceptives near the age of menopause. WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Cancer Causes Control. 1991;2(6):389-94. [pmid: 1764563].
Thomas DB, Ray RM. Oral contraceptives and invasive adenocarcinomas and adenosquamous carcinomas of the uterine cervix. The World Health Organization Collaborative Study of Neoplasia and Steroid Contraceptives. Am J Epidemiol. 1996;144(3):281-9. [pmid: 8686697].
Thomson SW, Heimburger DC, Cornwell PE, et al. Effect of total plasma homocysteine on cervical dysplasia risk. Nutr Cancer. 2000;37(2):128-33. [pmid: 11142083].
Thong FS, McLean C, Graham TE. Plasma leptin in female athletes: relationship with body fat, reproductive, nutritional, and endocrine factors. J Appl Physiol. 2000;88(6):2037-44. [pmid: 10846016].
Thorogood M, Hannaford PC. The influence of oral contraceptives on the risk of multiple sclerosis. Br J Obstet Gynaecol. 1998;105(12):1296-9. [pmid: 9883921].
Thorogood M, Mann J, Murphy M, et al. Is oral contraceptive use still associated with an increased risk of fatal myocardial infarction? Report of a case-control study. Br J Obstet Gynaecol. 1991;98(12):1245-53. [pmid: 1777457].
Thorogood M, Mann J, Murphy M, et al. Is oral contraceptive use still associated with an increased risk of fatal myocardial infarction? Report of a case-control study. Obstetrical and Gynecological Survey. 1992;47(7):512-514.
Thorogood M, Mann J, Murphy M, et al. Risk factors for fatal venous thromboembolism in young women: a case-control study. Int J Epidemiol. 1992;21(1):48-52. [pmid: 1544757].
Thurman AR, Hammond N, Brown HE, et al. Preventing repeat teen pregnancy: postpartum depot medroxyprogesterone acetate, oral contraceptive pills, or the patch?. J Pediatr Adolesc Gynecol. 2007;20(2):61-5. [pmid: 17418388].
Tilakaratne A, Soory M, Ranasinghe AW, et al. Effects of hormonal contraceptives on the periodontium, in a population of rural Sri-Lankan women. J Clin Periodontol. 2000;27(10):753-7. [pmid: 11034123].
Titus-Ernstoff L, Longnecker MP, Newcomb PA, et al. Menstrual factors in relation to breast cancer risk. Cancer Epidemiol Biomarkers Prev. 1998;7(9):783-9. [pmid: 9752986].
Tok EC, Ertunc D, Tataroglu C, et al. Clinicopathologic study of the putative precursor lesions of epithelial ovarian cancer in low-risk women. Int J Gynecol Cancer. 2006;16(2):501-6. [pmid: 16681718].
Tomasson H, Tomasson K. Oral contraceptives and risk of breast cancer. A historical prospective case-control study. Acta Obstet Gynecol Scand. 1996;75(2):157-61. [pmid: 8604603].
Torfs CP, Katz EA, Bateson TF, et al. Maternal medications and environmental exposures as risk factors for gastroschisis. Teratology. 1996;54(2):84-92. [pmid: 8948544].
Traina A, Cusimano R, Liquori M, et al. Oral contraceptive use and breast cancer risk in areas with different incidence. A case-control study among young women. Ann N Y Acad Sci. 1996;784:564-9. [pmid: 8651617].
Truitt Sarah T, Fraser Anna B, Gallo Maria F, et al. Combined hormonal versus nonhormonal versus progestin-only contraception in lactation. Cochrane Database Syst Rev. 2003;(2):CD003988. [pmid: 12804497].
Truitt ST, Fraser AB, Grimes DA, et al. Hormonal contraception during lactation. systematic review of randomized controlled trials. Contraception. 2003;68(4):233-8. [pmid: 14572885].
Truong T, Orsi L, Dubourdieu D, et al. Role of goiter and of menstrual and reproductive factors in thyroid cancer: a population-based case-control study in New Caledonia (South Pacific), a very high incidence area. Am J Epidemiol. 2005;161(11):1056-65. [pmid: 15901626].
Tryggvadottir L, Tulinius H, Gudmundsdottir GB. Oral contraceptive use at a young age and the risk of breast cancer: an Icelandic, population-based cohort study of the effect of birth year. Br J Cancer. 1997;75(1):139-43. [pmid: 9000612].
Tworoger SS, Gertig DM, Gates MA, et al. Caffeine, alcohol, smoking, and the risk of incident epithelial ovarian cancer. Cancer. 2008;112(5):1169-77. [pmid: 18213613].
Ursin G, Aragaki CC, Paganini-Hill A, et al. Oral contraceptives and premenopausal bilateral breast cancer: a case-control study. Epidemiology. 1992;3(5):414-9. [pmid: 1391133].
Ursin G, Pike MC, Preston-Martin S, et al. Sexual, reproductive, and other risk factors for adenocarcinoma of the cervix: results from a population-based case-control study (California, United States). Cancer Causes Control. 1996;7(3):391-401. [pmid: 8734834].
Ursin G, Ross RK, Sullivan-Halley J, et al. Use of oral contraceptives and risk of breast cancer in young women. Breast Cancer Res Treat. 1998;50(2):175-84. [pmid: 9822222].
Ursin G, Wu AH, Hoover RN, et al. Breast cancer and oral contraceptive use in Asian-American women. Am J Epidemiol. 1999;150(6):561-7. [pmid: 10489994].
Vahedi M, Abdollahzadeh S, Vaziri PB, et al. Oral contraceptive use and salivary C-erbB-2, CEA and CA15-3 in healthy women: a case-control study. Med Oral Patol Oral Cir Bucal. 2011;16(1):e29-32. [pmid: 20711149].
Valikhani M, Kavusi S, Chams-Davatchi C, et al. Pemphigus and associated environmental factors: a case-control study. Clin Exp Dermatol. 2007;32(3):256-60. [pmid: 17355277].
Vamre TB, Stalsberg H, Thomas DB. Extra-tumoral breast tissue in breast cancer patients: variations with steroid contraceptive use. Int J Cancer. 2006;118(11):2827-31. [pmid: 16380999].
van Beek EJ, Farmer KC, Millar DM, et al. Gallstone disease in women younger than 30 years. Neth J Surg. 1991;43(3):60-2. [pmid: 1922881].
Van Den Bosch MA, Kemmeren JM, Tanis BC, et al. The RATIO study: oral contraceptives and the risk of peripheral arterial disease in young women. J Thromb Haemost. 2003;1(3):439-44. [pmid: 12871447].
van der Kooy K, Rookus MA, Peterse HL, et al. p53 protein overexpression in relation to risk factors for breast cancer. Am J Epidemiol. 1996;144(10):924-33. [pmid: 8916503].
van Noord PA, Dubas JS, Dorland M, et al. Age at natural menopause in a population-based screening cohort: the role of menarche, fecundity, and lifestyle factors. Fertil Steril. 1997;68(1):95-102. [pmid: 9207591].
van Rooijen M, Hansson LO, Frostegard J, et al. Treatment with combined oral contraceptives induces a rise in serum C-reactive protein in the absence of a general inflammatory response. J Thromb Haemost. 2006;4(1):77-82. [pmid: 16409455].
van Rooijen M, Silveira A, Hamsten A, et al. Sex hormone--binding globulin--a surrogate marker for the prothrombotic effects of combined oral contraceptives. Am J Obstet Gynecol. 2004;190(2):332-7. [pmid: 14981370].
van Tilburg NH, Rosendaal FR, Bertina RM. Thrombin activatable fibrinolysis inhibitor and the risk for deep vein thrombosis. Blood. 2000;95(9):2855-9. [pmid: 10779431].
Van Vliet Huib AAM, Grimes David A, Lopez Laureen M, et al. Triphasic versus monophasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2011;(11):CD003553. [pmid: 22071807].
Van Vliet Huib AAM, Raps M, Lopez Laureen M, et al. Quadriphasic versus monophasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2011;(11):CD009038. [pmid: 22071862].
Vandenbroucke JP, Koster T, Briet E, et al. Increased risk of venous thrombosis in oral-contraceptive users who are carriers of factor V Leiden mutation. Lancet. 1994;344(8935):1453-7. [pmid: 7968118].
Vandenvelde C, Van Beers D. Risk factors inducing the persistence of high-risk genital papillomaviruses in the normal cervix. J Med Virol. 1992;38(3):226-32. [pmid: 1337551].
Vessey M, Yeates D. Oral contraceptives and benign breast disease: an update of findings in a large cohort study. Contraception. 2007;76(6):418-24. [pmid: 18061698].
Vessey M, Mant J, Painter R. Oral contraception and other factors in relation to hospital referral for fracture. Findings in a large cohort study. Contraception. 1998;57(4):231-5. [pmid: 9649913].
Vessey M, Painter R, Mant J. Oral contraception and other factors in relation to back disorders in women: findings in a large cohort study. Contraception. 1999;60(6):331-5. [pmid: 10715367].
Vessey M, Painter R, Mant J. Oral contraception and other factors in relation to hospital referral for menstrual problems without known underlying cause: Findings in a large cohort study. British Journal of Family Planning. 1997;22(4):166-169.
Vessey M. Oral contraceptive failures and body weight: findings in a large cohort study. J Fam Plann Reprod Health Care. 2001;27(2):90-1. [pmid: 12457519].
Vessey MP, Hannaford P, Mant J, et al. Oral contraception and eye disease: findings in two large cohort studies. Br J Ophthalmol. 1998;82(5):538-42. [pmid: 9722322].
Vessey MP, Painter R, Powell J. Skin disorders in relation to oral contraception and other factors, including age, social class, smoking and body mass index. Findings in a large cohort study. Br J Dermatol. 2000;143(4):815-20. [pmid: 11069462].
Vessey MP, Villard-Mackintosh L, Painter R. Epidemiology of endometriosis in women attending family planning clinics. BMJ. 1993;306(6871):182-4. [pmid: 8338516].
Vessey MP, Villard-Mackintosh L, Painter R. Oral contraceptives and pregnancy in relation to peptic ulcer. Contraception. 1992;46(4):349-57. [pmid: 1486773].
Vestergaard P, Rejnmark L, Mosekilde L. Oral contraceptive use and risk of fractures. Contraception. 2006;73(6):571-6. [pmid: 16730486].
Villard-Mackintosh L, Vessey MP. Oral contraceptives and reproductive factors in multiple sclerosis incidence. Contraception. 1993;47(2):161-8. [pmid: 8449016].
Vitrat-Hincky V, Gompel A, Dumestre-Perard C, et al. Type III hereditary angio-oedema: clinical and biological features in a French cohort. Allergy. 2010;65(10):1331-6. [pmid: 20384613].
Voigt LF, Deng Q, Weiss NS. Recency, duration, and progestin content of oral contraceptives in relation to the incidence of endometrial cancer (Washington, USA). Cancer Causes Control. 1994;5(3):227-33. [pmid: 8061170].
Wahedna I, Cooper S, Williams J, et al. Relation of pulmonary lymphangio-leiomyomatosis to use of the oral contraceptive pill and fertility in the UK: a national case control study. Thorax. 1994;49(9):910-4. [pmid: 7940433].
Waller DK, Gallaway MS, Taylor LG, et al. Use of oral contraceptives in pregnancy and major structural birth defects in offspring. Epidemiology. 2010;21(2):232-9. [pmid: 20087193].
Wang CC, Reilly M, Kreiss JK. Risk of HIV infection in oral contraceptive pill users: a meta-analysis. J Acquir Immune Defic Syndr. 1999;21(1):51-8. [pmid: 10235514].
Wang QS, Ross RK, Yu MC, et al. A case-control study of breast cancer in Tianjin. China Cancer Epidemiol Biomarkers Prev. 1992;1(6):435-9. [pmid: 1302554].
Warren MP, Miller KK, Olson WH, et al. Effects of an oral contraceptive (norgestimate/ethinyl estradiol) on bone mineral density in women with hypothalamic amenorrhea and osteopenia: an open-label extension of a double-blind, placebo-controlled study. Contraception. 2005;72(3):206-11. [pmid: 16102557].
Weiderpass E, Adami HO, Baron JA, et al. Use of oral contraceptives and endometrial cancer risk (Sweden). Cancer Causes Control. 1999;10(4):277-84. [pmid: 10482486].
Weinstein AL, Mahoney MC, Nasca PC, et al. Breast cancer risk and oral contraceptive use: results from a large case-control study. Epidemiology. 1991;2(5):353-8. [pmid: 1742384].
Wen SW, Yang T, Krewski D, et al. Patterns of pregnancy exposure to prescription FDA C, D and X drugs in a Canadian population. J Perinatol. 2008;28(5):324-9. [pmid: 18288118].
Wernli KJ, Newcomb PA, Hampton JM, et al. Inverse association of NSAID use and ovarian cancer in relation to oral contraceptive use and parity. Br J Cancer. 2008;98(11):1781-3. [pmid: 18506182].
Westerdahl J, Olsson H, Masback A, et al. Risk of malignant melanoma in relation to drug intake, alcohol, smoking and hormonal factors. Br J Cancer. 1996;73(9):1126-31. [pmid: 8624275].
Westhoff C, Britton JA, Gammon MD, et al. Oral contraceptive and benign ovarian tumors. Am J Epidemiol. 2000;152(3):242-6. [pmid: 10933271].
Westhoff C, Heartwell S, Edwards S, et al. Initiation of oral contraceptives using a quick start compared with a conventional start: a randomized controlled trial. Obstet Gynecol. 2007;109(6):1270-6. [pmid: 17540797].
White E, Malone KE, Weiss NS, et al. Breast cancer among young U.S. women in relation to oral contraceptive use. J Natl Cancer Inst. 1994;86(7):505-14. [pmid: 8133534].
Whittemore AS, Harris R, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. IV. The pathogenesis of epithelial ovarian cancer. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1212-20. [pmid: 1476143].
Wideroff L, Schiffman MH, Hoover R, et al. Epidemiologic determinants of seroreactivity to human papillomavirus (HPV) type 16 virus-like particles in cervical HPV-16 DNA-positive and-negative women. J Infect Dis. 1996;174(5):937-43. [pmid: 8896493].
Wiegratz I, Mittmann K, Dietrich H, et al. Fertility after discontinuation of treatment with an oral contraceptive containing 30 microg of ethinyl estradiol and 2 mg of dienogest. Fertil Steril. 2006;85(6):1812-9. [pmid: 16759929].
Wieland S, Dickersin K. Selective exposure reporting and Medline indexing limited the search sensitivity for observational studies of the adverse effects of oral contraceptives. J Clin Epidemiol. 2005;58(6):560-7. [pmid: 15878469].
Wielders S, Mukherjee M, Michiels J, et al. The routine determination of the endogenous thrombin potential, first results in different forms of hyper- and hypocoagulability. Thromb Haemost. 1997;77(4):629-36. [pmid: 9134633].
Wigertz A, Lonn S, Mathiesen T, et al. Risk of brain tumors associated with exposure to exogenous female sex hormones. Am J Epidemiol. 2006;164(7):629-36. [pmid: 16835295].
Wilcox AJ, Dunson DB, Weinberg CR, et al. Likelihood of conception with a single act of intercourse: providing benchmark rates for assessment of post-coital contraceptives. Contraception. 2001;63(4):211-5. [pmid: 11376648].
Wingo PA, Lee NC, Ory HW, et al. Age-specific differences in the relationship between oral contraceptive use and breast cancer. Cancer. 1993;71(4 Suppl):1506-17. [pmid: 8431887].
Wingo PA, Lee NC, Ory HW, et al. Age-specific differences in the relationship between oral contraceptive use and breast cancer. Obstet Gynecol. 1991;78(2):161-70. [pmid: 2067757].
Winkler UH, Ferguson H, Mulders JA. Cycle control, quality of life and acne with two low-dose oral contraceptives containing 20 microg ethinylestradiol. Contraception. 2004;69(6):469-76. [pmid: 15157791].
Winkler UH, Holscher T, Schulte H, et al. Ethinylestradiol 20 versus 30 micrograms combined with 150 micrograms desogestrel: a large comparative study of the effects of two low-dose oral contraceptives on the hemostatic system. Gynecol Endocrinol. 1996;10(4):265-71. [pmid: 8908527].
Winner B, Peipert JF, Zhao Q, et al. Effectiveness of long-acting reversible contraception. N Engl J Med. 2012;366(21):1998-2007. [pmid: 22621627].
Wise LA, Palmer JR, Harlow BL, et al. Reproductive factors, hormonal contraception, and risk of uterine leiomyomata in African-American women: a prospective study. Am J Epidemiol. 2004;159(2):113-23. [pmid: 14718211].
Wogelius P, Horvath-Puho E, Pedersen L, et al. Maternal use of oral contraceptives and risk of hypospadias - a population-based case-control study. Eur J Epidemiol. 2006;21(10):777-81. [pmid: 17077991].
Woodson GC. Risk factors for osteoporosis in postmenopausal African-American women. Curr Med Res Opin. 2004;20(10):1681-7. [pmid: 15462702].
Wreje U, Isacsson D, Aberg H. Oral contraceptives and back pain in women in a Swedish community. Int J Epidemiol. 1997;26(1):71-4. [pmid: 9126505].
Xiang AH, Kawakubo M, Buchanan TA, et al. A longitudinal study of lipids and blood pressure in relation to method of contraception in Latino women with prior gestational diabetes mellitus. Diabetes Care. 2007;30(8):1952-8. [pmid: 17519432].
Xiang AH, Kawakubo M, Kjos SL, et al. Long-acting injectable progestin contraception and risk of type 2 diabetes in Latino women with prior gestational diabetes mellitus. Diabetes Care. 2006;29(3):613-7. [pmid: 16505515].
Yang Q, Sherman SL, Hassold TJ, et al. Risk factors for trisomy 21: maternal cigarette smoking and oral contraceptive use in a population-based case-control study. Genet Med. 1999;1(3):80-8. [pmid: 11336457].
Ye Z, Thomas DB, Ray RM. Combined oral contraceptives and risk of cervical carcinoma in situ. WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Epidemiol. 1995;24(1):19-26. [pmid: 7797343].
Yeshaya A, Orvieto R, Kaplan B, et al. Flexible starting schedule for oral contraception: effect on the incidence of breakthrough bleeding and compliance. Eur J Contracept Reprod Health Care. 1998;3(3):121-3. [pmid: 9853202].
Yeshaya A, Orvieto R, Kauschansky A, et al. A delayed starting schedule of oral contraception: the effect on the incidence of breakthrough bleeding and compliance in women. Eur J Contracept Reprod Health Care. 1996;1(3):263-5. [pmid: 9678125].
Yin Z, Xu W, Xu C, et al. A population-based case-control study of risk factors for neural tube defects in Shenyang. China Childs Nerv Syst. 2011;27(1):149-54. [pmid: 20582422].
Ylitalo N, Sorensen P, Josefsson A, et al. Smoking and oral contraceptives as risk factors for cervical carcinoma in situ. Int J Cancer. 1999;81(3):357-65. [pmid: 10209949].
Yonkers KA, Brown C, Pearlstein TB, et al. Efficacy of a new low-dose oral contraceptive with drospirenone in premenstrual dysphoric disorder. Obstet Gynecol. 2005;106(3):492-501. [pmid: 16135578].
Yu MW, Chang HC, Chang SC, et al. Role of reproductive factors in hepatocellular carcinoma: Impact on hepatitis B- and C-related risk. Hepatology. 2003;38(6):1393-400. [pmid: 14647050].
Zahradnik HP, Hanjalic-Beck A. Efficacy, safety and sustainability of treatment continuation and results of an oral contraceptive containing 30 mcg ethinyl estradiol and 2 mg chlormadinone acetate, in long-term usage (up to 45 cycles)--an open-label, prospective, noncontrolled, office-based Phase III study. Contraception. 2008;77(5):337-43. [pmid: 18402849].
Zanetti R, Franceschi S, Rosso S, et al. Cutaneous malignant melanoma in females: the role of hormonal and reproductive factors. Int J Epidemiol. 1990;19(3):522-6. [pmid: 2262243].
Zapata LB, Paulen ME, Cansino C, et al. Contraceptive use among women with inflammatory bowel disease: A systematic review. Contraception. 2010;82(1):72-85. [pmid: 20682145].
Zhang Y, Coogan PF, Palmer JR, et al. A case-control study of reproductive factors, female hormone use, and risk of pancreatic cancer. Cancer Causes Control. 2010;21(3):473-8. [pmid: 19941157].
Zivadinovic R, Lilic G, Lilic V, et al. Recurrence of cervical intraepithelial neoplasias with negative cone margins: risk factors. J BUON. 2011;16(3):498-504. [pmid: 22006757].
Zondervan KT, Carpenter LM, Painter R, et al. Oral contraceptives and cervical cancer--further findings from the Oxford Family Planning Association contraceptive study. Br J Cancer. 1996;73(10):1291-7. [pmid: 8630295].

## Does not include non-OC controls (comparisons between OC formulations acceptable for articles reporting VTE, stroke, or MI)

Affinito P, Monterubbianesi M, Primizia M, et al. Efficacy, cycle control and side-effects of two monophasic combination oral contraceptives: gestodene/ethinylestradiol and norgestimate/ethinylestradiol. Gynecol Endocrinol. 1993;7(4):259-66. [pmid: 8147235].
Ahrendt HJ, Karckt U, Pichl T, et al. The effects of an oestrogen-free, desogestrel-containing oral contraceptive in women with cyclical symptoms: results from two studies on oestrogen-related symptoms and dysmenorrhoea. Eur J Contracept Reprod Health Care. 2007;12(4):354-61. [pmid: 17853159].
Ahrendt HJ, Makalova D, Parke S, et al. Bleeding pattern and cycle control with an estradiol-based oral contraceptive: a seven-cycle, randomized comparative trial of estradiol valerate/dienogest and ethinyl estradiol/levonorgestrel. Contraception. 2009;80(5):436-44. [pmid: 19835717].
Akerlund M, Rode A, Westergaard J. Comparative profiles of reliability, cycle control and side effects of two oral contraceptive formulations containing 150 micrograms desogestrel and either 30 micrograms or 20 micrograms ethinyl oestradiol. Br J Obstet Gynaecol. 1993;100(9):832-8. [pmid: 8218004].
Akerlund M. Clinical experience of a combined oral contraceptive with very low dose ethinyl estradiol. Acta Obstet Gynecol Scand Suppl. 1997;164:63-5. [pmid: 9225641].
Al-Saad S, Al-Shinnawi H, Shamsi NM. Risk factors of breast cancer in Bahrain. Bahrain Medical Bulletin. 2009;31(2).
Anderson FD, Hait H. A multicenter, randomized study of an extended cycle oral contraceptive. Contraception. 2003;68(2):89-96. [pmid: 12954519].
Andolsek KM. Cycle control with triphasic norgestimate and ethinyl estradiol, a new oral contraceptive agent. Acta Obstet Gynecol Scand Suppl. 1992;156:22-6. [pmid: 1324553].
Anonymous. A double-blind study comparing the contraceptive efficacy, acceptability and safety of two progestogen-only pills containing desogestrel 75 micrograms/day or levonorgestrel 30 micrograms/day. Collaborative Study Group on the Desogestrel-containing Progestogen-only Pill. Eur J Contracept Reprod Health Care. 1998;3(4):169-78. [pmid: 10036599].
Anstee P, Kovacs GT. A prospective randomized study comparing the clinical effects of a norethisterone and a levonorgestrel containing low dose oestrogen oral contraceptive pills. Aust N Z J Obstet Gynaecol. 1993;33(1):81-3. [pmid: 8498949].
Archer DF, Maheux R, DelConte A, et al. Efficacy and safety of a low-dose monophasic combination oral contraceptive containing 100 microg levonorgestrel and 20 microg ethinyl estradiol (Alesse). North american Levonorgestrel Study Group (NALSG). Am J Obstet Gynecol. 1999;181(5 Pt 2):39-44. [pmid: 10561674].
Arowojolu AO, Gallo MF, Grimes DA, et al. Combined oral contraceptive pills for treatment of acne. Cochrane Database Syst Rev. 2004;(3):CD004425. [pmid: 15266533].
Arowojolu AO, Gallo MF, Lopez LM, et al. Combined oral contraceptive pills for treatment of acne. Cochrane Database Syst Rev. 2007;(1):CD004425. [pmid: 17253506].
Arowojolu AO, Gallo MF, Lopez LM, et al. Combined oral contraceptive pills for treatment of acne. Cochrane Database Syst Rev. 2009;(3):CD004425. [pmid: 19588355].
Bassol S, Alvarado A, Celis C, et al. Latin american experience with two low-dose oral contraceptives containing 30 microg ethinylestradiol/75 microg gestodene and 20 microg ethinylestradiol/150 microg desogestrel. Contraception. 2000;62(3):131-5. [pmid: 11124360].
Bassol S, Alvarado G, Arreola RG, et al. A 13-month multicenter clinical experience of a low-dose monophasic oral contraceptive containing 20 microg ethinylestradiol and 75 microg gestodene in Latin American women. Contraception. 2003;67(5):367-72. [pmid: 12742559].
Belicova M, Lukac B, Dvorsky J, et al. Thromboembolic disease and present oral contraception. Clin Appl Thromb Hemost. 2003;9(1):45-51. [pmid: 12643323].
Blank MM, Wentzensen N, Murphy MA, et al. Dietary fat intake and risk of ovarian cancer in the NIH-AARP Diet and Health Study. Br J Cancer. 2012;106(3):596-602. [pmid: 22223086].
Blumel JE, Castelo-Branco C, Binfa L, et al. A scheme of combined oral contraceptives for women more than 40 years old. Menopause. 2001;8(4):286-9. [pmid: 11449087].
Brucker C, Hedon B, The HS, et al. Long-term efficacy and safety of a monophasic combined oral contraceptive containing 0.02 mg ethinylestradiol and 2 mg chlormadinone acetate administered in a 24/4-day regimen. Contraception. 2010;81(6):501-9. [pmid: 20472117].
Bruni V, Croxatto H, De La Cruz J, et al. A comparison of cycle control and effect on well-being of monophasic gestodene-, triphasic gestodene- and monophasic desogestrel-containing oral contraceptives. Gestodene Study Group Gynecol Endocrinol. 2000;14(2):90-8. [pmid: 10836195].
Burnhill MS. The use of a large-scale surveillance system in Planned Parenthood Federation of America clinics to monitor cardiovascular events in users of combination oral contraceptives. Int J Fertil Womens Med. 1999;44(1):19-30. [pmid: 10206196].
Cachrimanidou AC, Hellberg D, Nilsson S, et al. Long-interval treatment regimen with a desogestrel-containing oral contraceptive. Contraception. 1993;48(3):205-16. [pmid: 8222651].
Chavez A, DelConte A. A comparison of cycle control with monophasic levonorgestrel/ethinylestradiol 100 micrograms/20 micrograms versus triphasic norethindrone/ethinylestradiol 500-750-1000 micrograms/35 micrograms: a multicenter, randomized, open-label study. Eur J Contracept Reprod Health Care. 1999;4(2):75-83. [pmid: 10427482].
Christiansen SC, Cannegieter SC, Koster T, et al. Thrombophilia, clinical factors, and recurrent venous thrombotic events. JAMA. 2005;293(19):2352-61. [pmid: 15900005].
Christiansen SC, Lijfering WM, Helmerhorst FM, et al. Sex difference in risk of recurrent venous thrombosis and the risk profile for a second event. Journal of Thrombosis and Haemostasis. 2010;8(10):2159-2168. [pmid: 20738758].
Chroustova D, Kubinyi J, Jansa P, et al. V/P scan in diagnosis and follow-up of pulmonary embolism in 15-25-year-old females in relation to hormonal contraception use. Nucl Med Rev Cent East Eur. 2011;14(2):63-7. [pmid: 22219145].
Cibula D, Karck U, Weidenhammer HG, et al. Efficacy and safety of a low-dose 21-day combined oral contraceptive containing ethinylestradiol 20microg and drospirenone 3mg. Clin Drug Investig. 2006;26(3):143-50. [pmid: 17163245].
Ciccone A, Gatti A, Melis M, et al. Cigarette smoking and risk of cerebral sinus thrombosis in oral contraceptive users: a case-control study. Neurol Sci. 2005;26(5):319-23. [pmid: 16388365].
Coffee AL, Kuehl TJ, Willis S, et al. Oral contraceptives and premenstrual symptoms: comparison of a 21/7 and extended regimen. Am J Obstet Gynecol. 2006;195(5):1311-9. [pmid: 16796986].
Corson SL. Efficacy and clinical profile of a new oral contraceptive containing norgestimate. U.S. clinical trials. Acta Obstet Gynecol Scand Suppl. 1990;152:25-31. [pmid: 2189282].
Cotterchio M, Kreiger N, Theis B, et al. Hormonal factors and the risk of breast cancer according to estrogen- and progesterone-receptor subgroup. Cancer Epidemiol Biomarkers Prev. 2003;12(10):1053-60. [pmid: 14578142].
Coutinho EM, Mascarenhas I, de Acosta OM, et al. Comparative study on the efficacy, acceptability, and side effects of a contraceptive pill administered by the oral and the vaginal route: an international multicenter clinical trial. Clin Pharmacol Ther. 1993;54(5):540-5. [pmid: 8222497].
Coutinho JM, Ferro JM, Canhao P, et al. Cerebral venous and sinus thrombosis in women. Stroke. 2009;40(7):2356-61. [pmid: 19478226].
Couturaud F, Kearon C, Leroyer C, et al. Incidence of venous thromboembolism in first-degree relatives of patients with venous thromboembolism who have factor V Leiden. Thromb Haemost. 2006;96(6):744-9. [pmid: 17139368].
Dinger J, Bardenheuer K, Moehner S. The risk of venous thromboembolism in users of a drospirenone-containing oral contraceptive with a 24-day regimen – results from the INAS-OC Study. Fertility and Sterility. 2010;94(4 Supplement):S3.
Farmer RD, Williams TJ, Simpson EL, et al. Effect of 1995 pill scare on rates of venous thromboembolism among women taking combined oral contraceptives: analysis of general practice research database. BMJ. 2000;321(7259):477-9. [pmid: 10948026].
Gallo MF, Nanda K, Grimes DA, et al. 20 mcg versus >20 mcg estrogen combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2005;(2):CD003989. [pmid: 15846690].
Gallo MF, Nanda K, Grimes DA, et al. 20 microg versus >20 microg estrogen combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2008;(4):CD003989. [pmid: 18843653].
Gallo MF, Nanda K, Grimes DA, et al. 20 microg versus >20 microg estrogen combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2011;(1):CD003989. [pmid: 21249657].
Gallo MF, Nanda K, Grimes DA, et al. Twenty micrograms vs. >20 microg estrogen oral contraceptives for contraception: systematic review of randomized controlled trials. Contraception. 2005;71(3):162-9. [pmid: 15722064].
Grace E, Emans SJ, Havens KK, et al. Contraceptive compliance with a triphasic and a monophasic norethindrone-containing oral contraceptive pill in a private adolescent practice. Adolescent and Pediatric Gynecology. 1994;7(1):29-33.
Grimes DA, Lopez LM, O'Brien P, et al. Progestin-only pills for contraception. Cochrane Database of Systematic Reviews. 2009;(1):CD007541.
Grimes DA, Lopez LM, O'Brien PA, et al. Progestin-only pills for contraception. Cochrane Database Syst Rev. 2010;(1):CD007541. [pmid: 20091638].
Guang-Sheng F, Mei-Lu B, Li-Nan C, et al. Efficacy and safety of the combined oral contraceptive ethinylestradioldrospirenone (Yasmin(registered trademark)) in healthy Chinese women: A randomized, open-label, controlled, multicentre trial. Clinical Drug Investigation. 2010;30(6):387-396. [pmid: 20201608].
Hitchcock CL, Prior JC. Evidence about extending the duration of oral contraceptive use to suppress menstruation. Womens Health Issues. 2004;14(6):201-11. [pmid: 15589770].
Jensen G, Nyboe J, Appleyard M, et al. Risk factors for acute myocardial infarction in Copenhagen, II: Smoking, alcohol intake, physical activity, obesity, oral contraception, diabetes, lipids, and blood pressure. Eur Heart J. 1991;12(3):298-308. [pmid: 2040311].
Jick S, Kaye JA, Li L, et al. Further results on the risk of nonfatal venous thromboembolism in users of the contraceptive transdermal patch compared to users of oral contraceptives containing norgestimate and 35 microg of ethinyl estradiol. Contraception. 2007;76(1):4-7. [pmid: 17586129].
Jick SS, Hagberg KW, Hernandez RK, et al. Postmarketing study of ORTHO EVRA and levonorgestrel oral contraceptives containing hormonal contraceptives with 30 mcg of ethinyl estradiol in relation to nonfatal venous thromboembolism. Contraception. 2010;81(1):16-21. [pmid: 20004268].
Jick SS, Kaye JA, Russmann S, et al. Risk of nonfatal venous thromboembolism in women using a contraceptive transdermal patch and oral contraceptives containing norgestimate and 35 microg of ethinyl estradiol. Contraception. 2006;73(3):223-8. [pmid: 16472560].
Kashanian M, Shahpourian F, Zare O. A comparison between monophasic levonorgestrel-ethinyl estradiol 150/30 and triphasic levonorgestrel-ethinyl estradiol 50-75-125/30-40-30 contraceptive pills for side effects and patient satisfaction: a study in Iran. Eur J Obstet Gynecol Reprod Biol. 2010;150(1):47-51. [pmid: 20185226].
Kaunitz AM, Garceau RJ, Cromie MA. Comparative safety, efficacy, and cycle control of Lunelle monthly contraceptive injection (medroxyprogesterone acetate and estradiol cypionate injectable suspension) and Ortho-Novum 7/7/7 oral contraceptive (norethindrone/ethinyl estradiol triphasic). Lunelle Study Group. Contraception. 1999;60(4):179-87. [pmid: 10640164].
Kaunitz AM. Efficacy, cycle control, and safety of two triphasic oral contraceptives: Cyclessa (desogestrel/ethinyl estradiol) and ortho-Novum 7/7/7 (norethindrone/ethinyl estradiol): a randomized clinical trial. Contraception. 2000;61(5):295-302. [pmid: 10906499].
Kelly S, Davies E, Fearns S, et al. Effects of oral contraceptives containing ethinylestradiol with either drospirenone or levonorgestrel on various parameters associated with well-being in healthy women: a randomized, single-blind, parallel-group, multicentre study. Clin Drug Investig. 2010;30(5):325-36. [pmid: 20384388].
Kerscher M, Reuther T, Bayrhammer J, et al. Effects of an oral contraceptive containing chlormadinone and ethinylestradiol on acne-prone skin of women of different age groups: an open-label, single-centre, phase IV study. Clin Drug Investig. 2008;28(11):703-11. [pmid: 18840013].
Kirkman RJ, Bromham DR, O'Connor TP, et al. Prospective multicentre study comparing levonorgestrel implants with a combined contraceptive pill: final results. Br J Fam Plann. 1999;25(2):36-40. [pmid: 10454652].
Kirkman RJ, Pedersen JH, Fioretti P, et al. Clinical comparison of two low-dose oral contraceptives, Minulet and Mercilon, in women over 30 years of age. Contraception. 1994;49(1):33-46. [pmid: 8137624].
Koetsawang S, Charoenvisal C, Banharnsupawat L, et al. Multicenter trial of two monophasic oral contraceptives containing 30 mcg ethinylestradiol and either desogestrel or gestodene in Thai women. Contraception. 1995;51(4):225-9. [pmid: 7796587].
Legnani C, Cini M, Cosmi B, et al. Oral contraceptive use in women with poor anticoagulant response to activated protein C but not carrying the factor V Leiden mutation increases the risk of venous thrombosis. Thromb Haemost. 2004;91(4):712-8. [pmid: 15045132].
Lopez Laureen M, Newmann Sara J, Grimes David A, et al. Immediate start of hormonal contraceptives for contraception. Cochrane Database Syst Rev. 2008;(2):CD006260. [pmid: 18425943].
Mahmoodi BK, Brouwer JL, Ten Kate MK, et al. A prospective cohort study on the absolute risks of venous thromboembolism and predictive value of screening asymptomatic relatives of patients with hereditary deficiencies of protein S, protein C or antithrombin. J Thromb Haemost. 2010;8(6):1193-200. [pmid: 20230415].
Mahmoodi BK, Gansevoort RT, Veeger NJ, et al. Microalbuminuria and risk of venous thromboembolism. JAMA. 2009;301(17):1790-7. [pmid: 19417196].
Maitra Nandita N, Kulier R, Bloemenkamp K, et al. Progestogens in combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2004;(3):CD004861. [pmid: 15266546].
Mendonca MA, Tavares-Murta BM, Bachin ES, et al. Relationship between risk factors and tumor stage in breast cancer patients in a university hospital--Brazil. Eur J Gynaecol Oncol. 2008;29(1):80-2. [pmid: 18386471].
Ng EH, Gao F, Ji CY, et al. Risk factors for breast carcinoma in Singaporean Chinese women: the role of central obesity. Cancer. 1997;80(4):725-31. [pmid: 9264356].
Nightingale AL, Lawrenson RA, Simpson EL, et al. The effects of age, body mass index, smoking and general health on the risk of venous thromboembolism in users of combined oral contraceptives. Eur J Contracept Reprod Health Care. 2000;5(4):265-74. [pmid: 11245554].
Robertson C, Primic-Zakelj M, Boyle P, et al. Effect of parity and age at delivery on breast cancer risk in Slovenian women aged 25-54 years. Int J Cancer. 1997;73(1):1-9. [pmid: 9334801].
Rosenberg MJ, Waugh MS, Stevens CM. Smoking and cycle control among oral contraceptive users. Am J Obstet Gynecol. 1996;174(2):628-32. [pmid: 8623797].
Schambeck CM, Schwender S, Haubitz I, et al. Selective screening for the Factor V Leiden mutation: is it advisable prior to the prescription of oral contraceptives?. Thromb Haemost. 1997;78(6):1480-3. [pmid: 9423798].
Schlehofer B, Blettner M, Preston-Martin S, et al. Role of medical history in brain tumour development. Results from the international adult brain tumour study. Int J Cancer. 1999;82(2):155-60. [pmid: 10389745].
Schouten LJ, Zeegers MP, Goldbohm RA, et al. Alcohol and ovarian cancer risk: results from the Netherlands Cohort Study. Cancer Causes Control. 2004;15(2):201-9. [pmid: 15017133].
Serfaty D, Vree ML. A comparison of the cycle control and tolerability of two ultra low-dose oral contraceptives containing 20 micrograms ethinylestradiol and either 150 micrograms desogestrel or 75 micrograms gestodene. Eur J Contracept Reprod Health Care. 1998;3(4):179-89. [pmid: 10036600].
Shoupe D. Multicenter randomized comparative trial of two low-dose triphasic combined oral contraceptives containing desogestrel or norethindrone. Obstet Gynecol. 1994;83(5 Pt 1):679-85. [pmid: 8164925].
Shulman LP. Clinical trial results with MPA/E2C. J Reprod Med. 2000;45(10 Suppl):873-7. [pmid: 11077646].
Shulman LP. Controlled trial with a monthly combination injectable contraceptive in the USA. Gynecol Endocrinol. Suppl 3. 2001;15:15-8. [pmid: 11570313].
Singh M, Thomas D, Singh R, et al. A triphasic oral contraceptive pill, CTR-05: clinical efficacy and safety. Eur J Contracept Reprod Health Care. 1996;1(3):285-92. [pmid: 9678128].
Somigliana E, Vercellini P, Vigano P, et al. Endometriosis and estroprogestins: the chicken or the egg causality dilemma. Fertil Steril. 2011;95(1):431-3. [pmid: 20883987].
Spicer DV, Pike MC, Pike A, et al. Pilot trial of a gonadotropin hormone agonist with replacement hormones as a prototype contraceptive to prevent breast cancer. Contraception. 1993;47(5):427-44. [pmid: 8390340].
Spitzer WO. Cyproterone acetate with ethinylestradiol as a risk factor for venous thromboembolism: an epidemiological evaluation. J Obstet Gynaecol Can. 2003;25(12):1011-8. [pmid: 14663535].
Sulak PJ, Carl J, Gopalakrishnan I, et al. Outcomes of extended oral contraceptive regimens with a shortened hormone-free interval to manage breakthrough bleeding. Contraception. 2004;70(4):281-7. [pmid: 15451331].
Sulak PJ, Cressman BE, Waldrop E, et al. Extending the duration of active oral contraceptive pills to manage hormone withdrawal symptoms. Obstet Gynecol. 1997;89(2):179-83. [pmid: 9015017].
Sulak PJ, Kuehl TJ, Ortiz M, et al. Acceptance of altering the standard 21-day/7-day oral contraceptive regimen to delay menses and reduce hormone withdrawal symptoms. Am J Obstet Gynecol. 2002;186(6):1142-9. [pmid: 12066088].
Sulak PJ, Scow RD, Preece C, et al. Hormone withdrawal symptoms in oral contraceptive users. Obstet Gynecol. 2000;95(2):261-6. [pmid: 10674591].
Sulak PJ, Smith V, Coffee A, et al. Frequency and management of breakthrough bleeding with continuous use of the transvaginal contraceptive ring: a randomized controlled trial. Obstet Gynecol. 2008;112(3):563-71. [pmid: 18757653].
Suthipongse W, Taneepanichskul S. An open-label randomized comparative study of oral contraceptives between medications containing 3 mg drospirenone/30 microg ethinylestradiol and 150 microg levonogestrel/30 microg ethinylestradiol in Thai women. Contraception. 2004;69(1):23-6. [pmid: 14720615].
Trossarelli GF, Gennarelli G, Benedetto C, et al. Climacteric symptoms and control of the cycle in women aged 35 years or older taking an oral contraceptive with 0.150 mg desogestrel and 0.020 mg ethinylestradiol. Contraception. 1995;51(1):13-8. [pmid: 7750278].
Tsilidis KK, Allen NE, Key TJ, et al. Menopausal hormone therapy and risk of ovarian cancer in the European prospective investigation into cancer and nutrition. Cancer Causes Control. 2011;22(8):1075-84. [pmid: 21637986].
Uharcek P, Mlyncek M, Ravinger J, et al. Independent prognostic factors in endometrial cancer: A single institution review. Central European Journal of Medicine. 2011;6(3):294-299.
Uharcek P, Mlyncek M, Ravinger J, et al. Prognostic factors in women 45 years of age or younger with endometrial cancer. Int J Gynecol Cancer. 2008;18(2):324-8. [pmid: 18334010].
Van Vliet H, Grimes D, Helmerhorst F, et al. Biphasic versus monophasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2001;(4):CD002032. [pmid: 11687135].
Van Vliet H, Grimes D, Helmerhorst F, et al. Biphasic versus triphasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2001;(4):CD003283. [pmid: 11687185].
Van Vliet HA, Grimes DA, Helmerhorst FM, et al. Biphasic versus monophasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2003;(2):CD002032. [pmid: 12804421].
Van Vliet HA, Grimes DA, Helmerhorst FM, et al. Biphasic versus monophasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2006;(3):CD002032. [pmid: 16855983].
Van Vliet HA, Grimes DA, Helmerhorst FM, et al. Biphasic versus monophasic oral contraceptives for contraception: a Cochrane review. Hum Reprod. 2002;17(4):870-3. [pmid: 11925375].
Van Vliet HA, Grimes DA, Helmerhorst FM, et al. Biphasic versus triphasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2003;(2):CD003283. [pmid: 12804457].
Van Vliet HA, Grimes DA, Helmerhorst FM, et al. Biphasic versus triphasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2006;(3):CD003283. [pmid: 16856002].
van Vliet HA, Grimes DA, Helmerhorst FM, et al. Biphasic versus triphasic oral contraceptives for contraception. Contraception. 2002;65(5):321-4. [pmid: 12057781].
van Vliet HA, Grimes DA, Lopez LM, et al. Triphasic versus monophasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2006;(3):CD003553. [pmid: 16856013].
Visser J, Snel M, Van Vliet HA. Hormonal versus non-hormonal contraceptives in women with diabetes mellitus type 1 and 2. Cochrane Database Syst Rev. 2006;(4):CD003990. [pmid: 17054193].
Vitonis AF, Titus-Ernstoff L, Cramer DW. Assessing ovarian cancer risk when considering elective oophorectomy at the time of hysterectomy. Obstetrics and Gynecology. 2011;117(5):1042-1050. [pmid: 21471855].
Vree ML, Schmidt J. A large observational clinical evaluation of a desogestrel-containing combiphasic oral contraceptive in Germany. Eur J Contracept Reprod Health Care. 2001;6(2):108-14. [pmid: 11518448].
Warren JW, Clauw DJ, Wesselmann U, et al. Sexuality and reproductive risk factors for interstitial cystitis/painful bladder syndrome in women. Urology. 2011;77(3):570-5. [pmid: 21215994].
Weber-Diehl F, Lehnert J, Lachnit U. Comparison of two triphasic oral contraceptives containing either gestodene or norethindrone: a randomized, controlled trial. Contraception. 1993;48(4):291-301. [pmid: 8222658].
Wendler J, Siegert C, Schelhorn P, et al. The influence of Microgynon and Diane-35, two sub-fifty ovulation inhibitors, on voice function in women. Contraception. 1995;52(6):343-8. [pmid: 8749597].
Were EO, Kendall JZ, Nyongesa P. Randomised clinical trial to determine optimum initiation time of norgestrel-progestin only contraception in Eldoret Teaching Hospital, Kenya. East Afr Med J. 1997;74(2):103-7. [pmid: 9185396].
Westhoff C, Kaunitz AM, Korver T, et al. Efficacy, safety, and tolerability of a monophasic oral contraceptive containing nomegestrol acetate and 17(beta)-estradiol: A randomized controlled trial. Obstetrics and Gynecology. 2012;119(5):989-999. [pmid: 22525910].
Wiebe ER, Trouton K, Fang ZA. Comparing continuation rates and side effects of hormonal contraceptives in East Asian and Caucasian women after abortion. Contraception. 2008;78(5):405-8. [pmid: 18929738].
Woutersz TB. Clinical experience with a triphasic oral contraceptive in healthy, nonsmoking women aged 35 to 45 years: Results of a multicenter trial. Current Therapeutic Research - Clinical and Experimental. 1994;55(2):111-118.
Zervoudakis A, Strickler HD, Park Y, et al. Reproductive history and risk of colorectal cancer in postmenopausal women. J Natl Cancer Inst. 2011;103(10):826-34. [pmid: 21447807].

## Nonrandomized study <100 subjects

Mok CC, Lau CS, Wong RW. Use of exogenous estrogens in systemic lupus erythematosus. Semin Arthritis Rheum. 2001;30(6):426-35. [pmid: 11404826].
Tepper NK, Paulen ME, Marchbanks PA, et al. Safety of contraceptive use among women with peripartum cardiomyopathy: a systematic review. Contraception. 2010;82(1):95-101. [pmid: 20682147].