# Included Studies

Althuis MD, Brogan DD, Coates RJ, et al. Breast cancers among very young premenopausal women (United States). Cancer Causes Control. 2003;14(2):151-60. [pmid: 12749720].
Althuis MD, Brogan DR, Coates RJ, et al. Hormonal content and potency of oral contraceptives and breast cancer risk among young women. Br J Cancer. 2003;88(1):50-7. [pmid: 12556959].
Andersen BS, Olsen J, Nielsen GL, et al. Third generation oral contraceptives and heritable thrombophilia as risk factors of non-fatal venous thromboembolism. Thromb Haemost. 1998;79(1):28-31. [pmid: 9459317].
Anonymous. Acute myocardial infarction and combined oral contraceptives: results of an international multicentre case-control study. WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1997;349(9060):1202-9. [pmid: 9130941].
Anonymous. Cardiovascular disease and use of oral and injectable progestogen-only contraceptives and combined injectable contraceptives Results of an international, multicenter, case-control study. World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Contraception. 1998;57(5):315-24. [pmid: 9673838].
Anonymous. Effect of different progestagens in low oestrogen oral contraceptives on venous thromboembolic disease. World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1995;346(8990):1582-8. [pmid: 7500749].
Anonymous. Haemorrhagic stroke, overall stroke risk, and combined oral contraceptives: results of an international, multicentre, case-control study. WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1996;348(9026):505-10. [pmid: 8757152].
Anonymous. Ischaemic stroke and combined oral contraceptives: results of an international, multicentre, case-control study. WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1996;348(9026):498-505. [pmid: 8757151].
Anonymous. Venous thromboembolic disease and combined oral contraceptives: results of international multicentre case-control study. World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1995;346(8990):1575-82. [pmid: 7500748].
Antoniou AC, Rookus M, Andrieu N, et al. Reproductive and hormonal factors, and ovarian cancer risk for BRCA1 and BRCA2 mutation carriers: results from the International BRCA1/2 Carrier Cohort Study. Cancer Epidemiol Biomarkers Prev. 2009;18(2):601-10. [pmid: 19190154].
Austin H, Lally C, Benson JM, et al. Hormonal contraception, sickle cell trait, and risk for venous thromboembolism among African American women. Am J Obstet Gynecol. 2009;200(6):620 e1-3. [pmid: 19306959].
Badawy YA, Bayoumi DM. An epidemiologic study of ovarian cancer. Part 11: Oral contraceptive use and menstrual events. J Egypt Public Health Assoc. 1992;67(5-6):579-91. [pmid: 1294683].
Barinagarrementeria F, Gonzalez-Duarte A, Miranda L, et al. Cerebral infarction in young women: analysis of 130 cases. Eur Neurol. 1998;40(4):228-33. [pmid: 9813407].
Barnett GC, Shah M, Redman K, et al. Risk factors for the incidence of breast cancer: do they affect survival from the disease?. J Clin Oncol. 2008;26(20):3310-6. [pmid: 18612147].
Barsoum MK, Heit JA, Ashrani AA, et al. Is progestin an independent risk factor for incident venous thromboembolism? A population-based case-control study. Thromb Res. 2010;126(5):373-8. [pmid: 20833412].
Beard CM, Hartmann LC, Atkinson EJ, et al. The epidemiology of ovarian cancer: a population-based study in Olmsted County, Minnesota, 1935-1991. Ann Epidemiol. 2000;10(1):14-23. [pmid: 10658685].
Beral V, Doll R, Hermon C, et al. Ovarian cancer and oral contraceptives: collaborative reanalysis of data from 45 epidemiological studies including 23,257 women with ovarian cancer and 87,303 controls. Lancet. 2008;371(9609):303-14. [pmid: 18294997].
Beral V, Hermon C, Kay C, et al. Mortality associated with oral contraceptive use: 25 year follow up of cohort of 46 000 women from Royal College of General Practitioners' oral contraception study. BMJ. 1999;318(7176):96-100. [pmid: 9880284].
Bernholtz S, Laitman Y, Kaufman B, et al. Cancer risk in Jewish BRCA1 and BRCA2 mutation carriers: Effects of oral contraceptive use and parental origin of mutation. Breast Cancer Research and Treatment. 2011;129(2):557-563. [pmid: 21499684].
Bloemenkamp KW, Rosendaal FR, Buller HR, et al. Risk of venous thrombosis with use of current low-dose oral contraceptives is not explained by diagnostic suspicion and referral bias. Arch Intern Med. 1999;159(1):65-70. [pmid: 9892332].
Bloemenkamp KW, Rosendaal FR, Helmerhorst FM, et al. Enhancement by factor V Leiden mutation of risk of deep-vein thrombosis associated with oral contraceptives containing a third-generation progestagen. Lancet. 1995;346(8990):1593-6. [pmid: 7500751].
Bloemenkamp KW, Rosendaal FR, Helmerhorst FM, et al. Higher risk of venous thrombosis during early use of oral contraceptives in women with inherited clotting defects. Arch Intern Med. 2000;160(1):49-52. [pmid: 10632304].
Bosetti C, Negri E, Trichopoulos D, et al. Long-term effects of oral contraceptives on ovarian cancer risk. Int J Cancer. 2002;102(3):262-5. [pmid: 12397647].
Boyce EA, Costaggini I, Vitonis A, et al. The epidemiology of ovarian granulosa cell tumors: a case-control study. Gynecol Oncol. 2009;115(2):221-5. [pmid: 19664811].
Braem MG, Onland-Moret NC, van den Brandt PA, et al. Reproductive and hormonal factors in association with ovarian cancer in the Netherlands cohort study. Am J Epidemiol. 2010;172(10):1181-9. [pmid: 20861144].
Brohet RM, Goldgar DE, Easton DF, et al. Oral contraceptives and breast cancer risk in the international BRCA1/2 carrier cohort study: a report from EMBRACE, GENEPSO, GEO-HEBON, and the IBCCS Collaborating Group. J Clin Oncol. 2007;25(25):3831-6. [pmid: 17635951].
Campbell PT, Newcomb P, Gallinger S, et al. Exogenous hormones and colorectal cancer risk in Canada: associations stratified by clinically defined familial risk of cancer. Cancer Causes Control. 2007;18(7):723-33. [pmid: 17549595].
Chang CL, Donaghy M, Poulter N. Migraine and stroke in young women: case-control study. The World Health Organisation Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. BMJ. 1999;318(7175):13-8. [pmid: 9872876].
Chen Y, Wu PC, Lang JH, et al. Risk factors for epithelial ovarian cancer in Beijing, China. Int J Epidemiol. 1992;21(1):23-9. [pmid: 1544753].
Chiaffarino F, Pelucchi C, Parazzini F, et al. Reproductive and hormonal factors and ovarian cancer. Ann Oncol. 2001;12(3):337-41. [pmid: 11332145].
Colditz GA. Oral contraceptive use and mortality during 12 years of follow-up: the Nurses' Health Study. Ann Intern Med. 1994;120(10):821-6. [pmid: 8154642].
Conard J, Plu-Bureau G, Bahi N, et al. Progestogen-only contraception in women at high risk of venous thromboembolism. Contraception. 2004;70(6):437-41. [pmid: 15541404].
Dinger J, Assmann A, Mohner S, et al. Risk of venous thromboembolism and the use of dienogest- and drospirenone-containing oral contraceptives: results from a German case-control study. J Fam Plann Reprod Health Care. 2010;36(3):123-9. [pmid: 20659364].
Dinger JC, Heinemann LA, Kuhl-Habich D. The safety of a drospirenone-containing oral contraceptive: final results from the European Active Surveillance Study on oral contraceptives based on 142,475 women-years of observation. Contraception. 2007;75(5):344-54. [pmid: 17434015].
Dolle JM, Daling JR, White E, et al. Risk factors for triple-negative breast cancer in women under the age of 45 years. Cancer Epidemiol Biomarkers Prev. 2009;18(4):1157-66. [pmid: 19336554].
Dorjgochoo T, Shu XO, Li HL, et al. Use of oral contraceptives, intrauterine devices and tubal sterilization and cancer risk in a large prospective study, from 1996 to 2006. Int J Cancer. 2009;124(10):2442-9. [pmid: 19170208].
Dossus L, Allen N, Kaaks R, et al. Reproductive risk factors and endometrial cancer: the European Prospective Investigation into Cancer and Nutrition. Int J Cancer. 2010;127(2):442-51. [pmid: 19924816].
Dumeaux V, Alsaker E, Lund E. Breast cancer and specific types of oral contraceptives: a large Norwegian cohort study. Int J Cancer. 2003;105(6):844-50. [pmid: 12767072].
Dumeaux V, Fournier A, Lund E, et al. Previous oral contraceptive use and breast cancer risk according to hormone replacement therapy use among postmenopausal women. Cancer Causes Control. 2005;16(5):537-44. [pmid: 15986108].
Dunn N, Thorogood M, Faragher B, et al. Oral contraceptives and myocardial infarction: results of the MICA case-control study. BMJ. 1999;318(7198):1579-83. [pmid: 10364115].
Dunn NR, Arscott A, Thorogood M. The relationship between use of oral contraceptives and myocardial infarction in young women with fatal outcome, compared to those who survive: results from the MICA case-control study. Contraception. 2001;63(2):65-9. [pmid: 11292469].
Dunn NR, Faragher B, Thorogood M, et al. Risk of myocardial infarction in young female smokers. Heart. 1999;82(5):581-3. [pmid: 10525513].
Faheem M, Khurram M, Jafri IA, et al. Risk factors for breast cancer in patients treated at NORI Hospital, Islamabad. J Pak Med Assoc. 2007;57(5):242-5. [pmid: 17571480].
Farmer RD, Lawrenson RA, Thompson CR, et al. Population-based study of risk of venous thromboembolism associated with various oral contraceptives. Lancet. 1997;349(9045):83-8. [pmid: 8996419].
Farmer RD, Lawrenson RA, Todd JC, et al. A comparison of the risks of venous thromboembolic disease in association with different combined oral contraceptives. Br J Clin Pharmacol. 2000;49(6):580-90. [pmid: 10848722].
Farmer RDT, Preston TD. The risk of venous thromboembolism associated with low oestrogen oral contraceptives. Journal of Obstetrics & Gynaecology. 1995;15(3):195-200.
Figueiredo JC, Bernstein L, Capanu M, et al. Oral contraceptives, postmenopausal hormones, and risk of asynchronous bilateral breast cancer: the WECARE Study Group. J Clin Oncol. 2008;26(9):1411-8. [pmid: 18250348].
Figueiredo JC, Haile RW, Bernstein L, et al. Oral contraceptives and postmenopausal hormones and risk of contralateral breast cancer among BRCA1 and BRCA2 mutation carriers and noncarriers: the WECARE Study. Breast Cancer Res Treat. 2010;120(1):175-83. [pmid: 19597986].
Folger SG, Marchbanks PA, McDonald JA, et al. Risk of breast cancer associated with short-term use of oral contraceptives. Cancer Causes Control. 2007;18(2):189-98. [pmid: 17216547].
Fowke JH, Shu XO, Dai Q, et al. Oral contraceptive use and breast cancer risk: modification by NAD(P)H:quinone oxoreductase (NQO1) genetic polymorphisms. Cancer Epidemiol Biomarkers Prev. 2004;13(8):1308-15. [pmid: 15298951].
Franceschi S, Parazzini F, Negri E, et al. Pooled analysis of 3 European case-control studies of epithelial ovarian cancer: III. Oral contraceptive use. Int J Cancer. 1991;49(1):61-5. [pmid: 1874572].
Gallagher LG, Davis LB, Ray RM, et al. Reproductive history and mortality from cardiovascular disease among women textile workers in Shanghai, China. Int J Epidemiol. 2011;40(6):1510-8. [pmid: 22158661].
Godard B, Foulkes WD, Provencher D, et al. Risk factors for familial and sporadic ovarian cancer among French Canadians: a case-control study. Am J Obstet Gynecol. 1998;179(2):403-10. [pmid: 9731846].
Gomes AL, Guimaraes MD, Gomes CC, et al. Risk factors for breast cancer among pre- or post-menopausal women in Belo Horizonte, Brazil. Gynecol Obstet Invest. 2001;52(3):173-9. [pmid: 11598359].
Goodman MT, Ferrell R, McDuffie K, et al. Calcitonin gene polymorphism CALCA-624 (T/C) and ovarian cancer. Environ Mol Mutagen. 2005;46(1):53-8. [pmid: 15880427].
Goodman MT, Wu AH, Tung KH, et al. Association of galactose-1-phosphate uridyltransferase activity and N314D genotype with the risk of ovarian cancer. Am J Epidemiol. 2002;156(8):693-701. [pmid: 12370157].
Grabrick DM, Hartmann LC, Cerhan JR, et al. Risk of breast cancer with oral contraceptive use in women with a family history of breast cancer. JAMA. 2000;284(14):1791-8. [pmid: 11025831].
Grant DJ, Moorman PG, Akushevich L, et al. Primary peritoneal and ovarian cancers: An epidemiological comparative analysis. Cancer Causes and Control. 2010;21(7):991-998. [pmid: 20309725].
Green J, Berrington de Gonzalez A, Sweetland S, et al. Risk factors for adenocarcinoma and squamous cell carcinoma of the cervix in women aged 20-44 years: the UK National Case-Control Study of Cervical Cancer. Br J Cancer. 2003;89(11):2078-86. [pmid: 14647141].
Greer JB, Modugno F, Allen GO, et al. Androgenic progestins in oral contraceptives and the risk of epithelial ovarian cancer. Obstet Gynecol. 2005;105(4):731-40. [pmid: 15802398].
Greer JB, Modugno F, Allen GO, et al. Short-term oral contraceptive use and the risk of epithelial ovarian cancer. Am J Epidemiol. 2005;162(1):66-72. [pmid: 15961588].
Greggi S, Parazzini F, Paratore MP, et al. Risk factors for ovarian cancer in central. Italy Gynecol Oncol. 2000;79(1):50-4. [pmid: 11006030].
Grodstein F, Stampfer MJ, Goldhaber SZ, et al. Prospective study of exogenous hormones and risk of pulmonary embolism in women. Lancet. 1996;348(9033):983-7. [pmid: 8855854].
Gronich N, Lavi I, Rennert G. Higher risk of venous thrombosis associated with drospirenone-containing oral contraceptives: a population-based cohort study. CMAJ. 2011;183(18):E1319-25. [pmid: 22065352].
Gronwald J, Byrski T, Huzarski T, et al. Influence of selected lifestyle factors on breast and ovarian cancer risk in BRCA1 mutation carriers from Poland. Breast Cancer Res Treat. 2006;95(2):105-9. [pmid: 16261399].
Gross TP, Schlesselman JJ, Stadel BV, et al. The risk of epithelial ovarian cancer in short-term users of oral contraceptives. Am J Epidemiol. 1992;136(1):46-53. [pmid: 1415131].
Gwinn ML, Lee NC, Rhodes PH, et al. Pregnancy, breast feeding, and oral contraceptives and the risk of epithelial ovarian cancer. J Clin Epidemiol. 1990;43(6):559-68. [pmid: 2348208].
Haile RW, Thomas DC, McGuire V, et al. BRCA1 and BRCA2 mutation carriers, oral contraceptive use, and breast cancer before age 50. Cancer Epidemiol Biomarkers Prev. 2006;15(10):1863-70. [pmid: 17021353].
Hammouda D, Munoz N, Herrero R, et al. Cervical carcinoma in Algiers, Algeria: human papillomavirus and lifestyle risk factors. Int J Cancer. 2005;113(3):483-9. [pmid: 15455386].
Hankinson SE, Colditz GA, Hunter DJ, et al. A prospective study of reproductive factors and risk of epithelial ovarian cancer. Cancer. 1995;76(2):284-90. [pmid: 8625104].
Hannaford P, Elliott A. Use of exogenous hormones by women and colorectal cancer: evidence from the Royal College of General Practitioners' Oral Contraception Study. Contraception. 2005;71(2):95-8. [pmid: 15707557].
Hannaford PC, Kay CR. The risk of serious illness among oral contraceptive users: evidence from the RCGP's oral contraceptive study. Br J Gen Pract. 1998;48(435):1657-62. [pmid: 10071398].
Hannaford PC, Iversen L, Macfarlane TV, et al. Mortality among contraceptive pill users: cohort evidence from Royal College of General Practitioners' Ora Contraception Study. BMJ. 2010;340:c927. [pmid: 20223876].
Hannaford PC, Selvaraj S, Elliott AM, et al. Cancer risk among users of oral contraceptives: cohort data from the Royal College of General Practitioner's oral contraception study. BMJ. 2007;335(7621):651. [pmid: 17855280].
Harlow BL, Cramer DW, Geller J, et al. The influence of lactose consumption on the association of oral contraceptive use and ovarian cancer risk. Am J Epidemiol. 1991;134(5):445-53. [pmid: 1897499].
Harris R, Whittemore AS, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. III. Epithelial tumors of low malignant potential in white women. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1204-11. [pmid: 1476142].
Hartge P, Whittemore AS, Itnyre J, et al. Rates and risks of ovarian cancer in subgroups of white women in the United States The Collaborative Ovarian Cancer Group. Obstet Gynecol. 1994;84(5):760-4. [pmid: 7936508].
Heimdal K, Skovlund E, Moller P. Oral contraceptives and risk of familial breast cancer. Cancer Detect Prev. 2002;26(1):23-7. [pmid: 12088199].
Heinemann LA, Assmann A, DoMinh T, et al. Oral progestogen-only contraceptives and cardiovascular risk: results from the Transnational Study on Oral Contraceptives and the Health of Young Women. Eur J Contracept Reprod Health Care. 1999;4(2):67-73. [pmid: 10427481].
Heinemann LA, Lewis MA, Spitzer WO, et al. Thromboembolic stroke in young women. A European case-control study on oral contraceptives. Transnational Research Group on Oral Contraceptives and the Health of Young Women. Contraception. 1998;57(1):29-37. [pmid: 9554248].
Heinemann LA, Lewis MA, Thorogood M, et al. Case-control study of oral contraceptives and risk of thromboembolic stroke: results from International Study on Oral Contraceptives and Health of Young Women. BMJ. 1997;315(7121):1502-4. [pmid: 9420491].
Heinemann LA, Dinger JC, Assmann A, et al. Use of oral contraceptives containing gestodene and risk of venous thromboembolism: outlook 10 years after the third-generation “pill scare”. Contraception. 2010;81(5):401-7. [pmid: 20399946].
Herings RM, Urquhart J, Leufkens HG. Venous thromboembolism among new users of different oral contraceptives. Lancet. 1999;354(9173):127-8. [pmid: 10408492].
Herrinton LJ, Voigt LF, Weiss NS, et al. Risk factors for synchronous primary endometrial and ovarian cancers. Ann Epidemiol. 2001;11(8):529-33. [pmid: 11709271].
Horn-Ross PL, Whittemore AS, Harris R, et al. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 U.S. case-control studies. VI. Nonepithelial cancers among adults. Collaborative Ovarian Cancer Group. Epidemiology. 1992;3(6):490-5. [pmid: 1329996].
Huerta C, Johansson S, Wallander MA, et al. Risk factors and short-term mortality of venous thromboembolism diagnosed in the primary care setting in the United Kingdom. Arch Intern Med. 2007;167(9):935-43. [pmid: 17502535].
Hunter DJ, Colditz GA, Hankinson SE, et al. Oral contraceptive use and breast cancer: a prospective study of young women. Cancer Epidemiol Biomarkers Prev. 2010;19(10):2496-502. [pmid: 20802021].
Huusom LD, Frederiksen K, Hogdall EV, et al. Association of reproductive factors, oral contraceptive use and selected lifestyle factors with the risk of ovarian borderline tumors: a Danish case-control study. Cancer Causes Control. 2006;17(6):821-9. [pmid: 16783610].
Jernstrom H, Loman N, Johannsson OT, et al. Impact of teenage oral contraceptive use in a population-based series of early-onset breast cancer cases who have undergone BRCA mutation testing. Eur J Cancer. 2005;41(15):2312-20. [pmid: 16118051].
Jick H, Jick SS, Gurewich V, et al. Risk of idiopathic cardiovascular death and nonfatal venous thromboembolism in women using oral contraceptives with differing progestagen components. Lancet. 1995;346(8990):1589-93. [pmid: 7500750].
Jick H, Kaye JA, Vasilakis-Scaramozza C, et al. Risk of venous thromboembolism among users of third generation oral contraceptives compared with users of oral contraceptives with levonorgestrel before and after 1995: cohort and case-control analysis. BMJ. 2000;321(7270):1190-5. [pmid: 11073511].
Jick SS, Hernandez RK. Risk of non-fatal venous thromboembolism in women using oral contraceptives containing drospirenone compared with women using oral contraceptives containing levonorgestrel: case-control study using United States claims data. BMJ. 2011;342:d2151. [pmid: 21511805].
Jick SS, Kaye JA, Russmann S, et al. Risk of nonfatal venous thromboembolism with oral contraceptives containing norgestimate or desogestrel compared with oral contraceptives containing levonorgestrel. Contraception. 2006;73(6):566-70. [pmid: 16730485].
John EM, Whittemore AS, Harris R, et al. Characteristics relating to ovarian cancer risk: collaborative analysis of seven U.S. case-control studies. Epithelial ovarian cancer in black women. Collaborative Ovarian Cancer Group. J Natl Cancer Inst. 1993;85(2):142-7. [pmid: 8418303].
Jordan SJ, Green AC, Whiteman DC, et al. Serous ovarian, fallopian tube and primary peritoneal cancers: a comparative epidemiological analysis. Int J Cancer. 2008;122(7):1598-603. [pmid: 18058817].
Kabat GC, Miller AB, Rohan TE. Oral contraceptive use, hormone replacement therapy, reproductive history and risk of colorectal cancer in women. Int J Cancer. 2008;122(3):643-6. [pmid: 17847020].
Kemmeren JM, Tanis BC, van den Bosch MA, et al. Risk of Arterial Thrombosis in Relation to Oral Contraceptives (RATIO) study: oral contraceptives and the risk of ischemic stroke. Stroke. 2002;33(5):1202-8. [pmid: 11988591].
Kumle M, Weiderpass E, Braaten T, et al. Risk for invasive and borderline epithelial ovarian neoplasias following use of hormonal contraceptives: the Norwegian-Swedish Women's Lifestyle and Health Cohort Study. Br J Cancer. 2004;90(7):1386-91. [pmid: 15054460].
Kumle M, Weiderpass E, Braaten T, et al. Use of oral contraceptives and breast cancer risk: The Norwegian-Swedish Women's Lifestyle and Health Cohort Study. Cancer Epidemiol Biomarkers Prev. 2002;11(11):1375-81. [pmid: 12433714].
Le Gal G, Kovacs MJ, Carrier M, et al. Risk of recurrent venous thromboembolism after a first oestrogen-associated episode. Data from the REVERSE cohort study. Thromb Haemost. 2010;104(3):498-503. [pmid: 20539910].
Lee E, Ma H, McKean-Cowdin R, et al. Effect of reproductive factors and oral contraceptives on breast cancer risk in BRCA1/2 mutation carriers and noncarriers: results from a population-based study. Cancer Epidemiol Biomarkers Prev. 2008;17(11):3170-8. [pmid: 18990759].
Legnani C, Cini M, Cosmi B, et al. Risk of deep vein thrombosis: interaction between oral contraceptives and high factor VIII levels. Haematologica. 2004;89(11):1347-51. [pmid: 15531457].
Legnani C, Palareti G, Guazzaloca G, et al. Venous thromboembolism in young women; role of thrombophilic mutations and oral contraceptive use. Eur Heart J. 2002;23(12):984-90. [pmid: 12069454].
Levi F, Pasche C, Lucchini F, et al. Oral contraceptives and colorectal cancer. Dig Liver Dis. 2003;35(2):85-7. [pmid: 12747625].
Lewis MA, Heinemann LA, MacRae KD, et al. The increased risk of venous thromboembolism and the use of third generation progestagens: role of bias in observational research. The Transnational Research Group on Oral Contraceptives and the Health of Young Women. Contraception. 1996;54(1):5-13. [pmid: 8804801].
Lewis MA, Heinemann LA, Spitzer WO, et al. The use of oral contraceptives and the occurrence of acute myocardial infarction in young women. Results from the Transnational Study on Oral Contraceptives and the Health of Young Women. Contraception. 1997;56(3):129-40. [pmid: 9347202].
Lewis MA, MacRae KD, Kuhl-Habichl D, et al. The differential risk of oral contraceptives: the impact of full exposure history. Hum Reprod. 1999;14(6):1493-9. [pmid: 10359554].
Lewis MA, Spitzer WO, Heinemann LA, et al. Third generation oral contraceptives and risk of myocardial infarction: an international case-control study Transnational Research Group on Oral Contraceptives and the Health of Young Women. BMJ. 1996;312(7023):88-90. [pmid: 8555936].
Lewis MA. The Transnational Study on Oral Contraceptives and the Health of Young Women. Methods, results, new analyses and the healthy user effect. Hum Reprod Update. 1999;5(6):707-20. [pmid: 10652980].
Li Y, Chen F, Zhou L, et al. COC use, ACE/AGT gene polymorphisms, and risk of stroke. Pharmacogenet Genomics. 2010;20(5):298-306. [pmid: 20300047].
Li Y, Zhou L, Coulter D, et al. Prospective cohort study of the association between use of low-dose oral contraceptives and stroke in Chinese women. Pharmacoepidemiol Drug Saf. 2006;15(10):726-34. [pmid: 16761299].
Lidegaard O, Kreiner S. Cerebral thrombosis and oral contraceptives. A case-control study. Contraception. 1998;57(5):303-14. [pmid: 9673837].
Lidegaard O, Kreiner S. Contraceptives and cerebral thrombosis: a five-year national case-control study. Contraception. 2002;65(3):197-205. [pmid: 11929641].
Lidegaard O, Edstrom B, Kreiner S. Oral contraceptives and venous thromboembolism. A case-control study. Contraception. 1998;57(5):291-301. [pmid: 9673836].
Lidegaard O, Edstrom B, Kreiner S. Oral contraceptives and venous thromboembolism: a five-year national case-control study. Contraception. 2002;65(3):187-96. [pmid: 11929640].
Lidegaard O, Lokkegaard E, Jensen A, et al. Thrombotic stroke and myocardial infarction with hormonal contraception. N Engl J Med. 2012;366(24):2257-66. [pmid: 22693997].
Lidegaard O, Lokkegaard E, Svendsen AL, et al. Hormonal contraception and risk of venous thromboembolism: national follow-up study. BMJ. 2009;339:b2890. [pmid: 19679613].
Lidegaard O, Nielsen LH, Skovlund CW, et al. Risk of venous thromboembolism from use of oral contraceptives containing different progestogens and oestrogen doses: Danish cohort study, 2001-9. BMJ. 2011;343:d6423. [pmid: 22027398].
Lidegaard O. Oral contraceptives, pregnancy and the risk of cerebral thromboembolism: the influence of diabetes, hypertension, migraine and previous thrombotic disease. Br J Obstet Gynaecol. 1995;102(2):153-9. [pmid: 7756208].
Lidegaard O. Smoking and use of oral contraceptives: impact on thrombotic diseases. Am J Obstet Gynecol. 1999;180(6 Pt 2):S357-63. [pmid: 10368521].
Lidegaard O. Thrombotic diseases in young women and the influence of oral contraceptives. Am J Obstet Gynecol. 1998;179(3 Pt 2):S62-7. [pmid: 9753312].
Lin J, Zhang SM, Cook NR, et al. Oral contraceptives, reproductive factors, and risk of colorectal cancer among women in a prospective cohort study. Am J Epidemiol. 2007;165(7):794-801. [pmid: 17215381].
Long MD, Martin CF, Galanko JA, et al. Hormone replacement therapy, oral contraceptive use, and distal large bowel cancer: a population-based case-control study. Am J Gastroenterol. 2010;105(8):1843-50. [pmid: 20354510].
Lu Y, Ma H, Malone KE, et al. Oral contraceptive use and survival in women with invasive breast cancer. Cancer Epidemiol Biomarkers Prev. 2011;20(7):1391-7. [pmid: 21551244].
Lumachi F, Frigo AC, Basso U, et al. Estrogen therapy and risk of breast cancer in postmenopausal women: a case-control study and results of a multivariate analysis. Menopause. 2010;17(3):524-8. [pmid: 20130492].
Lund E, Bakken K, Dumeaux V, et al. Hormone replacement therapy and breast cancer in former users of oral contraceptives--The Norwegian Women and Cancer study. Int J Cancer. 2007;121(3):645-8. [pmid: 17372914].
Lurie G, Thompson P, McDuffie KE, et al. Association of estrogen and progestin potency of oral contraceptives with ovarian carcinoma risk. Obstet Gynecol. 2007;109(3):597-607. [pmid: 17329510].
Lurie G, Wilkens LR, Thompson PJ, et al. Combined oral contraceptive use and epithelial ovarian cancer risk: time-related effects. Epidemiology. 2008;19(2):237-43. [pmid: 18223481].
Ma H, Bernstein L, Ross RK, et al. Hormone-related risk factors for breast cancer in women under age 50 years by estrogen and progesterone receptor status: Results from a case-control and a case-case comparison. Breast Cancer Research. 2006;8(4):R39. [pmid: 16846528].
Ma H, Wang Y, Sullivan-Halley J, et al. Use of four biomarkers to evaluate the risk of breast cancer subtypes in the women's contraceptive and reproductive experiences study. Cancer Res. 2010;70(2):575-87. [pmid: 20068186].
Madeleine MM, Daling JR, Schwartz SM, et al. Human papillomavirus and long-term oral contraceptive use increase the risk of adenocarcinoma in situ of the cervix. Cancer Epidemiol Biomarkers Prev. 2001;10(3):171-7. [pmid: 11303584].
Mant J, Painter R, Vessey M. Risk of myocardial infarction, angina and stroke in users of oral contraceptives: an updated analysis of a cohort study. Br J Obstet Gynaecol. 1998;105(8):890-6. [pmid: 9746383].
Marchbanks PA, Curtis KM, Mandel MG, et al. Oral contraceptive formulation and risk of breast cancer. Contraception. 2012;85(4):342-350. [pmid: 22067757].
Marchbanks PA, McDonald JA, Wilson HG, et al. Oral contraceptives and the risk of breast cancer. N Engl J Med. 2002;346(26):2025-32. [pmid: 12087137].
Margolis KL, Adami HO, Luo J, et al. A prospective study of oral contraceptive use and risk of myocardial infarction among Swedish women. Fertil Steril. 2007;88(2):310-6. [pmid: 17624338].
Martinelli I, Battaglioli T, Burgo I, et al. Oral contraceptive use, thrombophilia and their interaction in young women with ischemic stroke. Haematologica. 2006;91(6):844-7. [pmid: 16769590].
Maxwell GL, Schildkraut JM, Calingaert B, et al. Progestin and estrogen potency of combination oral contraceptives and endometrial cancer risk. Gynecol Oncol. 2006;103(2):535-40. [pmid: 16740300].
McGuire V, Felberg A, Mills M, et al. Relation of contraceptive and reproductive history to ovarian cancer risk in carriers and noncarriers of BRCA1 gene mutations. Am J Epidemiol. 2004;160(7):613-8. [pmid: 15383404].
McLaughlin JR, Risch HA, Lubinski J, et al. Reproductive risk factors for ovarian cancer in carriers of BRCA1 or BRCA2 mutations: a case-control study. Lancet Oncol. 2007;8(1):26-34. [pmid: 17196508].
Mills PK, Riordan DG, Cress RD. Epithelial ovarian cancer risk by invasiveness and cell type in the Central Valley of California. Gynecol Oncol. 2004;95(1):215-25. [pmid: 15385135].
Milne RL, Knight JA, John EM, et al. Oral contraceptive use and risk of early-onset breast cancer in carriers and noncarriers of BRCA1 and BRCA2 mutations. Cancer Epidemiol Biomarkers Prev. 2005;14(2):350-6. [pmid: 15734957].
Modan B, Hartge P, Hirsh-Yechezkel G, et al. Parity, oral contraceptives, and the risk of ovarian cancer among carriers and noncarriers of a BRCA1 or BRCA2 mutation. N Engl J Med. 2001;345(4):235-40. [pmid: 11474660].
Modugno F, Ness RB, Wheeler JE. Reproductive risk factors for epithelial ovarian cancer according to histologic type and invasiveness. Ann Epidemiol. 2001;11(8):568-74. [pmid: 11709277].
Modugno F, Ness RB, Allen GO, et al. Oral contraceptive use, reproductive history, and risk of epithelial ovarian cancer in women with and without endometriosis. Am J Obstet Gynecol. 2004;191(3):733-40. [pmid: 15467532].
Moorman PG, Calingaert B, Palmieri RT, et al. Hormonal risk factors for ovarian cancer in premenopausal and postmenopausal women. Am J Epidemiol. 2008;167(9):1059-69. [pmid: 18303003].
Moorman PG, Millikan RC, Newman B. Oral contraceptives and breast cancer among African-american women and white women. J Natl Med Assoc. 2001;93(9):329-34. [pmid: 11560288].
Moreno V, Bosch FX, Munoz N, et al. Effect of oral contraceptives on risk of cervical cancer in women with human papillomavirus infection: the IARC multicentric case-control study. Lancet. 2002;359(9312):1085-92. [pmid: 11943255].
Nagle CM, Bain CJ, Green AC, et al. The influence of reproductive and hormonal factors on ovarian cancer survival. Int J Gynecol Cancer. 2008;18(3):407-13. [pmid: 17645507].
Narod SA, Dube MP, Klijn J, et al. Oral contraceptives and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers. J Natl Cancer Inst. 2002;94(23):1773-9. [pmid: 12464649].
Narod SA, Risch H, Moslehi R, et al. Oral contraceptives and the risk of hereditary ovarian cancer. Hereditary Ovarian Cancer Clinical Study Group. N Engl J Med. 1998;339(7):424-8. [pmid: 9700175].
Ness RB, Dodge RC, Edwards RP, et al. Contraception Methods, Beyond Oral Contraceptives and Tubal Ligation, and Risk of Ovarian Cancer. Ann Epidemiol. 2011;21(3):188-96. [pmid: 21109450].
Ness RB, Grisso JA, Cottreau C, et al. Factors related to inflammation of the ovarian epithelium and risk of ovarian cancer. Epidemiology. 2000;11(2):111-7. [pmid: 11021606].
Ness RB, Grisso JA, Klapper J, et al. Risk of ovarian cancer in relation to estrogen and progestin dose and use characteristics of oral contraceptives. SHARE Study Group. Steroid Hormones and Reproductions. Am J Epidemiol. 2000;152(3):233-41. [pmid: 10933270].
Ness RB, Grisso JA, Vergona R, et al. Oral contraceptives, other methods of contraception, and risk reduction for ovarian cancer. Epidemiology. 2001;12(3):307-12. [pmid: 11337604].
Newcomer LM, Newcomb PA, Trentham-Dietz A, et al. Oral contraceptive use and risk of breast cancer by histologic type. Int J Cancer. 2003;106(6):961-4. [pmid: 12918077].
Nichols HB, Trentham-Dietz A, Egan KM, et al. Oral contraceptive use and risk of breast carcinoma in situ. Cancer Epidemiol Biomarkers Prev. 2007;16(11):2262-8. [pmid: 18006914].
Nichols HB, Trentham-Dietz A, Hampton JM, et al. Oral contraceptive use, reproductive factors, and colorectal cancer risk: findings from Wisconsin. Cancer Epidemiol Biomarkers Prev. 2005;14(5):1212-8. [pmid: 15894674].
Nojomi M, Modaresgilani M, Mozafari N, et al. Cervical cancer and duration of using hormonal contraceptives. Asia-Pacific Journal of Clinical Oncology. 2008;4(2):107-112.
Norman SA, Berlin JA, Weber AL, et al. Combined effect of oral contraceptive use and hormone replacement therapy on breast cancer risk in postmenopausal women. Cancer Causes Control. 2003;14(10):933-43. [pmid: 14750532].
Nyante SJ, Gammon MD, Malone KE, et al. The association between oral contraceptive use and lobular and ductal breast cancer in young women. Int J Cancer. 2008;122(4):936-41. [pmid: 17957781].
Parazzini F, Chatenoud L, Chiantera V, et al. Population attributable risk for ovarian cancer. Eur J Cancer. 2000;36(4):520-4. [pmid: 10717530].
Parazzini F, La Vecchia C, Negri E, et al. Oral contraceptive use and the risk of ovarian cancer: an Italian case-control study. Eur J Cancer. 1991;27(5):594-8. [pmid: 1828969].
Parazzini F, Restelli C, La Vecchia C, et al. Risk factors for epithelial ovarian tumours of borderline malignancy. Int J Epidemiol. 1991;20(4):871-7. [pmid: 1800425].
Parkin L, Sharples K, Hernandez RK, et al. Risk of venous thromboembolism in users of oral contraceptives containing drospirenone or levonorgestrel: nested case-control study based on UK General Practice Research Database. BMJ. 2011;342:d2139. [pmid: 21511804].
Parslov M, Lidegaard O, Klintorp S, et al. Risk factors among young women with endometrial cancer: a Danish case-control study. Am J Obstet Gynecol. 2000;182(1 Pt 1):23-9. [pmid: 10649152].
Petitti DB, Sidney S, Bernstein A, et al. Stroke in users of low-dose oral contraceptives. N Engl J Med. 1996;335(1):8-15. [pmid: 8637557].
Phillips LS, Millikan RC, Schroeder JC, et al. Reproductive and hormonal risk factors for ductal carcinoma in situ of the breast. Cancer Epidemiol Biomarkers Prev. 2009;18(5):1507-14. [pmid: 19423528].
Pike MC, Pearce CL, Peters R, et al. Hormonal factors and the risk of invasive ovarian cancer: a population-based case-control study. Fertil Steril. 2004;82(1):186-95. [pmid: 15237010].
Polychronopoulou A, Tzonou A, Hsieh CC, et al. Reproductive variables, tobacco, ethanol, coffee and somatometry as risk factors for ovarian cancer. Int J Cancer. 1993;55(3):402-7. [pmid: 8375923].
Purdie DM, Siskind V, Bain CJ, et al. Reproduction-related risk factors for mucinous and nonmucinous epithelial ovarian cancer. Am J Epidemiol. 2001;153(9):860-4. [pmid: 11323316].
Quirk JT, Natarajan N, Mettlin CJ, et al. Risk factors for invasive epithelial ovarian cancer by histologic subtype. Online Journal of Health and Allied Sciences. 2004;3(3).
Riman T, Dickman PW, Nilsson S, et al. Risk factors for epithelial borderline ovarian tumors: results of a Swedish case-control study. Gynecol Oncol. 2001;83(3):575-85. [pmid: 11733975].
Riman T, Dickman PW, Nilsson S, et al. Risk factors for invasive epithelial ovarian cancer: results from a Swedish case-control study. Am J Epidemiol. 2002;156(4):363-73. [pmid: 12181107].
Risch HA, Marrett LD, Howe GR. Parity, contraception, infertility, and the risk of epithelial ovarian cancer. Am J Epidemiol. 1994;140(7):585-97. [pmid: 7942759].
Risch HA, Marrett LD, Jain M, et al. Differences in risk factors for epithelial ovarian cancer by histologic type. Results of a case-control study. Am J Epidemiol. 1996;144(4):363-72. [pmid: 8712193].
Rosenberg L, Boggs DA, Wise LA, et al. Oral contraceptive use and estrogen/progesterone receptor-negative breast cancer among African American women. Cancer Epidemiol Biomarkers Prev. 2010;19(8):2073-9. [pmid: 20647407].
Rosenberg L, Palmer JR, Rao RS, et al. Low-dose oral contraceptive use and the risk of myocardial infarction. Arch Intern Med. 2001;161(8):1065-70. [pmid: 11322840].
Rosenberg L, Palmer JR, Zauber AG, et al. A case-control study of oral contraceptive use and invasive epithelial ovarian cancer. Am J Epidemiol. 1994;139(7):654-61. [pmid: 8166126].
Rosenberg L, Zhang Y, Coogan PF, et al. A case-control study of oral contraceptive use and incident breast cancer. Am J Epidemiol. 2009;169(4):473-9. [pmid: 19074777].
Rosenberg LU, Magnusson C, Lindstrom E, et al. Menopausal hormone therapy and other breast cancer risk factors in relation to the risk of different histological subtypes of breast cancer: a case-control study. Breast Cancer Res. 2006;8(1):R11. [pmid: 16507159].
Rosenblatt KA, Gao DL, Ray RM, et al. Contraceptive methods and induced abortions and their association with the risk of colon cancer in Shanghai, China. Eur J Cancer. 2004;40(4):590-3. [pmid: 14962728].
Rosenblatt KA, Gao DL, Ray RM, et al. Oral contraceptives and the risk of all cancers combined and site-specific cancers in Shanghai. Cancer Causes Control. 2009;20(1):27-34. [pmid: 18704712].
Rosenblatt KA, Thomas DB, Noonan EA. High-dose and low-dose combined oral contraceptives: protection against epithelial ovarian cancer and the length of the protective effect. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Eur J Cancer. 1992;28A(11):1872-6. [pmid: 1389530].
Royar J, Becher H, Chang-Claude J. Low-dose oral contraceptives: protective effect on ovarian cancer risk. Int J Cancer. 2001;95(6):370-4. [pmid: 11668519].
Salazar-Martinez E, Lazcano-Ponce EC, Gonzalez Lira-Lira G, et al. Reproductive factors of ovarian and endometrial cancer risk in a high fertility population in Mexico. Cancer Res. 1999;59(15):3658-62. [pmid: 10446978].
Samuelsson E, Hagg S. Incidence of venous thromboembolism in young Swedish women and possibly preventable cases among combined oral contraceptive users. Acta Obstet Gynecol Scand. 2004;83(7):674-81. [pmid: 15225194].
Sanderson M, Williams MA, Weiss NS, et al. Oral contraceptives and epithelial ovarian cancer. Does dose matter?. J Reprod Med. 2000;45(9):720-6. [pmid: 11027080].
Santos C, Munoz N, Klug S, et al. HPV types and cofactors causing cervical cancer in Peru. Br J Cancer. 2001;85(7):966-71. [pmid: 11592767].
Schildkraut JM, Calingaert B, Marchbanks PA, et al. Impact of progestin and estrogen potency in oral contraceptives on ovarian cancer risk. J Natl Cancer Inst. 2002;94(1):32-8. [pmid: 11773280].
Schwartz SM, Petitti DB, Siscovick DS, et al. Stroke and use of low-dose oral contraceptives in young women: a pooled analysis of two US studies. Stroke. 1998;29(11):2277-84. [pmid: 9804634].
Schwartz SM, Siscovick DS, Longstreth WT Jr, et al. Use of low-dose oral contraceptives and stroke in young women. Ann Intern Med. 1997;127(8 Pt 1):596-603. [pmid: 9341057].
Seeger JD, Loughlin J, Eng PM, et al. Risk of thromboembolism in women taking ethinylestradiol/drospirenone and other oral contraceptives. Obstet Gynecol. 2007;110(3):587-93. [pmid: 17766604].
Setiawan VW, Pike MC, Kolonel LN, et al. Racial/ethnic differences in endometrial cancer risk: the multiethnic cohort study. Am J Epidemiol. 2007;165(3):262-70. [pmid: 17090617].
Shantakumar S, Terry MB, Paykin A, et al. Age and menopausal effects of hormonal birth control and hormone replacement therapy in relation to breast cancer risk. Am J Epidemiol. 2007;165(10):1187-98. [pmid: 17337757].
Shapiro S, Rosenberg L, Hoffman M, et al. Risk of breast cancer in relation to the use of injectable progestogen contraceptives and combined estrogen/progestogen contraceptives. Am J Epidemiol. 2000;151(4):396-403. [pmid: 10695598].
Shapiro S, Rosenberg L, Hoffman M, et al. Risk of invasive cancer of the cervix in relation to the use of injectable progestogen contraceptives and combined estrogen/progestogen oral contraceptives (South Africa). Cancer Causes Control. 2003;14(5):485-95. [pmid: 12946044].
Shields TS, Brinton LA, Burk RD, et al. A case-control study of risk factors for invasive cervical cancer among U.S. women exposed to oncogenic types of human papillomavirus. Cancer Epidemiol Biomarkers Prev. 2004;13(10):1574-82. [pmid: 15466972].
Sidney S, Petitti DB, Quesenberry CP Jr, et al. Myocardial infarction in users of low-dose oral contraceptives. Obstet Gynecol. 1996;88(6):939-44. [pmid: 8942831].
Sidney S, Petitti DB, Soff GA, et al. Venous thromboembolic disease in users of low-estrogen combined estrogen-progestin oral contraceptives. Contraception. 2004;70(1):3-10. [pmid: 15208046].
Sidney S, Siscovick DS, Petitti DB, et al. Myocardial infarction and use of low-dose oral contraceptives: a pooled analysis of 2 US studies. Circulation. 1998;98(11):1058-63. [pmid: 9736591].
Silvera SA, Miller AB, Rohan TE. Oral contraceptive use and risk of breast cancer among women with a family history of breast cancer: a prospective cohort study. Cancer Causes Control. 2005;16(9):1059-63. [pmid: 16184471].
Siritho S, Thrift AG, McNeil JJ, et al. Risk of ischemic stroke among users of the oral contraceptive pill: The Melbourne Risk Factor Study (MERFS) Group. Stroke. 2003;34(7):1575-80. [pmid: 12805499].
Siskind V, Green A, Bain C, et al. Beyond ovulation: oral contraceptives and epithelial ovarian cancer. Epidemiology. 2000;11(2):106-10. [pmid: 11021605].
Soegaard M, Jensen A, Hogdall E, et al. Different risk factor profiles for mucinous and nonmucinous ovarian cancer: results from the Danish MALOVA study. Cancer Epidemiol Biomarkers Prev. 2007;16(6):1160-6. [pmid: 17548679].
Spannagl M, Heinemann LA, Schramm W. Are factor V Leiden carriers who use oral contraceptives at extreme risk for venous thromboembolism?. Eur J Contracept Reprod Health Care. 2000;5(2):105-12. [pmid: 10943572].
Spitzer WO, Lewis MA, Heinemann LA, et al. Third generation oral contraceptives and risk of venous thromboembolic disorders: an international case-control study Transnational Research Group on Oral Contraceptives and the Health of Young Women. BMJ. 1996;312(7023):83-8. [pmid: 8555935].
Steinberg KK, Smith SJ, Stroup DF, et al. Comparison of effect estimates from a meta-analysis of summary data from published studies and from a meta-analysis using individual patient data for ovarian cancer studies. Am J Epidemiol. 1997;145(10):917-25. [pmid: 9149663].
Suissa S, Blais L, Spitzer WO, et al. First-time use of newer oral contraceptives and the risk of venous thromboembolism. Contraception. 1997;56(3):141-6. [pmid: 9347203].
Suissa S, Spitzer WO, Rainville B, et al. Recurrent use of newer oral contraceptives and the risk of venous thromboembolism. Hum Reprod. 2000;15(4):817-21. [pmid: 10739826].
Suter NM, Malone KE, Daling JR, et al. Androgen receptor (CAG)n and (GGC)n polymorphisms and breast cancer risk in a population-based case-control study of young women. Cancer Epidemiol Biomarkers Prev. 2003;12(2):127-35. [pmid: 12582022].
Sweeney C, Giuliano AR, Baumgartner KB, et al. Oral, injected and implanted contraceptives and breast cancer risk among U.S. Hispanic and non-Hispanic white women. Int J Cancer. 2007;121(11):2517-23. [pmid: 17657739].
Tanis BC, van den Bosch MA, Kemmeren JM, et al. Oral contraceptives and the risk of myocardial infarction. N Engl J Med. 2001;345(25):1787-93. [pmid: 11752354].
Tao MH, Xu WH, Zheng W, et al. Oral contraceptive and IUD use and endometrial cancer: a population-based case-control study in Shanghai, China. Int J Cancer. 2006;119(9):2142-7. [pmid: 16823853].
Tavani A, Bosetti C, Dal Maso L, et al. Influence of selected hormonal and lifestyle factors on familial propensity to ovarian cancer. Gynecol Oncol. 2004;92(3):922-6. [pmid: 14984961].
Tavani A, Negri E, Franceschi S, et al. Risk factors for epithelial ovarian cancer in women under age 45. Eur J Cancer. 1993;29A(9):1297-301. [pmid: 8343272].
Tavani A, Ricci E, La Vecchia C, et al. Influence of menstrual and reproductive factors on ovarian cancer risk in women with and without family history of breast or ovarian cancer. Int J Epidemiol. 2000;29(5):799-802. [pmid: 11034959].
Thomas DB. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives: the influence of combined oral contraceptives on risk of neoplasms in developing and developed countries. Contraception. 1991;43(6):695-710. [pmid: 1868738].
Todd J, Lawrenson R, Farmer RD, et al. Venous thromboembolic disease and combined oral contraceptives: A re-analysis of the MediPlus database. Hum Reprod. 1999;14(6):1500-5. [pmid: 10357966].
Trivers KF, Gammon MD, Abrahamson PE, et al. Oral contraceptives and survival in breast cancer patients aged 20 to 54 years. Cancer Epidemiol Biomarkers Prev. 2007;16(9):1822-7. [pmid: 17855700].
Tryggvadottir L, Tulinius H, Eyfjord JE, et al. Breast cancer risk factors and age at diagnosis: an Icelandic cohort study. Int J Cancer. 2002;98(4):604-8. [pmid: 11920622].
Tsilidis KK, Allen NE, Key TJ, et al. Oral contraceptive use and reproductive factors and risk of ovarian cancer in the European Prospective Investigation into Cancer and Nutrition. Br J Cancer. 2011;105(9):1436-42. [pmid: 21915124].
Tsilidis KK, Allen NE, Key TJ, et al. Oral contraceptives, reproductive history and risk of colorectal cancer in the European Prospective Investigation into Cancer and Nutrition. Br J Cancer. 2010;103(11):1755-9. [pmid: 21045829].
Tung KH, Goodman MT, Wu AH, et al. Reproductive factors and epithelial ovarian cancer risk by histologic type: a multiethnic case-control study. Am J Epidemiol. 2003;158(7):629-38. [pmid: 14507598].
Tung KH, Wilkens LR, Wu AH, et al. Effect of anovulation factors on pre- and postmenopausal ovarian cancer risk: revisiting the incessant ovulation hypothesis. Am J Epidemiol. 2005;161(4):321-9. [pmid: 15692075].
Tworoger SS, Fairfield KM, Colditz GA, et al. Association of oral contraceptive use, other contraceptive methods, and infertility with ovarian cancer risk. Am J Epidemiol. 2007;166(8):894-901. [pmid: 17656616].
Tzourio C, Tehindrazanarivelo A, Iglesias S, et al. Case-control study of migraine and risk of ischaemic stroke in young women. BMJ. 1995;310(6983):830-3. [pmid: 7711619].
Urban M, Banks E, Egger S, et al. Injectable and oral contraceptive use and cancers of the breast, cervix, ovary, and endometrium in black South African women: case-control study. PLoS Med. 2012;9(3):e1001182. [pmid: 22412354].
Van Hoften C, Burger H, Peeters PH, et al. Long-term oral contraceptive use increases breast cancer risk in women over 55 years of age: the DOM cohort. Int J Cancer. 2000;87(4):591-4. [pmid: 10918202].
Van Hylckama Vlieg A, Helmerhorst FM, Vandenbroucke JP, et al. The venous thrombotic risk of oral contraceptives, effects of oestrogen dose and progestogen type: Results of the MEGA case-control study. BMJ. 2009;339(7720):561.
van Vlijmen EF, Brouwer JL, Veeger NJ, et al. Oral contraceptives and the absolute risk of venous thromboembolism in women with single or multiple thrombophilic defects: results from a retrospective family cohort study. Arch Intern Med. 2007;167(3):282-9. [pmid: 17296885].
van Vlijmen EF, Veeger NJ, Middeldorp S, et al. Thrombotic risk during oral contraceptive use and pregnancy in women with factor V Leiden or prothrombin mutation: a rational approach to contraception. Blood. 2011;118(8):2055-61. quiz 2375. [pmid: 21659542].
Vanakankovit N, Taneepanichskul S. Effect of oral contraceptives on risk of cervical cancer. J Med Assoc Thai. 2008;91(1):7-12. [pmid: 18386537].
Vessey M, Painter R. Oral contraceptive use and cancer. Findings in a large cohort study, 1968-2004. Br J Cancer. 2006;95(3):385-9. [pmid: 16819539].
Vessey M, Painter R, Yeates D. Mortality in relation to oral contraceptive use and cigarette smoking. Lancet. 2003;362(9379):185-91. [pmid: 12885478].
Vessey M, Yeates D, Flynn S. Factors affecting mortality in a large cohort study with special reference to oral contraceptive use. Contraception. 2010;82(3):221-9. [pmid: 20705149].
Vessey MP, Painter R. Endometrial and ovarian cancer and oral contraceptives--findings in a large cohort study. Br J Cancer. 1995;71(6):1340-2. [pmid: 7779735].
Walker GR, Schlesselman JJ, Ness RB. Family history of cancer, oral contraceptive use, and ovarian cancer risk. Am J Obstet Gynecol. 2002;186(1):8-14. [pmid: 11810077].
Wang C, Li Y, Li H, et al. Increased risk of stroke in oral contraceptive users carried replicated genetic variants: a population-based case-control study in China. Hum Genet. 2012. [pmid: 22476622].
Wernli KJ, Ray RM, Gao DL, et al. Menstrual and reproductive factors in relation to risk of endometrial cancer in Chinese women. Cancer Causes Control. 2006;17(7):949-55. [pmid: 16841262].
Whittemore AS, Balise RR, Pharoah PD, et al. Oral contraceptive use and ovarian cancer risk among carriers of BRCA1 or BRCA2 mutations. Br J Cancer. 2004;91(11):1911-5. [pmid: 15545966].
Whittemore AS, Harris R, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. II. Invasive epithelial ovarian cancers in white women. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1184-203. [pmid: 1476141].
Wilailak S, Vipupinyo C, Suraseranivong V, et al. Depot medroxyprogesterone acetate and epithelial ovarian cancer: a multicentre case-control study. BJOG. 2012;119(6):672-7. [pmid: 22489761].
Wingo PA, Austin H, Marchbanks PA, et al. Oral contraceptives and the risk of death from breast cancer. Obstet Gynecol. 2007;110(4):793-800. [pmid: 17906011].
Wittenberg J, Cook LS, Rossing MA, et al. Reproductive risk factors for mucinous and non-mucinous epithelial ovarian cancer. Epidemiology. 1999;10(6):761-3. [pmid: 10535792].
Wrensch M, Chew T, Farren G, et al. Risk factors for breast cancer in a population with high incidence rates. Breast Cancer Res. 2003;5(4):R88-102. [pmid: 12817999].
Xu WH, Shu XO, Long J, et al. Relation of FGFR2 genetic polymorphisms to the association between oral contraceptive use and the risk of breast cancer in Chinese women. Am J Epidemiol. 2011;173(8):923-31. [pmid: 21382839].
Yang HP, Trabert B, Murphy MA, et al. Ovarian cancer risk factors by histologic subtypes in the NIH-AARP diet and health study. International Journal of Cancer. 2012;131(4):938-948.
Yang L, Kuper H, Sandin S, et al. Reproductive history, oral contraceptive use, and the risk of ischemic and hemorrhagic stoke in a cohort study of middle-aged Swedish women. Stroke. 2009;40(4):1050-8. [pmid: 19211494].

## Study Groupings

Table C-1 Primary articles and companion articles grouped by study name (alphabetical)

Study Name | Primary Abstracted Article | Companion Articles^*^
Cancer and Steroid Hormone (CASH) Study | Gross, 1992^1^
Cancer and Steroid Hormone (CASH) Study | Gwinn, 1990^2^
Cancer and Steroid Hormone (CASH) Study | Maxwell, 2006^3^
Cancer and Steroid Hormone (CASH) Study | Schildkraut, 2002^4^
Collaborative Ovarian Cancer Group Study | Harris, 1992^5^ | Steinberg, 1997^6^ Whittemore, 1992^7^ Whittemore, 1992^8,*^ Whittemore, 1992^9,*^
Collaborative Ovarian Cancer Group Study | Hartge, 1994^10^ | Steinberg, 1997^6^ Whittemore, 1992^7^ Whittemore, 1992^8,*^ Whittemore, 1992^9,*^
Collaborative Ovarian Cancer Group Study | Horn-Ross, 1992^11^ | Steinberg, 1997^6^ Whittemore, 1992^7^ Whittemore, 1992^8,*^ Whittemore, 1992^9,*^
Collaborative Ovarian Cancer Group Study | John, 1993^12^ | Steinberg, 1997^6^ Whittemore, 1992^7^ Whittemore, 1992^8,*^ Whittemore, 1992^9,*^
European Prospective Investigation Into Cancer and Nutrition | Dossus, 2010^13^
European Prospective Investigation Into Cancer and Nutrition | Tsilidis, 2010^14^
European Prospective Investigation Into Cancer and Nutrition | Tsilidis, 2011^15^
International Agency for Research on Cancer (IARC) Multicentric Case-Control Study | Moreno, 2002^16^
International Agency for Research on Cancer (IARC) Multicentric Case-Control Study | Hammouda, 2005^17^
International BRCA1/2 Carrier Cohort Study | Antoniou, 2009^18^
International BRCA1/2 Carrier Cohort Study | Brohet, 2007^19^
Leiden Thrombophilia Study | Bloemenkamp, 1995^20^
Leiden Thrombophilia Study | Bloemenkamp, 2000^21^
Malignant Ovarian (MALOVA) Cancer Study | Huusom, 2006 22 Soegaard, 2007^23^
Myocardial Infarction Causality (MICA) Study | Dunn, 1999^24^
Myocardial Infarction Causality (MICA) Study | Dunn, 1999^25^
Myocardial Infarction Causality (MICA) Study | Dunn, 2001^26^
Norwegian-Swedish Women's Lifestyle and Health Cohort Study | Kumle, 2004^27^
Norwegian-Swedish Women's Lifestyle and Health Cohort Study | Kumle, 2004^28^
Nurses' Health Study | Hankinson, 1995^29^ | Colditz, 1994^30^
Nurses' Health Study | Grodstein, 1996^31^
Nurses' Health Study | Tworoger, 2007^32^
Oxford Family Planning Association (Oxford-FPA) Contraceptive Study | Mant, 1998^33^
Oxford Family Planning Association (Oxford-FPA) Contraceptive Study | Vessey, 1995^34^
Oxford Family Planning Association (Oxford-FPA) Contraceptive Study | Vessey, 2006^35^
Oxford Family Planning Association (Oxford-FPA) Contraceptive Study | Vessey, 2010^36^ | Vessey, 2003^37^
Risk of Arterial Thrombosis in Relation to Oral Contraceptives (RATIO) Study | Kemmeren, 2002^38^
Risk of Arterial Thrombosis in Relation to Oral Contraceptives (RATIO) Study | Tanis, 2001^39^
Royal College of General Practitioners' Oral Contraceptive Study | Hannaford, 1998^40^
Royal College of General Practitioners' Oral Contraceptive Study | Hannaford, 2007^41^ | Hannaford, 2005^42^
Royal College of General Practitioners' Oral Contraceptive Study | Hannaford, 2010^43^ | Beral, 1999^44^
Shanghai Breast Cancer Study | Fowke, 2004^45^
Shanghai Breast Cancer Study | Xu, 2011^46^
Shanghai Textile Workers Study | Rosenblatt, 2004^47^
Shanghai Textile Workers Study | Rosenblatt, 2009^48^ | Wernli, 2006^49^
Shanghai Textile Workers Study | Gallagher, 2011^50^
Study of Health and Reproduction (SHARE) | Greer, 2005^51^
Study of Health and Reproduction (SHARE) | Greer, 2005^52^
Study of Health and Reproduction (SHARE) | Modugno, 2001^53^ | Ness, 2000^54^ Ness, 2000^55^ Ness, 2001^56^
Study of Health and Reproduction (SHARE) | Ness, 2000^55^ | Ness, 2000^54^ Ness, 2001^56^ Modugno, 2001^53^
Study of Health and Reproduction (SHARE) | Ness, 2001^56^ | Ness, 2000^55^ Modugno, 2001^53^ Ness, 2000^54^
Study of Health and Reproduction (SHARE) | Walker, 2002^57^
Transnational Study on Oral Contraceptives and the Health of Young Women | Heinemann, 1997^58^ | Heinemann, 1998^59^ Spitzer, 1993^60,*^
Transnational Study on Oral Contraceptives and the Health of Young Women | Heinemann, 1999^61^
Transnational Study on Oral Contraceptives and the Health of Young Women | Lewis, 1999^62^ | Lewis, 1996^63^ Lewis, 1996^64^ Lewis, 1997^65^ Lewis, 1999^66^
Transnational Study on Oral Contraceptives and the Health of Young Women | Suissa, 1997^67^ | Spitzer, 1996^68^
Transnational Study on Oral Contraceptives and the Health of Young Women | Suissa, 2000^69^
Women's Environment, Cancer, and Radiation Epidemiology (WECARE) Study | Figueiredo, 2008^70^
Women's Environment, Cancer, and Radiation Epidemiology (WECARE) Study | Figueiredo, 2010^71^
Women's Contraceptive and Reproductive Experiences (CARE) Study | Folger, 2007^72^
Women's Contraceptive and Reproductive Experiences (CARE) Study | Ma, 2010^73^
Women's Contraceptive and Reproductive Experiences (CARE) Study | Marchbanks, 2002^74^ | Marchbanks, 2002^75,*^
Women's Contraceptive and Reproductive Experiences (CARE) Study | Norman, 2003^76^
Women's Contraceptive and Reproductive Experiences (CARE) Study | Marchbanks, 2012^77^ | Marchbanks, 2002^74^
Women's Contraceptive and Reproductive Experiences (CARE) Study | Lu, 2011^78^ (Presents data from both CARE and the California Teachers Study [CTS], analyzed separately)
Women's Learning the Influence of Family and Environment (LIFE) Study | Lee, 2008^79^
Women's Learning the Influence of Family and Environment (LIFE) Study | Ma, 2006^80^
World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception | Anonymous, 1995^81^ | Anonymous, 1995^82,*^
World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception | Anonymous, 1995^83^ | Anonymous, 1995^82,*^
World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception | Anonymous, 1996^84^ | Anonymous, 1995^82,*^
World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception | Anonymous, 1996^85^ | Anonymous, 1995^82,*^
World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception | Anonymous, 1997^86^ | Anonymous, 1995^82,*^
World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception | Anonymous, 1998^87^ | Anonymous, 1995^82,*^
World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception | Chang, 1999^88^ | Anonymous, 1995^82,*^
World Health Organization Collaborative Study of Neoplasia and Steroid Contraceptives | Rosenblatt, 1992^89^
World Health Organization Collaborative Study of Neoplasia and Steroid Contraceptives | Thomas, 1991^90^

* Companion articles marked with an asterisk did not individually meet criteria for inclusion but were considered for supplemental information (e.g., methods data pertinent to an included study).

Table C-2 Primary articles and companion articles grouped by author (study name not applicable)

Author | Primary Abstracted Article | Companion Articles^*^
Althuis, 2003 | Althuis, 2003^91^ | Brinton, 1995^92,*^
Althuis, 2003 | Althuis, 2003^93^ | Brinton, 1995^92,*^
Badawy, 1992 | Badawy, 1992^94^ | Badawy, 1992^95,*^
Chiaffarino, 2001 | Chiaffarino, 2001^96^
Chiaffarino, 2001 | Tavani, 2004^97^
Jick, 2000 | Jick, 2000^98^ | Jick,1995^99^
Jick, 2000 | Farmer, 2000^100^
Le Gal, 2010 | Le Gal, 2010^101^ | Rodger, 2008^102,*^
Legnani, 2002 | Legnani, 2002^103^
Legnani, 2002 | Legnani, 2004^104^
Lidegaard, 2012 | Lidegaard, 2012^105^ | Lidegaard, 2002^106^ Lidegaard, 1998^107^
Lidegaard, 2012 | Lidegaard, 2011^108^ | Lidegaard, 2009^109^
Lidegaard, 2012 | Lidegaard, 2002^110^ | Lidegaard, 1998^111^
Lidegaard, 2012 | Lidegaard, 1998^112^ | Lidegaard, 1999^113^ Lidegaard, 1995^114^ Lidegaard, 1998^107^
Newcomer, 2003 | Newcomer, 2003^115^ | Newcomb, 1994^116,*^
Parazzini, 1991 | Parazzini, 1991^117^
Parazzini, 1991 | Parazzini, 2000^118^
Parazzini, 1991 | Tavani, 2000^119^
Riman, 2001 | Riman, 2001^120^
Riman, 2001 | Riman, 2002^121^
Risch, 1996 | Risch, 1996^122^ | Risch, 1994^123^ Risch, 1994^124,*^
Sanderson, 2000 | Sanderson, 2000^125^
Sanderson, 2000 | Wittenberg, 1999^126^
Siskind, 2000 | Nagle, 2008^127^
Siskind, 2000 | Siskind, 2000^128^ | Purdie, 2001^129^
Tryggvadóttir, 2002 | Tryggvadóttir, 2002^130^ | Tryggvadóttir, 2001^131,*^
Tung, 2003 | Lurie, 2007^132^ | Goodman, 2005^133^ Goodman, 2002^134^
Tung, 2003 | Lurie, 2008^135^
Tung, 2003 | Tung, 2003^136^
Tung, 2003 | Tung, 2005^137^
van Vlijmen, 2007 | van Vlijmen, 2007^138^ | Brouwer, 2006^139,*^
Wang, 2012 | Wang, 2012^140^ | Li, 2006^141^
Wang, 2012 | Li, 2010^142^

* Companion articles marked with an asterisk did not individually meet criteria for inclusion but were considered for supplemental information (e.g., methods data pertinent to an included study).

### References for Study Groupings

1 Gross TP, Schlesselman JJ, Stadel BV, et al. The risk of epithelial ovarian cancer in short-term users of oral contraceptives. Am J Epidemiol. 1992;136(1):46-53. [pmid: 1415131].
2 Gwinn ML, Lee NC, Rhodes PH, et al. Pregnancy, breast feeding, and oral contraceptives and the risk of epithelial ovarian cancer. J Clin Epidemiol. 1990;43(6):559-68. [pmid: 2348208].
3 Maxwell GL, Schildkraut JM, Calingaert B, et al. Progestin and estrogen potency of combination oral contraceptives and endometrial cancer risk. Gynecol Oncol. 2006;103(2):535-40. [pmid: 16740300].
4 Schildkraut JM, Calingaert B, Marchbanks PA, et al. Impact of progestin and estrogen potency in oral contraceptives on ovarian cancer risk. J Natl Cancer Inst. 2002;94(1):32-8. [pmid: 11773280].
5 Harris R, Whittemore AS, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. III. Epithelial tumors of low malignant potential in white women. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1204-11. [pmid: 1476142].
6 Steinberg KK, Smith SJ, Stroup DF, et al. Comparison of effect estimates from a meta-analysis of summary data from published studies and from a meta-analysis using individual patient data for ovarian cancer studies. Am J Epidemiol. 1997;145(10):917-25. [pmid: 9149663].
7 Whittemore AS, Harris R, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. II. Invasive epithelial ovarian cancers in white women. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1184-203. [pmid: 1476141].
8 Whittemore AS, Harris R, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. IV. The pathogenesis of epithelial ovarian cancer. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1212-20. [pmid: 1476143].
9 Whittemore AS, Harris R, Itnyre J, et al. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. I. Methods. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1175-83. [pmid: 1476140].
10 Hartge P, Whittemore AS, Itnyre J, et al. Rates and risks of ovarian cancer in subgroups of white women in the United States. The Collaborative Ovarian Cancer Group. Obstet Gynecol. 1994;84(5):760-4. [pmid: 7936508].
11 Horn-Ross PL, Whittemore AS, Harris R, et al. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 U.S. case-control studies. VI. Nonepithelial cancers among adults. Collaborative Ovarian Cancer Group. Epidemiology. 1992;3(6):490-5. [pmid: 1329996].
12 John EM, Whittemore AS, Harris R, et al. Characteristics relating to ovarian cancer risk: collaborative analysis of seven U.S. case-control studies. Epithelial ovarian cancer in black women. Collaborative Ovarian Cancer Group. J Natl Cancer Inst. 1993;85(2):142-7. [pmid: 8418303].
13 Dossus L, Allen N, Kaaks R, et al. Reproductive risk factors and endometrial cancer: the European Prospective Investigation into Cancer and Nutrition. Int J Cancer. 2010;127(2):442-51. [pmid: 19924816].
14 Tsilidis KK, Allen NE, Key TJ, et al. Oral contraceptives, reproductive history and risk of colorectal cancer in the European Prospective Investigation into Cancer and Nutrition. Br J Cancer. 2010;103(11):1755-9. [pmid: 21045829].
15 Tsilidis KK, Allen NE, Key TJ, et al. Oral contraceptive use and reproductive factors and risk of ovarian cancer in the European Prospective Investigation into Cancer and Nutrition. Br J Cancer. 2011;105(9):1436-42. [pmid: 21915124].
16 Moreno V, Bosch FX, Munoz N, et al. Effect of oral contraceptives on risk of cervical cancer in women with human papillomavirus infection: the IARC multicentric case-control study. Lancet. 2002;359(9312):1085-92. [pmid: 11943255].
17 Hammouda D, Munoz N, Herrero R, et al. Cervical carcinoma in Algiers, Algeria: human papillomavirus and lifestyle risk factors. Int J Cancer. 2005;113(3):483-9. [pmid: 15455386].
18 Antoniou AC, Rookus M, Andrieu N, et al. Reproductive and hormonal factors, and ovarian cancer risk for BRCA1 and BRCA2 mutation carriers: results from the International BRCA1/2 Carrier Cohort Study. Cancer Epidemiol Biomarkers Prev. 2009;18(2):601-10. [pmid: 19190154].
19 Brohet RM, Goldgar DE, Easton DF, et al. Oral contraceptives and breast cancer risk in the international BRCA1/2 carrier cohort study: a report from EMBRACE, GENEPSO, GEO-HEBON, and the IBCCS Collaborating Group. J Clin Oncol. 2007;25(25):3831-6. [pmid: 17635951].
20 Bloemenkamp KW, Rosendaal FR, Helmerhorst FM, et al. Enhancement by factor V Leiden mutation of risk of deep-vein thrombosis associated with oral contraceptives containing a third-generation progestagen. Lancet. 1995;346(8990):1593-6. [pmid: 7500751].
21 Bloemenkamp KW, Rosendaal FR, Helmerhorst FM, et al. Higher risk of venous thrombosis during early use of oral contraceptives in women with inherited clotting defects. Arch Intern Med. 2000;160(1):49-52. [pmid: 10632304].
22 Huusom LD, Frederiksen K, Hogdall EV, et al. Association of reproductive factors, oral contraceptive use and selected lifestyle factors with the risk of ovarian borderline tumors: a Danish case-control study. Cancer Causes Control. 2006;17(6):821-9. [pmid: 16783610].
23 Soegaard M, Jensen A, Hogdall E, et al. Different risk factor profiles for mucinous and nonmucinous ovarian cancer: results from the Danish MALOVA study. Cancer Epidemiol Biomarkers Prev. 2007;16(6):1160-6. [pmid: 17548679].
24 Dunn N, Thorogood M, Faragher B, et al. Oral contraceptives and myocardial infarction: results of the MICA case-control study. BMJ. 1999;318(7198):1579-83. [pmid: 10364115].
25 Dunn NR, Faragher B, Thorogood M, et al. Risk of myocardial infarction in young female smokers. Heart. 1999;82(5):581-3. [pmid: 10525513].
26 Dunn NR, Arscott A, Thorogood M. The relationship between use of oral contraceptives and myocardial infarction in young women with fatal outcome, compared to those who survive: results from the MICA case-control study. Contraception. 2001;63(2):65-9. [pmid: 11292469].
27 Kumle M, Weiderpass E, Braaten T, et al. Risk for invasive and borderline epithelial ovarian neoplasias following use of hormonal contraceptives: the Norwegian-Swedish Women's Lifestyle and Health Cohort Study. Br J Cancer. 2004;90(7):1386-91. [pmid: 15054460].
28 Kumle M, Weiderpass E, Braaten T, et al. Use of oral contraceptives and breast cancer risk: The Norwegian-Swedish Women's Lifestyle and Health Cohort Study. Cancer Epidemiol Biomarkers Prev. 2002;11(11):1375-81. [pmid: 12433714].
29 Hankinson SE, Colditz GA, Hunter DJ, et al. A prospective study of reproductive factors and risk of epithelial ovarian cancer. Cancer. 1995;76(2):284-90. [pmid: 8625104].
30 Colditz GA. Oral contraceptive use and mortality during 12 years of follow-up: the Nurses' Health Study. Ann Intern Med. 1994;120(10):821-6. [pmid: 8154642].
31 Grodstein F, Stampfer MJ, Goldhaber SZ, et al. Prospective study of exogenous hormones and risk of pulmonary embolism in women. Lancet. 1996;348(9033):983-7. [pmid: 8855854].
32 Tworoger SS, Fairfield KM, Colditz GA, et al. Association of oral contraceptive use, other contraceptive methods, and infertility with ovarian cancer risk. Am J Epidemiol. 2007;166(8):894-901. [pmid: 17656616].
33 Mant J, Painter R, Vessey M. Risk of myocardial infarction, angina and stroke in users of oral contraceptives: an updated analysis of a cohort study. Br J Obstet Gynaecol. 1998;105(8):890-6. [pmid: 9746383].
34 Vessey MP, Painter R. Endometrial and ovarian cancer and oral contraceptives--findings in a large cohort study. Br J Cancer. 1995;71(6):1340-2. [pmid: 7779735].
35 Vessey M, Painter R. Oral contraceptive use and cancer. Findings in a large cohort study, 1968-2004. Br J Cancer. 2006;95(3):385-9. [pmid: 16819539].
36 Vessey M, Yeates D, Flynn S. Factors affecting mortality in a large cohort study with special reference to oral contraceptive use. Contraception. 2010;82(3):221-9. [pmid: 20705149].
37 Vessey M, Painter R, Yeates D. Mortality in relation to oral contraceptive use and cigarette smoking. Lancet. 2003;362(9379):185-91. [pmid: 12885478].
38 Kemmeren JM, Tanis BC, van den Bosch MA, et al. Risk of Arterial Thrombosis in Relation to Oral Contraceptives (RATIO) study: oral contraceptives and the risk of ischemic stroke. Stroke. 2002;33(5):1202-8. [pmid: 11988591].
39 Tanis BC, van den Bosch MA, Kemmeren JM, et al. Oral contraceptives and the risk of myocardial infarction. N Engl J Med. 2001;345(25):1787-93. [pmid: 11752354].
40 Hannaford PC, Kay CR. The risk of serious illness among oral contraceptive users: evidence from the RCGP's oral contraceptive study. Br J Gen Pract. 1998;48(435):1657-62. [pmid: 10071398].
41 Hannaford PC, Selvaraj S, Elliott AM, et al. Cancer risk among users of oral contraceptives: cohort data from the Royal College of General Practitioner's oral contraception study. BMJ. 2007;335(7621):651. [pmid: 17855280].
42 Hannaford P, Elliott A. Use of exogenous hormones by women and colorectal cancer: evidence from the Royal College of General Practitioners' Oral Contraception Study. Contraception. 2005;71(2):95-8. [pmid: 15707557].
43 Hannaford PC, Iversen L, Macfarlane TV, et al. Mortality among contraceptive pill users: cohort evidence from Royal College of General Practitioners' Oral Contraception Study. BMJ. 2010;340:c927. [pmid: 20223876].
44 Beral V, Hermon C, Kay C, et al. Mortality associated with oral contraceptive use: 25 year follow up of cohort of 46 000 women from Royal College of General Practitioners' oral contraception study. BMJ. 1999;318(7176):96-100. [pmid: 9880284].
45 Fowke JH, Shu XO, Dai Q, et al. Oral contraceptive use and breast cancer risk: modification by NAD(P)H:quinone oxoreductase (NQO1) genetic polymorphisms. Cancer Epidemiol Biomarkers Prev. 2004;13(8):1308-15. [pmid: 15298951].
46 Xu WH, Shu XO, Long J, et al. Relation of FGFR2 genetic polymorphisms to the association between oral contraceptive use and the risk of breast cancer in Chinese women. Am J Epidemiol. 2011;173(8):923-31. [pmid: 21382839].
47 Rosenblatt KA, Gao DL, Ray RM, et al. Contraceptive methods and induced abortions and their association with the risk of colon cancer in Shanghai, China. Eur J Cancer. 2004;40(4):590-3. [pmid: 14962728].
48 Rosenblatt KA, Gao DL, Ray RM, et al. Oral contraceptives and the risk of all cancers combined and site-specific cancers in Shanghai. Cancer Causes Control. 2009;20(1):27-34. [pmid: 18704712].
49 Wernli KJ, Ray RM, Gao DL, et al. Menstrual and reproductive factors in relation to risk of endometrial cancer in Chinese women. Cancer Causes Control. 2006;17(7):949-55. [pmid: 16841262].
50 Gallagher LG, Davis LB, Ray RM, et al. Reproductive history and mortality from cardiovascular disease among women textile workers in Shanghai, China. Int J Epidemiol. 2011;40(6):1510-8. [pmid: 22158661].
51 Greer JB, Modugno F, Allen GO, et al. Androgenic progestins in oral contraceptives and the risk of epithelial ovarian cancer. Obstet Gynecol. 2005;105(4):731-40. [pmid: 15802398].
52 Greer JB, Modugno F, Allen GO, et al. Short-term oral contraceptive use and the risk of epithelial ovarian cancer. Am J Epidemiol. 2005;162(1):66-72. [pmid: 15961588].
53 Modugno F, Ness RB, Wheeler JE. Reproductive risk factors for epithelial ovarian cancer according to histologic type and invasiveness. Ann Epidemiol. 2001;11(8):568-74. [pmid: 11709277].
54 Ness RB, Grisso JA, Cottreau C, et al. Factors related to inflammation of the ovarian epithelium and risk of ovarian cancer. Epidemiology. 2000;11(2):111-7. [pmid: 11021606].
55 Ness RB, Grisso JA, Klapper J, et al. Risk of ovarian cancer in relation to estrogen and progestin dose and use characteristics of oral contraceptives. SHARE Study Group. Steroid Hormones and Reproductions. Am J Epidemiol. 2000;152(3):233-41. [pmid: 10933270].
56 Ness RB, Grisso JA, Vergona R, et al. Oral contraceptives, other methods of contraception, and risk reduction for ovarian cancer. Epidemiology. 2001;12(3):307-12. [pmid: 11337604].
57 Walker GR, Schlesselman JJ, Ness RB. Family history of cancer, oral contraceptive use, and ovarian cancer risk. Am J Obstet Gynecol. 2002;186(1):8-14. [pmid: 11810077].
58 Heinemann LA, Lewis MA, Thorogood M, et al. Case-control study of oral contraceptives and risk of thromboembolic stroke: results from International Study on Oral Contraceptives and Health of Young Women. BMJ. 1997;315(7121):1502-4. [pmid: 9420491].
59 Heinemann LA, Lewis MA, Spitzer WO, et al. Thromboembolic stroke in young women. A European case-control study on oral contraceptives. Transnational Research Group on Oral Contraceptives and the Health of Young Women. Contraception. 1998;57(1):29-37. [pmid: 9554248].
60 Spitzer WO, Thorogood M, Heinemann L. Trinational Case-Control Study of Oral Contraceptives and Health. Pharmacoepidemiology and drug safety. 1993;2:21-31. PMID:.
61 Heinemann LA, Assmann A, DoMinh T, et al. Oral progestogen-only contraceptives and cardiovascular risk: results from the Transnational Study on Oral Contraceptives and the Health of Young Women. Eur J Contracept Reprod Health Care. 1999;4(2):67-73. [pmid: 10427481].
62 Lewis MA. The Transnational Study on Oral Contraceptives and the Health of Young Women. Methods, results, new analyses and the healthy user effect. Hum Reprod Update. 1999;5(6):707-20. [pmid: 10652980].
63 Lewis MA, Heinemann LA, MacRae KD, et al. The increased risk of venous thromboembolism and the use of third generation progestagens: role of bias in observational research. The Transnational Research Group on Oral Contraceptives and the Health of Young Women. Contraception. 1996;54(1):5-13. [pmid: 8804801].
64 Lewis MA, Spitzer WO, Heinemann LA, et al. Third generation oral contraceptives and risk of myocardial infarction: an international case-control study Transnational Research Group on Oral Contraceptives and the Health of Young Women. BMJ. 1996;312(7023):88-90. [pmid: 8555936].
65 Lewis MA, Heinemann LA, Spitzer WO, et al. The use of oral contraceptives and the occurrence of acute myocardial infarction in young women. Results from the Transnational Study on Oral Contraceptives and the Health of Young Women. Contraception. 1997;56(3):129-40. [pmid: 9347202].
66 Lewis MA, MacRae KD, Kuhl-Habichl D, et al. The differential risk of oral contraceptives: the impact of full exposure history. Hum Reprod. 1999;14(6):1493-9. [pmid: 10359554].
67 Suissa S, Blais L, Spitzer WO, et al. First-time use of newer oral contraceptives and the risk of venous thromboembolism. Contraception. 1997;56(3):141-6. [pmid: 9347203].
68 Spitzer WO, Lewis MA, Heinemann LA, et al. Third generation oral contraceptives and risk of venous thromboembolic disorders: an international case-control study Transnational Research Group on Oral Contraceptives and the Health of Young Women. BMJ. 1996;312(7023):83-8. [pmid: 8555935].
69 Suissa S, Spitzer WO, Rainville B, et al. Recurrent use of newer oral contraceptives and the risk of venous thromboembolism. Hum Reprod. 2000;15(4):817-21. [pmid: 10739826].
70 Figueiredo JC, Bernstein L, Capanu M, et al. Oral contraceptives, postmenopausal hormones, and risk of asynchronous bilateral breast cancer: the WECARE Study Group. J Clin Oncol. 2008;26(9):1411-8. [pmid: 18250348].
71 Figueiredo JC, Haile RW, Bernstein L, et al. Oral contraceptives and postmenopausal hormones and risk of contralateral breast cancer among BRCA1 and BRCA2 mutation carriers and noncarriers: the WECARE Study. Breast Cancer Res Treat. 2010;120(1):175-83. [pmid: 19597986].
72 Folger SG, Marchbanks PA, McDonald JA, et al. Risk of breast cancer associated with short-term use of oral contraceptives. Cancer Causes Control. 2007;18(2):189-98. [pmid: 17216547].
73 Ma H, Wang Y, Sullivan-Halley J, et al. Use of four biomarkers to evaluate the risk of breast cancer subtypes in the women's contraceptive and reproductive experiences study. Cancer Res. 2010;70(2):575-87. [pmid: 20068186].
74 Marchbanks PA, McDonald JA, Wilson HG, et al. Oral contraceptives and the risk of breast cancer. N Engl J Med. 2002;346(26):2025-32. [pmid: 12087137].
75 Marchbanks PA, McDonald JA, Wilson HG, et al. The NICHD Women's Contraceptive and Reproductive Experiences Study: methods and operational results. Ann Epidemiol. 2002;12(4):213-21. [pmid: 11988408].
76 Norman SA, Berlin JA, Weber AL, et al. Combined effect of oral contraceptive use and hormone replacement therapy on breast cancer risk in postmenopausal women. Cancer Causes Control. 2003;14(10):933-43. [pmid: 14750532].
77 Marchbanks PA, Curtis KM, Mandel MG, et al. Oral contraceptive formulation and risk of breast cancer. Contraception. 2012;85(4):342-350. [pmid: 22067757].
78 Lu Y, Ma H, Malone KE, et al. Oral contraceptive use and survival in women with invasive breast cancer. Cancer Epidemiol Biomarkers Prev. 2011;20(7):1391-7. [pmid: 21551244].
79 Lee E, Ma H, McKean-Cowdin R, et al. Effect of reproductive factors and oral contraceptives on breast cancer risk in BRCA1/2 mutation carriers and noncarriers: results from a population-based study. Cancer Epidemiol Biomarkers Prev. 2008;17(11):3170-8. [pmid: 18990759].
80 Ma H, Bernstein L, Ross RK, et al. Hormone-related risk factors for breast cancer in women under age 50 years by estrogen and progesterone receptor status: Results from a case-control and a case-case comparison. Breast Cancer Research. 2006;8(4). PMID:.
81 Anonymous. Venous thromboembolic disease and combined oral contraceptives: results of international multicentre case-control study. World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1995;346(8990):1575-82. [pmid: 7500748].
82 Anonymous. A multinational case-control study of cardiovascular disease and steroid hormone contraceptives Description and validation of methods. World Health Organization Collaborative Study of Cardiovascular and Steroid Hormone Contraception. J Clin Epidemiol. 1995;48(12):1513-47. [pmid: 8543965].
83 Anonymous. Effect of different progestagens in low oestrogen oral contraceptives on venous thromboembolic disease. World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1995;346(8990):1582-8. [pmid: 7500749].
84 Anonymous. Ischaemic stroke and combined oral contraceptives: results of an international, multicentre, case-control study. WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1996;348(9026):498-505. [pmid: 8757151].
85 Anonymous. Haemorrhagic stroke, overall stroke risk, and combined oral contraceptives: results of an international, multicentre, case-control study. WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1996;348(9026):505-10. [pmid: 8757152].
86 Anonymous. Acute myocardial infarction and combined oral contraceptives: results of an international multicentre case-control study. WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. 1997;349(9060):1202-9. [pmid: 9130941].
87 Anonymous. Cardiovascular disease and use of oral and injectable progestogen-only contraceptives and combined injectable contraceptives Results of an international, multicenter, case-control study. World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Contraception. 1998;57(5):315-24. [pmid: 9673838].
88 Chang CL, Donaghy M, Poulter N. Migraine and stroke in young women: case-control study. The World Health Organisation Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. BMJ. 1999;318(7175):13-8. [pmid: 9872876].
89 Rosenblatt KA, Thomas DB, Noonan EA. High-dose and low-dose combined oral contraceptives: protection against epithelial ovarian cancer and the length of the protective effect. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Eur J Cancer. 1992;28A(11):1872-6. [pmid: 1389530].
90 Thomas DB. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives: the influence of combined oral contraceptives on risk of neoplasms in developing and developed countries. Contraception. 1991;43(6):695-710. [pmid: 1868738].
91 Althuis MD, Brogan DR, Coates RJ, et al. Hormonal content and potency of oral contraceptives and breast cancer risk among young women. Br J Cancer. 2003;88(1):50-7. [pmid: 12556959].
92 Brinton LA, Daling JR, Liff JM, et al. Oral contraceptives and breast cancer risk among younger women. J Natl Cancer Inst. 1995;87(11):827-35. [pmid: 7791232].
93 Althuis MD, Brogan DD, Coates RJ, et al. Breast cancers among very young premenopausal women (United States). Cancer Causes Control. 2003;14(2):151-60. [pmid: 12749720].
94 Badawy YA, Bayoumi DM. An epidemiologic study of ovarian cancer. Part 11: Oral contraceptive use and menstrual events. J Egypt Public Health Assoc. 1992;67(5-6):579-91. [pmid: 1294683].
95 Badawy YA, Bayoumi DM. An epidemiologic study of ovarian cancer. Part 1: Reproductive and social factors. J Egypt Public Health Assoc. 1992;67(3-4):465-77. [pmid: 1296973].
96 Chiaffarino F, Pelucchi C, Parazzini F, et al. Reproductive and hormonal factors and ovarian cancer. Ann Oncol. 2001;12(3):337-41. [pmid: 11332145].
97 Tavani A, Bosetti C, Dal Maso L, et al. Influence of selected hormonal and lifestyle factors on familial propensity to ovarian cancer. Gynecol Oncol. 2004;92(3):922-6. [pmid: 14984961].
98 Jick H, Kaye JA, Vasilakis-Scaramozza C, et al. Risk of venous thromboembolism among users of third generation oral contraceptives compared with users of oral contraceptives with levonorgestrel before and after 1995: cohort and case-control analysis. BMJ. 2000;321(7270):1190-5. [pmid: 11073511].
99 Jick H, Jick SS, Gurewich V, et al. Risk of idiopathic cardiovascular death and nonfatal venous thromboembolism in women using oral contraceptives with differing progestagen components. Lancet. 1995;346(8990):1589-93. [pmid: 7500750].
100 Farmer RD, Lawrenson RA, Todd JC, et al. A comparison of the risks of venous thromboembolic disease in association with different combined oral contraceptives. Br J Clin Pharmacol. 2000;49(6):580-90. [pmid: 10848722].
101 Le Gal G, Kovacs MJ, Carrier M, et al. Risk of recurrent venous thromboembolism after a first oestrogen-associated episode. Data from the REVERSE cohort study. Thromb Haemost. 2010;104(3):498-503. [pmid: 20539910].
102 Rodger MA, Kahn SR, Wells PS, et al. Identifying unprovoked thromboembolism patients at low risk for recurrence who can discontinue anticoagulant therapy. CMAJ. 2008;179(5):417-26. [pmid: 18725614].
103 Legnani C, Palareti G, Guazzaloca G, et al. Venous thromboembolism in young women; role of thrombophilic mutations and oral contraceptive use. Eur Heart J. 2002;23(12):984-90. [pmid: 12069454].
104 Legnani C, Cini M, Cosmi B, et al. Risk of deep vein thrombosis: interaction between oral contraceptives and high factor VIII levels. Haematologica. 2004;89(11):1347-51. [pmid: 15531457].
105 Lidegaard O, Lokkegaard E, Jensen A, et al. Thrombotic stroke and myocardial infarction with hormonal contraception. N Engl J Med. 2012;366(24):2257-66. [pmid: 22693997].
106 Lidegaard O, Kreiner S. Contraceptives and cerebral thrombosis: a five-year national case-control study. Contraception. 2002;65(3):197-205. [pmid: 11929641].
107 Lidegaard O, Kreiner S. Cerebral thrombosis and oral contraceptives. A case-control study. Contraception. 1998;57(5):303-14. [pmid: 9673837].
108 Lidegaard O, Nielsen LH, Skovlund CW, et al. Risk of venous thromboembolism from use of oral contraceptives containing different progestogens and oestrogen doses: Danish cohort study, 2001-9. BMJ. 2011;343:d6423. [pmid: 22027398].
109 Lidegaard O, Lokkegaard E, Svendsen AL, et al. Hormonal contraception and risk of venous thromboembolism: national follow-up study. BMJ. 2009;339:b2890. [pmid: 19679613].
110 Lidegaard O, Edstrom B, Kreiner S. Oral contraceptives and venous thromboembolism: a five-year national case-control study. Contraception. 2002;65(3):187-96. [pmid: 11929640].
111 Lidegaard O, Edstrom B, Kreiner S. Oral contraceptives and venous thromboembolism. A case-control study. Contraception. 1998;57(5):291-301. [pmid: 9673836].
112 Lidegaard O. Thrombotic diseases in young women and the influence of oral contraceptives. Am J Obstet Gynecol. 1998;179(3 Pt 2):S62-7. [pmid: 9753312].
113 Lidegaard O. Smoking and use of oral contraceptives: impact on thrombotic diseases. Am J Obstet Gynecol. 1999;180(6 Pt 2):S357-63. [pmid: 10368521].
114 Lidegaard O. Oral contraceptives, pregnancy and the risk of cerebral thromboembolism: the influence of diabetes, hypertension, migraine and previous thrombotic disease. Br J Obstet Gynaecol. 1995;102(2):153-9. [pmid: 7756208].
115 Newcomer LM, Newcomb PA, Trentham-Dietz A, et al. Oral contraceptive use and risk of breast cancer by histologic type. Int J Cancer. 2003;106(6):961-4. [pmid: 12918077].
116 Newcomb PA, Storer BE, Longnecker MP, et al. Lactation and a reduced risk of premenopausal breast cancer. N Engl J Med. 1994;330(2):81-7. [pmid: 8259187].
117 Parazzini F, La Vecchia C, Negri E, et al. Oral contraceptive use and the risk of ovarian cancer: an Italian case-control study. Eur J Cancer. 1991;27(5):594-8. [pmid: 1828969].
118 Parazzini F, Chatenoud L, Chiantera V, et al. Population attributable risk for ovarian cancer. Eur J Cancer. 2000;36(4):520-4. [pmid: 10717530].
119 Tavani A, Ricci E, La Vecchia C, et al. Influence of menstrual and reproductive factors on ovarian cancer risk in women with and without family history of breast or ovarian cancer. Int J Epidemiol. 2000;29(5):799-802. [pmid: 11034959].
120 Riman T, Dickman PW, Nilsson S, et al. Risk factors for epithelial borderline ovarian tumors: results of a Swedish case-control study. Gynecol Oncol. 2001;83(3):575-85. [pmid: 11733975].
121 Riman T, Dickman PW, Nilsson S, et al. Risk factors for invasive epithelial ovarian cancer: results from a Swedish case-control study. Am J Epidemiol. 2002;156(4):363-73. [pmid: 12181107].
122 Risch HA, Marrett LD, Jain M, et al. Differences in risk factors for epithelial ovarian cancer by histologic type. Results of a case-control study. Am J Epidemiol. 1996;144(4):363-72. [pmid: 8712193].
123 Risch HA, Marrett LD, Howe GR. Parity, contraception, infertility, and the risk of epithelial ovarian cancer. Am J Epidemiol. 1994;140(7):585-97. [pmid: 7942759].
124 Risch HA, Jain M, Marrett LD, et al. Dietary lactose intake, lactose intolerance, and the risk of epithelial ovarian cancer in southern Ontario (Canada). Cancer Causes Control. 1994;5(6):540-8. [pmid: 7827241].
125 Sanderson M, Williams MA, Weiss NS, et al. Oral contraceptives and epithelial ovarian cancer. Does dose matter?. J Reprod Med. 2000;45(9):720-6. [pmid: 11027080].
126 Wittenberg J, Cook LS, Rossing MA, et al. Reproductive risk factors for mucinous and non-mucinous epithelial ovarian cancer. Epidemiology. 1999;10(6):761-3. [pmid: 10535792].
127 Nagle CM, Bain CJ, Green AC, et al. The influence of reproductive and hormonal factors on ovarian cancer survival. Int J Gynecol Cancer. 2008;18(3):407-13. [pmid: 17645507].
128 Siskind V, Green A, Bain C, et al. Beyond ovulation: oral contraceptives and epithelial ovarian cancer. Epidemiology. 2000;11(2):106-10. [pmid: 11021605].
129 Purdie DM, Siskind V, Bain CJ, et al. Reproduction-related risk factors for mucinous and nonmucinous epithelial ovarian cancer. Am J Epidemiol. 2001;153(9):860-4. [pmid: 11323316].
130 Tryggvadottir L, Tulinius H, Eyfjord JE, et al. Breast cancer risk factors and age at diagnosis: an Icelandic cohort study. Int J Cancer. 2002;98(4):604-8. [pmid: 11920622].
131 Tryggvadottir L, Tulinius H, Eyfjord JE, et al. Breastfeeding and reduced risk of breast cancer in an Icelandic cohort study. Am J Epidemiol. 2001;154(1):37-42. [pmid: 11427403].
132 Lurie G, Thompson P, McDuffie KE, et al. Association of estrogen and progestin potency of oral contraceptives with ovarian carcinoma risk. Obstet Gynecol. 2007;109(3):597-607. [pmid: 17329510].
133 Goodman MT, Ferrell R, McDuffie K, et al. Calcitonin gene polymorphism CALCA-624 (T/C) and ovarian cancer. Environ Mol Mutagen. 2005;46(1):53-8. [pmid: 15880427].
134 Goodman MT, Wu AH, Tung KH, et al. Association of galactose-1-phosphate uridyltransferase activity and N314D genotype with the risk of ovarian cancer. Am J Epidemiol. 2002;156(8):693-701. [pmid: 12370157].
135 Lurie G, Wilkens LR, Thompson PJ, et al. Combined oral contraceptive use and epithelial ovarian cancer risk: time-related effects. Epidemiology. 2008;19(2):237-43. [pmid: 18223481].
136 Tung KH, Goodman MT, Wu AH, et al. Reproductive factors and epithelial ovarian cancer risk by histologic type: a multiethnic case-control study. Am J Epidemiol. 2003;158(7):629-38. [pmid: 14507598].
137 Tung KH, Wilkens LR, Wu AH, et al. Effect of anovulation factors on pre- and postmenopausal ovarian cancer risk: revisiting the incessant ovulation hypothesis. Am J Epidemiol. 2005;161(4):321-9. [pmid: 15692075].
138 van Vlijmen EF, Brouwer JL, Veeger NJ, et al. Oral contraceptives and the absolute risk of venous thromboembolism in women with single or multiple thrombophilic defects: results from a retrospective family cohort study. Arch Intern Med. 2007;167(3):282-9. [pmid: 17296885].
139 Brouwer JL, Veeger NJ, Kluin-Nelemans HC, et al. The pathogenesis of venous thromboembolism: evidence for multiple interrelated causes. Ann Intern Med. 2006;145(11):807-15. [pmid: 17146065].
140 Wang C, Li Y, Li H, et al. Increased risk of stroke in oral contraceptive users carried replicated genetic variants: a population-based case-control study in China. Hum Genet. 2012. [pmid: 22476622].
141 Li Y, Zhou L, Coulter D, et al. Prospective cohort study of the association between use of low-dose oral contraceptives and stroke in Chinese women. Pharmacoepidemiol Drug Saf. 2006;15(10):726-34. [pmid: 16761299].
142 Li Y, Chen F, Zhou L, et al. COC use, ACE/AGT gene polymorphisms, and risk of stroke. Pharmacogenet Genomics. 2010;20(5):298-306. [pmid: 20300047].