# Data Abstraction Elements

## I Study Characteristics

- Other articles used in this abstraction
- Last Name of First Author
- Publication Year
- Study dates
  ○ Date enrollment started
  ○ Date follow-up ended
- Study site information
  ○ Single center, multicenter, or pooled analysis
  ○ If single center, city and state (U.S.) or city and country (outside U.S.)
  ○ If multicenter
    ■ Number of sites
    ■ Location/ geographic region(s) (Select all that apply)
      - U.S.
      - Canada
      - U.K.
      - Europe
      - S. America
      - Asia
      - Africa
      - Australia/New Zealand
      - Unclear/Not reported
      - Other (specify)
  ○ If pooled analysis, number of studies included
- Funding (Select all that apply)
  ○ Government
  ○ Private
  ○ Foundation
  ○ Industry
  ○ Unclear/Not reported
  ○ Other (specify)
- Indications for OCs (Select all that apply, assume contraception if not otherwise stated)
  ○ Contraception
  ○ Prevention of ovarian cancer
  ○ Other stated indication (specify)
- Outcomes Assessed (Select all that apply)
  ○ Ovarian cancer (Select all that apply)
    ■ Invasive
    ■ Borderline/Low Malignant Potential
    ■ Unclear/Not reported
  ○ Breast cancer
  ○ Colorectal cancer
  ○ Cervical cancer
  ○ Endometrial cancer
  ○ Other cancer (specify)
  ○ Stroke (Select all that apply)
    ■ Hemorrhagic stroke
    ■ Thrombotic stroke
    ■ Unclear/Not reported
  ○ Myocardial infarction
  ○ Deep venous thrombosis
  ○ Pulmonary embolism
- Study design
  ○ Randomized controlled trial (RCT)
  ○ Cohort
  ○ Case-control
  ○ Patient-level pooled analysis (Select design of component studies)
    ■ Case-control
    ■ Cohort
- Comments

## II Cohort Study Details

- Total number of subjects (Enter total N for each category, NR for not reported, or NA for not applicable)
  ○ Number reported as (Select one): Subjects/Person-years
  ○ Record the following for both OCP exposed and OCP non-exposed groups:
    ■ Initially screened
    ■ Enrolled
    ■ Excluded for other specified reason
    ■ Lost to follow-up
    ■ N for analysis
    ■ Source of subjects reported (Yes/NR)
      - If yes, select source
        ○ Hospital
        ○ Population
        ○ Other (specify)
- Subject Age Reported (Yes/NR)
  ○ Record age in years for both OCP exposed and OCP non-exposed groups
    ■ Mean
    ■ Median
    ■ SD
    ■ Min. age
    ■ Max. age
    ■ 25% IQR
    ■ 75% IQR
    ■ Categorical reporting (specify)
    ■ Other (specify)
  ○ p-value between groups
- Subject Race Reported (Yes/NR)
  ○ Record the following for both OCP exposed and OCP non-exposed groups
    ■ American Indian or Alaska Native (N or %)
    ■ Asian (N or %)
    ■ Black or African American (N or %)
    ■ Hispanic (N or %)
    ■ Native Hawaiian or other Pacific Islander (N or %)
    ■ White (N or %)
    ■ Multiracial (N or %)
  ○ p-values between groups
- Medical History
  ○ Record the following for both OCP exposed and OCP non-exposed groups
    ■ Age at menarche reported (Yes/NR)
      - Mean
      - SD
      - Min age
      - Max age
      - Median
      - 25% IQR
      - 75% IQR
      - Categorical reporting (specify)
      - Other (specify)
    ■ Gravidity reported (Yes/NR)
      - Mean
      - SD
      - Min age
      - Max age
      - Median
      - 25% IQR
      - 75% IQR
      - Categorical reporting (specify)
      - Other (specify)
    ■ Parity reported (Yes/NR)
      - Mean
      - SD
      - Min age
      - Max age
      - Median
      - 25% IQR
      - 75% IQR
      - Categorical reporting (specify)
      - Other (specify)
    ■ Menopausal status reported (Yes/NR)
      - Premenopausal (%)
      - Postmenopausal (%)
      - Perimenopausal (%)
      - Unknown
    ■ Breastfeeding reported (Yes/NR)
      - Yes (%)
      - No (%)
    ■ Hysterectomy reported (Yes/NR)
      - Yes
      - No
    ■ Oophorectomy reported (Yes/NR)
      - Yes
      - No
      - Excluded
    ■ Family history of ovarian cancer reported (Yes/NR)
      - Yes
      - No
    ■ BrCA1 status reported (Yes/NR)
      - Positive
      - Negative
    ■ BrCA2 status reported (Yes/NR)
      - Positive
      - Negative
    ■ Other genetic risk factor reported (Yes/NR)
      - Family history of primary outcome
      - Factor V Leiden
      - Other thrombogenic genotype
      - Other genetic risk factor (specify)
  ○ p-values between groups
- Contraception data reported (Yes/NR)
  ○ Non-Oral Contraceptive Group(s)
    ■ Record N and % for the following:
      - Barrier method
      - IUD
      - Injectable/implantable hormones
      - Female sterilization
      - Male sterilization
  ○ Oral Contraceptives
    ■ For each OC type reported, record the following:
      - Estrogen formulation (Select one)
        ○ Estradiol valerate
        ○ Ethinyl estradiol
        ○ Mestranol
        ○ None
      - Estrogen Dose (Select one)
        ○ High
        ○ Low
        ○ Not applicable
      - Progestin formulation (Select one)
        ○ Desogestrel
        ○ Dienogest
        ○ Drospirenone
        ○ Ethynodiol diacetate
        ○ Levonorgestrel
        ○ Norethindrone
        ○ Norethindrone diacetate
        ○ Norgestimate
        ○ Norgestrel
      - Progestin Generation (Select one)
        ○ 1
        ○ 2
        ○ 3
        ○ 4
        ○ Unclear/Not Reported
      - Progestin Dose (Select one)
        ○ High
        ○ Low
        ○ Not applicable
      - N and % of subjects using this type of OC
    ■ Duration of OC use (record the following, if reported):
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
    ■ Ages OCs used (record the following, if reported):
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
    ■ Time since last OC use & assessment of outcome status (record the following, if reported):
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
    ■ Pattern of OC use (record the following, if reported):
      - Number of episodes of use
      - Number of continuous months
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
    ■ Number of months between OC uses (record the following, if reported):
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
- Comments

## III Case-Control Study Details

- Total number of subjects (Enter total N for each category, NR for not reported, or NA for not applicable)
  ○ Number reported as (Select one): Subjects/Person-years
  ○ Record the following for both cases and controls:
    ■ Initially screened
    ■ Declined to participate
    ■ Excluded based on criteria
    ■ N for analysis
    ■ Source of subjects reported (Yes/NR)
      - If yes, select source
        ○ Hospital
        ○ Population
        ○ Other (specify)
- Subject Age Reported (Yes/NR)
  ○ Record age in years for both cases and controls
    ■ Mean
    ■ Median
    ■ SD
    ■ Min. age
    ■ Max. age
    ■ 25% IQR
    ■ 75% IQR
    ■ Categorical reporting (specify)
    ■ Other (specify)
  ○ p-value between groups
- Subject Race Reported (Yes/NR)
  ○ Record the following for both cases and controls
    ■ American Indian or Alaska Native (N or %)
    ■ Asian (N or %)
    ■ Black or African American (N or %)
    ■ Hispanic (N or %)
    ■ Native Hawaiian or other Pacific Islander (N or %)
    ■ White (N or %)
    ■ Multiracial (N or %)
  ○ p-values between groups
- Medical History
  ○ Record the following for both cases and controls
    ■ Age at menarche reported (Yes/NR)
      - Mean
      - SD
      - Min age
      - Max age
      - Median
      - 25% IQR
      - 75% IQR
      - Categorical reporting (specify)
      - Other (specify)
    ■ Gravidity reported (Yes/NR)
      - Mean
      - SD
      - Min age
      - Max age
      - Median
      - 25% IQR
      - 75% IQR
      - Categorical reporting (specify)
      - Other (specify)
    ■ Parity reported (Yes/NR)
      - Mean
      - SD
      - Min age
      - Max age
      - Median
      - 25% IQR
      - 75% IQR
      - Categorical reporting (specify)
      - Other (specify)
    ■ Menopausal status reported (Yes/NR)
      - Premenopausal (%)
      - Postmenopausal (%)
      - Perimenopausal (%)
      - Unknown
    ■ Breastfeeding reported (Yes/NR)
      - Yes (%)
      - No (%)
    ■ Hysterectomy reported (Yes/NR)
      - Yes
      - No
    ■ Oophorectomy reported (Yes/NR)
      - Yes
      - No
      - Excluded
    ■ Family history of ovarian cancer reported (Yes/NR)
      - Yes
      - No
    ■ BrCA1 status reported (Yes/NR)
      - Positive
      - Negative
    ■ BrCA2 status reported (Yes/NR)
      - Positive
      - Negative
    ■ Other genetic risk factor reported (Yes/NR)
      - Family history of primary outcome
      - Factor V Leiden
      - Other thrombogenic genotype
      - Other genetic risk factor (specify)
  ○ p-values between groups
- Contraception data reported (Yes/NR)
  ○ Record the following for both cases and controls:
    ■ Record N and % of subjects utilizing the following non-OC contraceptive methods:
      - Barrier method
      - IUD
      - Injectable/implantable hormones
      - Female sterilization
      - Male sterilization
    ■ Oral Contraceptives
      - For each OC type reported, record the following:
        ○ Estrogen formulation (Select one)
          ■ Estradiol valerate
          ■ Ethinyl estradiol
          ■ Mestranol
          ■ None
        ○ Estrogen Dose (Select one)
          ■ High
          ■ Low
          ■ Not applicable
        ○ Progestin formulation (Select one)
          ■ Desogestrel
          ■ Dienogest
          ■ Drospirenone
          ■ Ethynodiol diacetate
          ■ Levonorgestrel
          ■ Norethindrone
          ■ Norethindrone diacetate
          ■ Norgestimate
          ■ Norgestrel
        ○ Progestin Generation (Select one)
          ■ 1
          ■ 2
          ■ 3
          ■ 4
          ■ Unclear/Not Reported
        ○ Progestin Dose (Select one)
          ■ High
          ■ Low
          ■ Not applicable
        ○ N and % of subjects using this type of OC
    ■ Duration of OC use (record the following, if reported):
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
    ■ Ages OCs used (record the following, if reported):
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
    ■ Time since last OC use & assessment of outcome status (record the following, if reported):
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
    ■ Pattern of OC use (record the following, if reported):
      - Number of episodes of use
      - Number of continuous months
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
    ■ Number of months between OC uses (record the following, if reported):
      - Minimum
      - Maximum
      - Mean
      - Median
      - SD
      - p-value
      - Categorical reporting (specify)
- Comments

## IV Outcomes Reporting Form

- Select outcome being reported
  ○ Ovarian Cancer
  ○ Breast Cancer
  ○ Colorectal Cancer
  ○ Cervical Cancer
  ○ Endometrial Cancer
  ○ Deep venous thrombosis
  ○ Pulmonary embolus
  ○ Stroke
  ○ Myocardial infarction
  ○ Is this data for disease incidence or disease-specific mortality?
    ■ Incidence
    ■ Disease-specific mortality
  ○ Is this data for a special population (Yes/No)
    ■ If yes, indicate the population
  ○ Is this data for a subgroup of the overall study population (Yes/No)
    ■ If yes, indicate the subgroup population
- For this outcome
  ○ Enter N analyzed for cases or OC exposed group
  ○ Enter N analyzed for controls or OC non-exposed group
  ○ Record the following data for OC ever use
    ■ Crude OR and 95% CI
    ■ Adjusted OR and 95% CI
      - Indicate adjustment factors:
        ○ Age
        ○ Race
        ○ Parity
        ○ Menopausal status
        ○ BMI
        ○ Family History
        ○ Age at menarche
        ○ Smoking
        ○ Breastfeeding
        ○ Other (specify)
  ○ Data reported by OC duration (Yes/NR)
    ■ Does this data represent recency of use (Yes/No)
    ■ Record the following for all duration categories reported:
      - Crude OR and 95% CI
      - Adjusted OR and 95% CI
        ○ Indicate adjustment factors:
          ■ Age
          ■ Race
          ■ Parity
          ■ Menopausal status
          ■ BMI
          ■ Family History
          ■ Age at menarche
          ■ Smoking
          ■ Breastfeeding
          ■ Other (specify)
  ○ Data reported by age at first use (Yes/NR)
    ■ Record the following for all categories reported:
      - Crude OR and 95% CI
      - Adjusted OR and 95% CI
        ○ Indicate adjustment factors:
          ■ Age
          ■ Race
          ■ Parity
          ■ Menopausal status
          ■ BMI
          ■ Family History
          ■ Age at menarche
          ■ Smoking
          ■ Breastfeeding
          ■ Other (specify)
  ○ Data reported by age at last use (Yes/NR)
    ■ Record the following for all categories reported:
      - Crude OR and 95% CI
      - Adjusted OR and 95% CI
        ○ Indicate adjustment factors:
          ■ Age
          ■ Race
          ■ Parity
          ■ Menopausal status
          ■ BMI
          ■ Family History
          ■ Age at menarche
          ■ Smoking
          ■ Breastfeeding
          ■ Other (specify)
  ○ Data reported by formulation (Yes/NR)
    ■ Record the following for all categories reported:
      - Crude OR and 95% CI
      - Adjusted OR and 95% CI
        ○ Indicate adjustment factors:
          ■ Age
          ■ Race
          ■ Parity
          ■ Menopausal status
          ■ BMI
          ■ Family History
          ■ Age at menarche
          ■ Smoking
          ■ Breastfeeding
          ■ Other (specify)
  ○ Subgroup/Stratified Analyses performed? (Yes/No)
  ○ Stratification Variables
    ■ Age
    ■ Race
    ■ Parity
    ■ Menopausal status
    ■ BMI
    ■ Family history
    ■ Other (specify)
- Comments

## V Cohort Studies Quality Assessment

- Selection Bias
  ○ Was there any attempt to balance the allocation between the groups? (Yes/No/Unclear)
  ○ Did the study apply inclusion/exclusion criteria uniformly to all comparison groups? (Yes/No/Unclear)
  ○ Is the selection of the comparison group appropriate? (Yes/No/Unclear)
  ○ Did the strategy for recruiting participants into the study differ across study groups? (Yes/No/Unclear)
  ○ Are baseline characteristics similar between groups? If not, did the analysis control for differences? (Yes/No/Unclear)
  ○ Does the design or analysis control account for important confounding and modifying variables? (Yes/No/Unclear)
- Performance Bias
  ○ Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
  ○ Did variation from the study protocol compromise the conclusions of the study?
- Attrition Bias
  ○ Is the length of follow-up different between the groups?
  ○ Was there a high rate of differential or overall attrition?
  ○ Is the analysis conducted on an intention-to-treat (ITT) basis?
- Detection Bias
  ○ Were the outcome assessors blinded to the intervention or exposure status of participants?
  ○ Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants?
  ○ Are interventions/exposures assessed using valid and reliable measures, implemented consistently across all study participants?
  ○ Are primary outcomes assessed using valid and reliable measures, implemented consistently across all study participants?
  ○ Are confounding variables assessed using valid and reliable measures, implemented consistently across all study participants?
- Reporting Bias
  ○ Are the potential outcomes pre-specified by the researchers? Are all pre-specified outcomes reported?
- Record any additional comments relating to potential sources of bias or other study limitations.
- Summary Quality Rating
  ○ Good
  ○ Fair
  ○ Poor
  ○ If the study is rated as “Fair” or “Poor,” provide rationale for decision.

## VI Case-Control Studies Quality Assessment

- Selection Bias
  ○ Did the study apply inclusion/exclusion criteria uniformly to all comparison groups? (Yes/No/Unclear)
  ○ Is the selection of the comparison group appropriate? (Yes/No/Unclear)
  ○ Does the design or analysis control account for important confounding and modifying variables? (Yes/No/Unclear)
- Performance Bias
  ○ Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
  ○ Did variation from the study protocol compromise the conclusions of the study?
- Detection Bias
  ○ Were the outcome assessors blinded to the intervention or exposure status of participants?
  ○ Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants?
  ○ Are interventions/exposures assessed using valid and reliable measures, implemented consistently across all study participants?
  ○ Are primary outcomes assessed using valid and reliable measures, implemented consistently across all study participants?
  ○ Are confounding variables assessed using valid and reliable measures, implemented consistently across all study participants?
- Reporting Bias
  ○ Are the potential outcomes pre-specified by the researchers? Are all pre-specified outcomes reported?
- Record any additional comments relating to potential sources of bias or other study limitations.
- Summary Quality Rating
  ○ Good
  ○ Fair
  ○ Poor
  ○ If the study is rated as “Fair” or “Poor,” provide rationale for decision.

## VII Cohort Applicability Assessment

- Population (P)
  ○ Age at OC use
    ■ At least 25% of study population age 35 years or older
    ■ <25% of study population age 35 or older
  ○ Baseline risk for ovarian cancer
    ■ Risk factors described (e.g., family history)
    ■ Risk factors not described
- Intervention (I)
  ○ OC formulation
    ■ Currently available in U.S.
    ■ Not currently available in U.S.
    ■ NR
- Comparator (C)
  ○ Other contraceptive
    ■ Currently available in U.S.
    ■ Not currently available in U.S.
    ■ NR
- Setting (S)
  ○ Location
    ■ U.S.
    ■ Non-U.S.

## VIII Case-Control Applicability Assessment

- Population (P)
  ○ Age at OC use
    ■ At least 25% of study population age 35 years or older
    ■ <25% of study population age 35 or older
  ○ Baseline risk for ovarian cancer
    ■ Risk factors described (e.g., family history)
    ■ Risk factors not described
- Intervention (I)
  ○ OC formulation
    ■ Currently available in U.S.
    ■ Not currently available in U.S.
    ■ NR
- Comparator (C)
  ○ Other contraceptive
    ■ Currently available in U.S.
    ■ Not currently available in U.S.
    ■ NR
- Setting (S)
  ○ Location
    ■ U.S.
    ■ Non-U.S.