# Exact Search Strings

## PubMed^®^ search strategy (June 29, 2012)

((((“contraceptive agents, female”[MeSH Terms] OR (“contraceptive”[All Fields] AND “agents”[All Fields] AND “female”[All Fields]) OR “female contraceptive agents”[All Fields] OR (“female”[All Fields] AND “contraceptive”[All Fields] AND “agents”[All Fields]) OR “contraceptive agents, female”[Pharmacological Action]) OR (“contraceptives, oral”[MeSH Terms] OR (“contraceptives”[All Fields] AND “oral”[All Fields]) OR “oral contraceptives”[All Fields] OR (“oral”[All Fields] AND “contraceptives”[All Fields]) OR “contraceptives, oral”[Pharmacological Action])) AND ((“ovarian neoplasms”[MeSH Terms] OR (“ovarian”[All Fields] AND “neoplasms”[All Fields]) OR “ovarian neoplasms”[All Fields] OR (“ovarian”[All Fields] AND “cancer”[All Fields]) OR “ovarian cancer”[All Fields]) OR (“granulosa cell tumour”[All Fields] OR “granulosa cell tumor”[MeSH Terms] OR (“granulosa”[All Fields] AND “cell”[All Fields] AND “tumor”[All Fields]) OR “granulosa cell tumor”[All Fields]) OR (“luteoma”[MeSH Terms] OR “luteoma”[All Fields]) OR (“meigs syndrome”[MeSH Terms] OR (“meigs”[All Fields] AND “syndrome”[All Fields]) OR “meigs syndrome”[All Fields]) OR (“sertoli leydig cell tumour”[All Fields] OR “sertoli-leydig cell tumor”[MeSH Terms] OR (“sertoli-leydig”[All Fields] AND “cell”[All Fields] AND “tumor”[All Fields]) OR “sertoli-leydig cell tumor”[All Fields] OR (“sertoli”[All Fields] AND “leydig”[All Fields] AND “cell”[All Fields] AND “tumor”[All Fields]) OR “sertoli leydig cell tumor”[All Fields] OR “Sertoli-Leydig Cell Tumor”[MeSH Terms] OR (“Sertoli-Leydig”[All Fields] AND “Cell”[All Fields] AND “Tumor”[All Fields]) OR “Sertoli-Leydig Cell Tumor”[All Fields] OR (“sertoli”[All Fields] AND “leydig”[All Fields] AND “cell”[All Fields] AND “tumor”[All Fields]) OR “sertoli leydig cell tumor”[All Fields] OR “Sertoli Leydig Cell Tumor”[MeSH Terms] OR (“Sertoli”[All Fields] AND “Leydig”[All Fields] AND “Cell”[All Fields] AND “Tumor”[All Fields]) OR “Sertoli Leydig Cell Tumor”[All Fields] OR (“sertoli”[All Fields] AND “leydig”[All Fields] AND “cell”[All Fields] AND “tumor”[All Fields])) OR (“thecoma”[MeSH Terms] OR “thecoma”[All Fields]) OR “ovarian cysts”[MeSH Terms:noexp] OR (“pregnancy”[MeSH Terms] OR “pregnancy”[All Fields]) OR (“venous thrombosis”[MeSH Terms] OR (“venous”[All Fields] AND “thrombosis”[All Fields]) OR “venous thrombosis”[All Fields] OR (“deep”[All Fields] AND “vein”[All Fields] AND “thrombosis”[All Fields]) OR “deep vein thrombosis”[All Fields]) OR DVT[All Fields] OR (“budd-chiari syndrome”[MeSH Terms] OR (“budd-chiari”[All Fields] AND “syndrome”[All Fields]) OR “budd-chiari syndrome”[All Fields] OR (“budd”[All Fields] AND “chiari”[All Fields] AND “syndrome”[All Fields]) OR “budd chiari syndrome”[All Fields]) OR (“retinal vein occlusion”[MeSH Terms] OR (“retinal”[All Fields] AND “vein”[All Fields] AND “occlusion”[All Fields]) OR “retinal vein occlusion”[All Fields]) OR (“thrombophlebitis”[MeSH Terms] OR “thrombophlebitis”[All Fields]) OR (“venous thromboembolism”[MeSH Terms] OR (“venous”[All Fields] AND “thromboembolism”[All Fields]) OR “venous thromboembolism”[All Fields]) OR ((“veins”[MeSH Terms] OR “veins”[All Fields] OR “venous”[All Fields]) AND (“thromboembolism”[MeSH Terms] OR “thromboembolism”[All Fields] OR (“thromboembolic”[All Fields] AND “event”[All Fields]) OR “thromboembolic event”[All Fields])) OR VTE[All Fields] OR (“cerebrovascular disorders”[MeSH Terms] OR (“cerebrovascular”[All Fields] AND “disorders”[All Fields]) OR “cerebrovascular disorders”[All Fields]) OR (“stroke”[MeSH Terms] OR “stroke”[All Fields]) OR (((“brain”[MeSH Terms] OR “brain”[All Fields]) OR (“cerebrum”[MeSH Terms] OR “cerebrum”[All Fields] OR “cerebral”[All Fields] OR “brain”[MeSH Terms] OR “brain”[All Fields])) AND ((“infarction”[MeSH Terms] OR “infarction”[All Fields]) OR (“ischaemia”[All Fields] OR “ischemia”[MeSH Terms] OR “ischemia”[All Fields]) OR (“embolism”[MeSH Terms] OR “embolism”[All Fields]) OR (“thrombosis”[MeSH Terms] OR “thrombosis”[All Fields]))) OR (“meningioma”[MeSH Terms] OR “meningioma”[All Fields]) OR (“melanoma”[MeSH Terms] OR “melanoma”[All Fields]) OR (“breast neoplasms”[MeSH Terms] OR (“breast”[All Fields] AND “neoplasms”[All Fields]) OR “breast neoplasms”[All Fields] OR (“breast”[All Fields] AND “cancer”[All Fields]) OR “breast cancer”[All Fields]) OR (“uterine neoplasms”[MeSH Terms] OR (“uterine”[All Fields] AND “neoplasms”[All Fields]) OR “uterine neoplasms”[All Fields]) OR (“uterine cervical neoplasms”[MeSH Terms] OR (“uterine”[All Fields] AND “cervical”[All Fields] AND “neoplasms”[All Fields]) OR “uterine cervical neoplasms”[All Fields] OR (“cervical”[All Fields] AND “cancer”[All Fields]) OR “cervical cancer”[All Fields]) OR (“endometrial neoplasms”[MeSH Terms] OR (“endometrial”[All Fields] AND “neoplasms”[All Fields]) OR “endometrial neoplasms”[All Fields] OR (“endometrial”[All Fields] AND “cancer”[All Fields]) OR “endometrial cancer”[All Fields]) OR (“endometriosis”[MeSH Terms] OR “endometriosis”[All Fields]) OR (“endometrial hyperplasia”[MeSH Terms] OR (“endometrial”[All Fields] AND “hyperplasia”[All Fields]) OR “endometrial hyperplasia”[All Fields]) OR (“metrorrhagia”[MeSH Terms] OR “metrorrhagia”[All Fields] OR (“dysfunctional”[All Fields] AND “uterine”[All Fields] AND “bleeding”[All Fields]) OR “dysfunctional uterine bleeding”[All Fields]) OR (“metrorrhagia”[MeSH Terms] OR “metrorrhagia”[All Fields]) OR (“menorrhagia”[MeSH Terms] OR “menorrhagia”[All Fields]) OR (“hypermenorrhoea”[All Fields] OR “menorrhagia”[MeSH Terms] OR “menorrhagia”[All Fields] OR “hypermenorrhea”[All Fields]) OR (“menstruation disturbances”[MeSH Terms] OR (“menstruation”[All Fields] AND “disturbances”[All Fields]) OR “menstruation disturbances”[All Fields]) OR (“amenorrhoea”[All Fields] OR “amenorrhea”[MeSH Terms] OR “amenorrhea”[All Fields]) OR (“dysmenorrhoea”[All Fields] OR “dysmenorrhea”[MeSH Terms] OR “dysmenorrhea”[All Fields]) OR “painful menstruation”[All Fields] OR “menstrual pain”[All Fields] OR (“oligomenorrhoea”[All Fields] OR “oligomenorrhea”[MeSH Terms] OR “oligomenorrhea”[All Fields]) OR (“premenstrual syndrome”[MeSH Terms] OR (“premenstrual”[All Fields] AND “syndrome”[All Fields]) OR “premenstrual syndrome”[All Fields]) OR PMS[All Fields] OR “premenstrual dysphoric disorder”[All Fields] OR PMDD[All Fields] OR (“uterine haemorrhage”[All Fields] OR “uterine hemorrhage”[MeSH Terms] OR (“uterine”[All Fields] AND “hemorrhage”[All Fields]) OR “uterine hemorrhage”[All Fields]) OR “uterine bleeding”[All Fields] OR (“acne vulgaris”[MeSH Terms] OR (“acne”[All Fields] AND “vulgaris”[All Fields]) OR “acne vulgaris”[All Fields] OR “acne”[All Fields]) OR (“colorectal neoplasms”[MeSH Terms] OR (“colorectal”[All Fields] AND “neoplasms”[All Fields]) OR “colorectal neoplasms”[All Fields] OR (“colorectal”[All Fields] AND “cancer”[All Fields]) OR “colorectal cancer”[All Fields]) OR (“colonic neoplasms”[MeSH Terms] OR (“colonic”[All Fields] AND “neoplasms”[All Fields]) OR “colonic neoplasms”[All Fields] OR (“colon”[All Fields] AND “cancer”[All Fields]) OR “colon cancer”[All Fields]) OR (“rectal neoplasms”[MeSH Terms] OR (“rectal”[All Fields] AND “neoplasms”[All Fields]) OR “rectal neoplasms”[All Fields] OR (“rectal”[All Fields] AND “cancer”[All Fields]) OR “rectal cancer”[All Fields]) OR (“anus neoplasms”[MeSH Terms] OR (“anus”[All Fields] AND “neoplasms”[All Fields]) OR “anus neoplasms”[All Fields] OR (“anus”[All Fields] AND “cancer”[All Fields]) OR “anus cancer”[All Fields]) OR (“myocardial infarction”[MeSH Terms] OR (“myocardial”[All Fields] AND “infarction”[All Fields]) OR “myocardial infarction”[All Fields] OR (“heart”[All Fields] AND “attack”[All Fields]) OR “heart attack”[All Fields]) OR (“myocardial infarction”[MeSH Terms] OR (“myocardial”[All Fields] AND “infarction”[All Fields]) OR “myocardial infarction”[All Fields]) OR (“liver neoplasms”[MeSH Terms] OR (“liver”[All Fields] AND “neoplasms”[All Fields]) OR “liver neoplasms”[All Fields] OR (“liver”[All Fields] AND “cancer”[All Fields]) OR “liver cancer”[All Fields]) OR (“mortality”[Subheading] OR “mortality”[All Fields] OR “mortality”[MeSH Terms]) OR (“mortality”[Subheading] OR “mortality”[All Fields] OR (“death”[All Fields] AND “rate”[All Fields]) OR “death rate”[All Fields] OR “mortality”[MeSH Terms] OR (“death”[All Fields] AND “rate”[All Fields]) OR “death rate”[All Fields]) OR (“survival rate”[MeSH Terms] OR (“survival”[All Fields] AND “rate”[All Fields]) OR “survival rate”[All Fields]) OR (“survival analysis”[MeSH Terms] OR (“survival”[All Fields] AND “analysis”[All Fields]) OR “survival analysis”[All Fields]) OR (“fatal outcome”[MeSH Terms] OR (“fatal”[All Fields] AND “outcome”[All Fields]) OR “fatal outcome”[All Fields]) OR (“life expectancy”[MeSH Terms] OR (“life”[All Fields] AND “expectancy”[All Fields]) OR “life expectancy”[All Fields])) AND (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR placebo[tiab] OR “clinical trials as topic”[MeSH Terms:noexp] OR randomly[tiab] OR trial[ti] OR (“cohort studies”[MeSH Terms] OR (“cohort”[All Fields] AND “studies”[All Fields]) OR “cohort studies”[All Fields] OR (“cohort”[All Fields] AND “study”[All Fields]) OR “cohort study”[All Fields]) OR cohort[All Fields] OR longitudinal[All Fields] OR “follow up”[All Fields] OR “prospective”[All Fields] OR (“case-control studies”[MeSH Terms] OR (“case-control”[All Fields] AND “studies”[All Fields]) OR “case-control studies”[All Fields] OR (“case”[All Fields] AND “control”[All Fields] AND “study”[All Fields]) OR “case control study”[All Fields]) OR (“case-control studies”[MeSH Terms] OR (“case-control”[All Fields] AND “studies”[All Fields]) OR “case-control studies”[All Fields] OR (“case”[All Fields] AND “control”[All Fields] AND “studies”[All Fields]) OR “case control studies”[All Fields]) OR systematic[sb])) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp])) NOT (“animals”[MeSH Terms] NOT “humans”[MeSH Terms]) AND (English[lang] AND (“1990”[PDAT] : “3000”[PDAT]))

## Embase^®^ search strategy (June 29, 2012)

Platform: Embase.com

[embase]/lim NOT [medline]/lim AND (‘oral contraceptive agent’/exp OR ‘oral contraceptives’) AND (‘ovary tumor’/exp OR ‘ovarian cancer’:ti OR ‘ovarian cancer’:ab OR ‘granulosa cell tumor’:ti OR ‘granulosa cell tumor’:ab OR dysgerminoma:ti OR dysgerminoma:ab OR ‘meigs syndrome’:ti OR ‘meigs syndrome’:ab OR luteoma:ti OR luteoma:ab OR ‘androblastoma’/exp OR ‘sertoli-leydig cell tumor’:ti OR ‘sertoli-leydig cell tumor’:ab OR thecoma:ti OR thecoma:ab OR ‘ovary cyst’/de OR ‘ovarian cyst’:ti OR ‘ovarian cyst’:ab OR ‘pregnancy’/exp OR pregnancy:ti OR pregnancy:ab OR ‘vein thrombosis’/exp OR ‘venous thrombosis’:ti OR ‘venous thrombosis’:ab OR ‘deep vein thrombosis’:ti OR ‘deep vein thrombosis’:ab OR dvt:ti OR dvt:ab OR ‘budd chiari syndrome’/exp OR ‘budd chiari syndrome’:ti OR ‘budd chiari syndrome’:ab OR ‘vein occlusion’/exp OR ‘retinal vein occlusion’:ti OR ‘retinal vein occlusion’:ab OR thrombophlebitis:ti OR thrombophelbitis:ab OR ‘venous thromboembolism’/exp OR ‘venous thromboembolism’:ti OR ‘venous thromboembolism’:ab OR ‘venous thromboembolic event’:ti OR ‘venous thromboembolic event’:ab OR vte:ti OR vte:ab OR ‘cerebrovascular disease’/exp OR stroke:ti OR stroke:ab OR (brain:ti OR brain:ab OR cerebral:ti OR cerebral:ab AND (infarction:ti OR infarction:ab OR ischemia:ti OR ischemia:ab OR embolism:ti OR embolism:ab OR thrombosis:ti OR thrombosis:ab OR hemorrhage:ti OR hemorrhage:ab OR hematoma:ti OR hematoma:ab)) OR ‘meningioma’/exp OR meningioma:ti OR meningioma:ab OR ‘melanoma’/exp OR melanoma:ti OR melanoma:ab OR ‘breast cancer’/exp OR ‘breast cancer’:ti OR ‘breast cancer’:ab OR ‘uterus cancer’/exp OR ‘uterine cancer’:ti OR ‘uterine cancer’:ab OR ‘uterine cervix cancer’/exp OR ‘cervical cancer’:ti OR ‘cervical cancer’:ab OR ‘endometrium cancer’/exp OR ‘endometrial cancer’:ti OR ‘endometrial cancer’:ab OR ‘endometriosis’/exp OR endometriosis:ti OR endometriosis:ab OR ‘endometrium hyperplasia’/exp OR ‘endometrial hyperplasia’:ti OR ‘endometrial hyperplasia’:ab OR menorrhagia:ti OR menorrhagia:ab OR metrorrhagia:ti OR metrorrhagia:ab OR hypermenorrhea:ti OR hypermenorrhea:ab OR ‘dysfunctional uterine bleeding’:ti OR ‘dysfunctional uterine bleeding’:ab OR ‘menstruation disorder’/exp OR amenorrhea:ti OR amenorrhea:ab OR oligomenorrhea:ti OR oligomenorrhea:ab OR dysmenorrhea:ti OR dysmenorrhea:ab OR ‘premenstrual dysphoric disorder’:ti OR ‘premenstrual dysphoric disorder’:ab OR pmdd:ti OR pmdd:ab OR ‘premenstrual syndrome’:ti OR ‘premenstrual syndrome’:ab OR pms:ti OR pms:ab OR ‘painful menstruation’:ti OR ‘painful menstruation’:ab OR ‘menstrual pain’:ti OR ‘menstrual pain’:ab OR ‘uterus bleeding’/exp OR ‘uterine hemorrhage’:ti OR ‘uterine hemorrhage’:ab OR ‘uterine bleeding’:ti OR ‘uterine bleeding’:ab OR ‘acne’/exp OR acne:ti OR acne:ab OR ‘colon cancer’/exp OR ‘colon cancer’:ti OR ‘colon cancer’:ab OR ‘colorectal cancer’:ti OR ‘colorectal cancer’:ab OR ‘rectum cancer’/exp OR ‘rectal cancer’:ti OR ‘rectal cancer’:ab OR ‘anus cancer’/exp OR ‘anus cancer’:ti OR ‘anus cancer’:ab OR ‘anal cancer’:ti OR ‘anal cancer’:ab OR ‘heart infarction’/exp OR ‘heart attack’:ti OR ‘heart attack’:ab OR ‘myocardial infarction’:ti OR ‘myocardial infarction’:ab OR ‘liver cancer’/exp OR ‘liver cancer’:ti OR ‘liver cancer’:ab OR ‘mortality’/exp OR mortality:ti OR mortality:ab OR ‘death rate’:ti OR ‘death rate’:ab OR ‘survival’/exp OR survival:ti OR survival:ab OR ‘fatality’/exp OR fatality:ti OR fatality:ab OR ‘life expectancy’:ti OR ‘life expectancy’:ab OR ‘life expectancy’/exp) AND (‘controlled study’/exp OR ‘randomized controlled trial’:ti OR ‘randomized controlled trial’:ab OR randomized:ti OR randomized:ab OR placebo:ti OR placebo:ab OR randomly:ti OR randomly:ab OR trial:ti OR ‘cohort analysis’/exp OR ‘controlled clinical trial’/exp OR ‘case control study’/exp OR ‘intervention study’/exp OR ‘longitudinal study’/exp OR ‘prospective study’/exp OR ‘cohort study’:ti OR ‘cohort study’:ab OR longitudinal:ti OR longitudinal:ab OR ‘follow up’:ti OR ‘follow up’:ab OR prospective:ti OR prospective:ab OR ‘case control’:ti OR ‘case control’:ab OR ‘systematic review’/exp OR ‘meta analysis’/exp) NOT ‘case report’/exp AND [humans]/lim AND [english]/lim AND [1990-2011]/py

## Cochrane search strategy (June 29, 2012)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews

Oral contraceptives [in title-abstract-keywords]

## ClinicalTrials.gov search strategy (December 15, 2012)

Platform: www.clinicaltrials.gov

Search #1:

- Intervention: oral contraceptive
  Outcome Measures: ovarian cancer OR myocardial infarction OR MI OR thromboembolism OR VTE OR PE OR DVT OR pulmonary embolism OR stroke OR cervical cancer OR endometrial cancer OR breast cancer OR colorectal cancer

Search #2:

- General search terms (all fields): oral contraceptive AND ovarian cancer