# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BMI: body mass index
BRCA: breast cancer genetic mutation
BSO: bilateral salpingo-oophorectomy
BTL: bilateral tubal ligation
CDC: Centers for Disease Control and Prevention
CI: confidence interval
DMV: Department of Motor Vehicles
DVT: deep venous thrombosis
ER: estrogen receptor
FIGO: International Federation of Gynecology and Obstetrics
GCT: granulosa cell tumor
HPV: human papilloma virus
HR: hazard ratio
HRT: hormone replacement therapy
IRR: incidence rate ratio
IUD: intrauterine device
KQ: Key Question
MI: myocardial infarction
mo: month/months
NA: not applicable
NCHS: National Center for Health Statistics
NHB: net health benefits
NIS: Nationwide Inpatient Sample
NMB: net monetary benefits
NNH: number needed to harm
NNP: number needed to prevent
NR: not reported
NS: nonsignificant
NSFG: National Survey of Family Growth
NZ: New Zealand
OC: oral contraceptive
OR: odds ratio
PE: pulmonary embolism
PICOTS: population, interventions, comparators, outcomes, timing, settings
PR: progesterone receptor
QALY: quality-adjusted life year
RR: risk ratio
SEER: Surveillance, Epidemiology, and End Results registry
SOE: strength of evidence
TEP: Technical Expert Panel
UK: United Kingdom
VTE: venous thromboembolism
WHO: World Health Organization
WTP: willingness to pay
yr: year/years