# General Clinical Topics

Chapter 21 Preventing In-Facility Pressure Ulcers

Chapter 22 Inpatient Intensive Glucose Control Strategies To Reduce Death and Infection (NEW)

Chapter 23 Interventions To Prevent Contrast-Induced Acute Kidney Injury

Chapter 24 Rapid-Response Systems (NEW)

Chapter 25 Medication Reconciliation Supported by Clinical Pharmacists (NEW)

Chapter 26 Identifying Patients at Risk for Suicide: Brief Review (NEW)

Chapter 27 Strategies To Prevent Stress-Related Gastrointestinal Bleeding (Stress Ulcer Prophylaxis): Brief Update Review

Chapter 28 Prevention of Venous Thromboembolism: Brief Update Review

Chapter 29 Preventing Patient Death or Serious Injury Associated With Radiation Exposure From Fluoroscopy and Computed Tomography: Brief Review (NEW)

Chapter 30 Ensuring Documentation of Patients' Preferences for Life-Sustaining Treatment: Brief Update Review