# Safety Practices Aimed Primarily at Hospitalized Elders

Chapter 19 Preventing In-Facility Falls

Chapter 20 Preventing In-Facility Delirium