# Surgery, Anesthesia, and Perioperative Medicine

Chapter 13 Preoperative Checklists and Anesthesia Checklists

Chapter 14 Use of Report Cards and Outcome Measurements To Improve Safety of Surgical Care: American College of Surgeons National Quality Improvement Program (NEW)

Chapter 15 Prevention of Surgical Items Being Left Inside Patient: Brief Update Review

Chapter 16 Operating Room Integration and Display Systems: Brief Review (NEW)

Chapter 17 Use of Beta Blockers To Prevent Perioperative Cardiac Events: Brief Update Review

Chapter 18 Use of Real-Time Ultrasound Guidance During Central Line Insertion: Brief Update Review