# Infection Control

Chapter 7 Barrier Precautions, Patient Isolation, and Routine Surveillance for Prevention of Health Care-Associated Infections: Brief Update Review

Chapter 8 Interventions To Improve Hand Hygiene Compliance: Brief Update Review

Chapter 9 Reducing Unnecessary Urinary Catheter Use and Other Strategies To Prevent Catheter-Associated Urinary Tract Infections: Brief Update Review

Chapter 10 Prevention of Central Line-Associated Bloodstream Infections: Brief Update Review

Chapter 11 Ventilator-Associated Pneumonia: Brief Update Review

Chapter 12 Interventions To Allow the Reuse of Single-Use Devices: Brief Review (NEW)