# Adverse Drug Events

Chapter 3 High-Alert Drugs: Patient Safety Practices for Intravenous Anticoagulants

Chapter 4 Clinical Pharmacist's Role in Preventing Adverse Drug Events: Brief Update Review

Chapter 5 The Joint Commission's “Do Not Use” List: Brief Review (NEW)

Chapter 6 Smart Pumps and Other Protocols for Infusion Pumps: Brief Review (NEW)