# Discussion

Chapter 44 Discussion