# Practices Designed To Improve Overall System/Multiple Targets

Chapter 31 Human Factors and Ergonomics

Chapter 32 Promoting Engagement by Patients and Families To Reduce Adverse Events (NEW)

Chapter 33 Promoting a Culture of Safety

Chapter 34 Effect of Nurse-to-Patient Staffing Ratios on Patient Morbidity and Mortality

Chapter 35 Patient Safety Practices Targeted at Diagnostic Errors (NEW)

Chapter 36 Monitoring Patient Safety Problems (NEW)

Chapter 37 Interventions To Improve Care Transitions at Hospital Discharge (NEW)

Chapter 38 Use of Simulation Exercises in Patient Safety Efforts

Chapter 39 Obtaining Informed Consent From Patients: Brief Update Review

Chapter 40 Team-Training in Health Care: Brief Update Review

Chapter 41 Computerized Provider Order Entry With Clinical Decision Support Systems: Brief Update Review

Chapter 42 Tubing Misconnections: Brief Review (NEW)

Chapter 43 Limiting Individual Providers' Hours of Service: Brief Update Review