# Practices Designed for a Specific Patient Safety Target

Section A Adverse Drug Events

Section B Infection Control

Section C Surgery, Anesthesia, and Perioperative Medicine

Section D Safety Practices Aimed Primarily at Hospitalized Elders

Section E General Clinical Topics