# Evidence Reviews of Patient Safety Practices

The following pages contain the evidence reviews for 41 patient safety practices or approaches to care. They are organized as follows:

- Practices designed for a specific patient safety target
- Practices designed to improve the overall system/multiple targets

Within the section “Practices Designed for a Specific Patient Safety Target” the topics are organized according to the target:

- Adverse drug events
- Infection control
- Surgery, anesthesia, and perioperative medicine
- Safe practices for hospitalized elders
- General clinical topics

Within each subsection, the topics are organized as follows:

- In-depth reviews
- Brief reviews

In-depth reviews are presented in the following format:

How important is the problem?
This section briefly sketches the nature of the target for the Patient Safety Practice.
What is the Patient Safety Practice?
This section describes the practice or practices proposed and evaluated.
Why should this Patient Safety Practice work?
This section describes what has been written about the basis for a proposed Patient Safety Practice, such as an underlying theory, a logic model for how it should work, or prior data.
What are the beneficial effects of the Patient Safety Practice?
This section provides the review of the evidence of effectiveness, and is the section most similar to traditional Evidence-based Practice Center reports.
What are the harms of the Patient Safety Practice?
This section contains the evidence of harms. Unlike reviews of most clinical interventions, evaluating potential harms is not a routine part of Patient Safety Practice evaluations. Thus, for most topics, this section is underdeveloped.
How has the Patient Safety Practice been implemented, and in what contexts?
This section describes what has been reported about how to implement the Patient Safety Practice and the range of institutions or contexts of where it has been implemented. When there is sufficient evidence, implementation studies are evaluated qualitatively for themes regarding effective implementation.
Are there any data about costs?
This section describes the evidence of costs of implementing the Patient Safety Practice, or, in some cases, cost-effectiveness analyses that have been performed.
Are there any data about the effect of context on effectiveness?
This section describes the evidence about whether or not the Patient Safety Practice has been shown to have differential effectiveness in different contexts. The “Context Sensitivity” project defined important contexts for Patient Safety Practices in four domains: external factors (e.g., financial or performance incentives or Patient Safety Practice regulations); structural organizational characteristics (e.g., size, organizational complexity, or financial status); safety culture, teamwork, and leadership involvement; and availability of implementation and management tools (e.g., organizational training incentives).^*^

* Taylor SL, Dy S, Foy R, et al. What context features might be important determinants of the effectiveness of patient safety practice interventions?. BMJ Qual Saf. 2011;20(7):611-7. [pmid: 21617166].

Brief reviews use a different format, that varies somewhat depending on the topic. The general format for brief reviews is: What is (are) the patient safety practice(s)?; How has the patient safety practices been implemented?; What have we learned about the practice(s)? Brief update reviews are topics that were covered in “Making Health Care Safer” 2001 and use a format designed for reader to identify what's new since then.

References. Each chapter is individually referenced for convenience.