# Overview

Chapter 1 Introduction

Chapter 2 Methods