# Additional Contributors

## General Contributors

### ECRI Institute

Michele Datko, M.S.

Lydia Dharia

Kitty Donahue

Eileen Erinoff, M.S.L.I.S.

Gina Giradi, M.S.

Allison Gross, M.S., M.L.S.

Janice Kaczmarek, M.S.

Laura Koepfler, M.L.S.

Kristy McShea, M.S.L.I.S.

Kristi Yingling, M.A., M.S.L.S.

### Additional Chapter Contributors

- Steven C. Bagley, M.D.
  Veterans Affairs Palo Alto Healthcare System
  Palo Alto, CA
  Chapter 26
- Sean M. Berenholtz, M.D., M.H.S.
  Johns Hopkins University
  Baltimore, MD
  Chapter 11
- Vineet Chopra, M.D., M.Sc.
  University of Michigan, School of Medicine
  Ann Arbor, MI
  Chapter 10
- Despina Contopoulos-Ioannidis, M.D.
  Stanford University
  Stanford, CA
  Chapter 35
- Kristina M. Cordasco, M.D., M.P.H., M.S.H.S.
  Veterans Affairs Greater Los Angeles Healthcare System
  Los Angeles, CA
  Chapter 39
- Paul Dallas, M.D.
  Carilion Clinic's CME Program
  Roanoke, VA
  Chapter 18
- Cyrus Engineer, Dr.P.H.
  Johns Hopkins University
  Baltimore, MD
  Chapter 8
- Mohamad G. Fakih, M.D., Ph.D.
  St. John Hospital and Medical Center
  Detroit, MI
  Chapter 9
- Olavo A. Fernandes, B.Sc.Phm., Pharm.D.
  University of Toronto
  Toronto, Ontario, Canada
  Chapter 25
- Tabor Flickinger, M.D., M.S.
  Johns Hopkins University
  Baltimore, MD
  Chapter 32
- David A. Ganz, M.D., Ph.D.
  Veterans Affairs Greater Los Angeles Healthcare System
  Los Angeles, CA
  Chapter 19
- Melinda Maggard-Gibbons, M.D., M.S.H.S.
  University of California, Los Angeles
  Los Angeles, CA
  Chapter 14
- Peter Glassman, M.B.B.S., M.Sc.
  Veterans Affairs Greater Los Angeles Healthcare System
  Los Angeles, CA
  Chapters 4 and 5
- Sara N. Goldhaber-Fiebert, M.D.
  Stanford University, School of Medicine
  Stanford, CA
  Chapter 38
- Elliott R. Haut, M.D., FACS
  Johns Hopkins University
  Baltimore, MD
  Chapter 28
- Susanne Hempel, Ph.D.
  RAND Corporation
  Santa Monica, CA
  Chapter 19
- Lawrence A. Ho, M.D.
  Stanford University, Stanford University Medical Center
  Stanford, CA
  Chapter 38
- John Ioannidis, M.D.
  Stanford University
  Stanford, CA
  Chapter 35
- Devan Kansagara, M.D., M.C.R., FACP
  Portland Veterans Affairs Medical Center
  Portland, OR
  Chapter 22
- Sarah Kianfar, M.S.
  Center for Quality and Productivity Improvement
  Department of Industrial and Systems Engineering
  University of Wisconsin-Madison
  Madison, WI
  Chapter 31
- Sarah L. Krein, Ph.D., R.N.
  Ann Arbor Veterans Affairs Medical Center
  University of Michigan, School of Medicine
  Ann Arbor, MI
  Chapters 9 and 10
- Janice Kwan, M.D.
  University of Toronto
  Toronto, Ontario, Canada
  Chapter 25
- Brandyn D. Lau, M.P.H.
  Johns Hopkins University
  Baltimore, MD
  Chapter 28
- Lisha Lo, M.Sc.
  University of Toronto
  Toronto, Ontario, Canada
  Chapter 25
- Julia Lonhart, B.S., B.A.
  Stanford University
  Stanford, CA
  Chapter 35
- Lisa Lubomski, Ph.D.
  Johns Hopkins University
  Baltimore, MD
  Chapter 33
- Yimdriuska Magan, B.S.
  University of California, San Francisco
  San Francisco, CA
  Chapters 23 and 37
- Brian Matesic, B.S.
  Stanford University
  Stanford, CA
  Chapter 35
- Jennifer Meddings, M.D., MS.c.
  University of Michigan, School of Medicine
  Ann Arbor, MI
  Chapter 9
- Isomi M. Miake-Lye, B.A.
  Veterans Affairs Greater Los Angeles Healthcare System
  Los Angeles, CA
  Chapter 19
- Erika Moseson, M.D.
  University of California, San Francisco
  San Francisco, CA
  Chapter 23
- Oanh K. Nguyen, M.D.
  University of California, San Francisco
  San Francisco, CA
  Chapter 37
- Russell N. Olmsted, M.P.H., C.I.C.
  St. Joseph Mercy Health System
  Ann Arbor, MI
  Chapters 9 and 10
- Noelle Pineda, B.A.
  Stanford University
  Stanford, CA
  Chapter 35
- Michael A. Rosen, Ph.D.
  Johns Hopkins University
  Baltimore, MD
  Chapter 40
- Nasia Safdar, M.D., Ph.D.
  University of Wisconsin–Madison, School of Medicine and Public Health
  Madison, WI
  Chapter 10
- Marin Schweizer, Ph.D.
  University of Iowa Health Care
  Iowa City, IA
  Chapter 7
- Marwa H. Shoeb, M.D., M.S.
  University of California, San Francisco
  San Francisco, CA
  Chapter 37
- David Thompson, D.N.Sc., M.S., R.N.
  Johns Hopkins University
  Baltimore, MD
  Chapter 3
- Anping Xie, M.S.
  Center for Quality and Productivity Improvement
  Department of Industrial and Systems Engineering
  University of Wisconsin–Madison
  Madison, WI
  Chapter 31