# Authors and Affiliations

Co-Principal Investigators
- Paul G. Shekelle, M.D., Ph.D., RAND Corporation Evidence-based Practice Center
- Robert M. Wachter, M.D., University of California, San Francisco
- Peter J. Pronovost, M.D., Ph.D., Johns Hopkins University

ECRI Institute
- Scott Lucas, Ph.D., P.E.
- Meredith Noble, M.S.
- James Reston, Ph.D., M.P.H.
- Karen Schoelles, M.D., S.M., FACP
- Nancy Sullivan, B.A.
- Fang Sun, M.D., Ph.D.
- Kelley Tipton, M.P.H.
- Jonathan R. Treadwell, Ph.D.
- Amy Tsou, M.D. M.S.

Johns Hopkins University
- Sallie J. Weaver, Ph.D.
- Bradford D. Winters, M.D., Ph.D.
- Elizabeth Pfoh, M.P.H.
- Renee Wilson, M.S.
- Kathryn Martinez, M.P.H.; Ph.D.
- Sydney M. Dy, M.D., M.Sc.
- Zack Berger, M.D., Ph.D.

RAND Corporation
- Breanne Johnsen, B.S.
- Jody Wozar Larkin, M.L.I.S.
- Aneesa Motala, B.A.
- Roberta Shanman, M.L.S.

University of California, San Francisco/Stanford
- Kathryn M. McDonald, M.M.
- Sumant R. Ranji, M.D.
- Stephanie Rennke, M.D.
- Eric Schmidt, B.A.

University of Toronto
- Kaveh Shojania, M.D.

Communications Analysts
- Sydne J. Newberry, Ph.D., RAND Corporation
- Mary E. Vaiana, Ph.D., RAND Corporation