# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project.

## Technical Expert Panel

- Alyce Adams, Ph.D.
  Kaiser Permanente
  Oakland, CA
- Peter B. Angood, M.D., FACS, FCCM
  American College of Physician Executives
  Tampa, FL
- David Bates, M.D., M.Sc.
  Harvard University, Brigham and Women's Hospital
  Boston, MA
- Leonard Bickman, Ph.D.
  Vanderbilt University Peabody College
  Nashville, TN
- Pascale Carayon, Ph.D.
  University of Wisconsin–Madison
  Madison, WI
- Sir Liam Donaldson, M.B.Ch.B., M.Sc., FRCS(Ed), MFPHM, M.D., FFPHM
  Imperial College London
  London, United Kingdom
- Naihua Duan, Ph.D.
  New York State Psychiatric Institute
  New York, NY
- Donna Farley, Ph.D., M.P.H.
  RAND Corporation
  Pittsburgh, PA
- Trisha Greenhalgh, B.M.B.C.H., M.R.C.P., M.R.C.G.P., M.D. thesis, FRCP, FRCGP, FHEA, FFPH
  Global Health, Policy and Innovation Unit
  Centre for Primary Care and Public Health
  Blizard Institute
  Barts and The London School of Medicine and Dentistry
  London, UK
- John L. Haughom, M.D.
  PeaceHealth
  Eugene, OR
- Eileen Lake, Ph.D., R.N., FAAN
  University of Pennsylvania
  Wynnewood, PA
- Richard Lilford Ph.D., FRCP, FRCOG, FFPHM
  University of Birmingham
  Edgbaston, Birmingham, UK
- Kathleen Lohr, Ph.D., M.Phil.
  RTI International-UNC Evidence-based Practice Center
  Research Triangle Park, NC
- Gregg S. Meyer, M.D., M.Sc.
  Dartmouth Institute for Health Policy and Clinical Practice
  Lebanon, NH
- Marlene R. Miller, M.D., M.Sc.
  Johns Hopkins Children's Center
  Baltimore, MD
- Duncan Neuhauser, Ph.D., M.B.A., M.H.A.
  Case Western Reserve University
  Cleveland, OH
- Gery Ryan, Ph.D.
  RAND Corporation
  Santa Monica, CA
- Sanjay Saint, M.D., M.P.H.
  Veterans Affairs Ann Arbor Healthcare System
  University of Michigan
  Ann Arbor, MI
- Steve Shortell, Ph.D., M.P.H., M.B.A.
  University of California, Berkeley
  Berkeley, CA
- David Stevens, M.D.
  Dartmouth Institute for Health Policy and Clinical Practice
  Lebanon, NH
- Kieran Walshe, Ph.D.
  Manchester Business School, University of Manchester
  Manchester, UK

## Peer Reviewers

- Scott Flanders, M.D.
  Department of Medicine, University of California, San Francisco
  San Francisco, CA
- Rainu Kaushal, M.D., M.P.H.
  Harvard Medical School, Division of General Internal Medicine, Brigham and Women's Hospital
  Boston, MA
- Harvey J. Murff, M.D., M.P.H.
  Vanderbilt Institute for Medicine and Public Health
  Nashville, TN
- Jeffrey M. Rothschild, M.D., M.P.H.
  Harvard Medical School, Division of General Medicine, Brigham and Women's Hospital
  Boston, MA
- Hardeep Singh, M.D., M.P.H.
  University of Texas, Center for Healthcare Quality and Safety
  Houston, TX
- Donna Woods, Ph.D.
  Northwestern University Feinberg School of Medicine
  Chicago, IL