# Reducing Unnecessary Urinary Catheter Use and Other Strategies To Prevent Catheter-Associated Urinary Tract Infections: Brief Update Review

## Introduction

Urinary tract infection has long been considered the most common healthcare-associated infection (HAI), with the vast majority of these infections occurring after placement of the convenient, often unnecessary,1-3 and easily forgotten urinary catheter.4 With an estimated one million catheter-associated urinary tract infections5 (CAUTIs) per year, associated with an additional cost of $676 per admission (or $2836 when complicated by bacteremia),6 it is not surprising that CAUTIs were among the first hospital-acquired conditions selected for non-payment by Medicare as of October 2008,^7^ and have been further targeted for complete elimination8 as a “never event,” with a national goal to reduce CAUTI by 25% and reduce urinary catheter use by 50% by 2014.^9,10^ These national initiatives renewed public and research interest in the prevention of CAUTI, prompting updates of several comprehensive guidelines11-14 and reviews of strategies to prevent CAUTI released since the 2001 “Making Health Care Safer” report.15

## What Strategies May Prevent Catheter-Associated Urinary Tract Infections?

Similar to other hospital-acquired infections — such as central line-associated blood stream infection (CLABSI) — many CAUTI prevention strategies have been “bundled” into multi-modal sets of interventions known as “bladder bundles,”16 consisting of educational interventions to improve appropriate use and clinical skill in catheter placement, behavioral interventions such as catheter restriction and removal protocols, and use of specific technologies such as the bladder ultrasound. Despite some early success in implementing a “bladder bundle”16 to reduce urinary catheterization rates,17 CAUTI prevention has proven challenging for several important reasons. For example, monitoring urinary catheter use and CAUTI rates to inform and sustain urinary catheter-related interventions is very resource intensive. Perhaps more importantly, improving practice regarding urinary catheter placement and removal also requires interventions to change the expectations and habits of nurses, physicians, and patients about the need for urinary catheters.

To help organize and prioritize the many potential interventions to prevent CAUTI, we use the conceptual model of the “lifecycle of the urinary catheter”18 to highlight that the highest yield interventions to prevent CAUTI will target at least one of the four “stages” of the catheter's “life.” As illustrated in Figure 1, the “lifecycle” of the catheter (1) begins with its initial placement, (2) continues when it remains in place, day after day, (3) ceases when it is removed, and (4) may start over if another catheter is inserted after removal of the first one.

Figure 1, Chapter 9 Lifecycle of the urinary catheter18

This conceptual model illustrates four stages of the urinary catheter lifecycle as targets for interventions to decrease catheter use and catheter-associated urinary tract infections.

Meddings J, Saint S. Disrupting the Life Cycle of the Urinary Catheter. Clin Infect Dis. 2011; 52(11): 1291-3 by permission of Oxford University Press.

Figure 1 depicts a conceptual model of the four stages of the typical life cycle of a urinary catheter as targets for interventions to decrease catheter use and catheter-associated urinary tract infection. This figure was taken, with permission, from a 2011 article by Meddings and colleagues published in the journal, Clinical Infectious Diseases, entitled “Disrupting the Life Cycle of the Urinary Catheter.” The figure is further explained in the text below the image.

Because avoiding unnecessary urinary catheter use is the most important goal in prevention of CAUTI, this chapter reviews the evidence on two types of interventions that target unnecessary urinary catheter use: (1) protocols and interventions to decrease unnecessary placement of urinary catheters (catheter lifecycle stage 1), and (2) interventions that prompt removal of unnecessary urinary catheters (catheter lifecycle stage 3).

The evidence summarized in this chapter was generated using a literature search conducted for a prior systematic review and meta-analysis19 along with a focused update of the published peer-reviewed literature (from August 2008 to February 2012) through a MEDLINE search for intervention studies to reduce use of unnecessary urinary catheters in the acute care of adults. A CINAHL database search was also performed for interventions developed and implemented by nurses related to urinary catheter use. Studies were included if at least one outcome involving catheter use or CAUTI events (Table 1) was reported as a result of the intervention, and with a comparison group (either pre- vs. post-intervention or a separate control group).

Table 1, Chapter 9 Description of outcomes evaluated (adapted from the prior meta-analysis19)

Measures of Catheter-Associated Urinary Tract Infection (Cauti) Development | Number of CAUTI episodes per 1,000 catheter-days was recorded and a rate ratio was calculated to compare pre- vs. post-intervention. When rates of both asymptomatic and symptomatic CAUTI were reported separately,20 the rates of symptomatic CAUTI were used for the meta-analysis.19
Measures of Catheter-Associated Urinary Tract Infection (Cauti) Development | Cumulative risk of CAUTI during hospitalization (i.e., the percentage of patients who developed CAUTI) was also extracted for each study, and a risk ratio was calculated to compare risks before and after the intervention for the meta-analysis.19
Measures of Urinary Catheter Use | Mean number of days of urinary catheter use per patient was recorded before and after the intervention, and a standardized mean difference (SMD) was calculated to compare the two groups for the meta-analysis.19
Measures of Urinary Catheter Use | Percentage of patient days in which the catheter was in place was calculated before and after the intervention, and a standardized mean difference (SMD) was determined for each study for the meta-analysis.19
Measures of Urinary Catheter Use | Daily catheter prevalence, defined as the number of patients with catheters in place during a specific time period, is reported for some of the more recent studies.
Need for Catheter Replacement | Re-catheterization need was extracted as the number and percent of patients who required replacement of a catheter after prior removal of an indwelling catheter.

The table in Appendix D summarizes the intervention studies described in this review, including study designs, patient populations, and the interventions employed to avoid unnecessary catheter placement or to prompt catheter removal.

Meddings J, Rogers MA, Macy M, et al. Systematic review and meta-analysis: reminder systems to reduce catheter-associated urinary tract infections and urinary catheter use in hospitalized patients. Clin Infect Dis. 2010;51(5):550-60 by permission of Oxford University Press.

## What Strategies May Reduce Unnecessary Catheter Use?

### Strategies To Avoid Unnecessary Placement of Indwelling Urinary Catheters

Simply put, patients without urinary catheters do not develop CAUTI. Yet, multiple studies show that between 21 and 63 percent1,3,21-24 of urinary catheters are placed in patients who do not have an appropriate indication and therefore may not even need a catheter. Over the past decade, several studies have employed interventions to decrease unnecessary catheter placement (described in Appendix D Table). Although educational interventions are a common and important first step to decrease inappropriate catheter use, more effective and potentially more sustainable interventions go a step further by instituting restrictions on catheter placement. Protocols that restrict catheter placement can serve as a constant reminder for providers about the appropriate use of catheters, can suggest alternatives to indwelling catheter use (such as condom catheters or intermittent straight catheterization), but perhaps most importantly, can generate accountability for placement of each individual urinary catheter. A fairly typical approach for developing a catheter restriction protocol is to begin with a basic list of appropriate catheter uses (such as provided in the Centers for Disease Control and Prevention's Healthcare Infection Control Practices Advisory Committee (HICPAC) guideline11); this list (Table 2) can then be tailored to include other indications based on local opinion and specialized patient populations.

Table 2, Chapter 9 Indications for indwelling urethral catheter use (from the 2009 CDC's guideline11)

A. Examples of Appropriate Indications for Indwelling Urethral Catheter Use
Patient has acute urinary retention or bladder outlet obstruction
Need for accurate measurements of urinary output in critically ill patients
Perioperative use for selected surgical procedures:; - Patients undergoing urologic or other surgery on contiguous structures of genitourinary tract; - Anticipated prolonged surgery duration; catheters inserted for this reason should be removed in post-anesthesia care unit; - Patients anticipated to receive large-volume infusions or diuretics during surgery; - Need for intraoperative monitoring of urinary output
To assist in healing of open sacral or perineal wounds in incontinent patients
Patient requires prolonged immobilization (e.g., potentially unstable thoracic or lumbar spine, multiple traumatic injuries such as pelvic fractures)
To improve comfort for end of life care if needed
B. Examples of Inappropriate Uses of Indwelling Catheters
As a substitute for nursing care of the patient or resident with incontinence
As a means to obtain urine for culture or other diagnostic tests when patient can voluntarily void
For prolonged postoperative duration without appropriate indications (e.g., structural repair of urethra or contiguous structures, prolonged effect of epidural anesthesia, etc.)

The technology required to implement catheter placement restrictions ranges from low technology strategies such as a hospital or unit policy on appropriate catheter placement or pre-printed catheter orders with limited indications to higher technology strategies such as computerized orders22,23,25 for catheter placement. Catheter restriction protocols have been a common component of successful multi-modal interventions to decrease catheter use and/or CAUTI rates, including hospital-wide23 interventions and interventions tailored for specific environments such as the emergency department,21,26 inpatient units17 (including general medical25,27,28-surgical29 wards and ICU29-33), and in the peri-procedural32 setting. Urinary retention protocols22,28,29,32-34 are a type of catheter restriction protocols that often incorporate the use of a portable bladder ultrasound22,28,32,34,35 to verify retention prior to catheterization, and recommend use of intermittent catheterization rather than indwelling catheters to manage a common and often temporary issue.

### Strategies To Prompt Removal of Unnecessary Urinary Catheters

Urinary catheters are commonly left in place when no longer needed.3,24 In most hospitals, four steps are required to remove a urinary catheter:18 (1) a physician recognizes the catheter is in place, (2) the physician recognizes the catheter is no longer needed, (3) the physician writes the order to remove catheter, and (4) a nurse removes the catheter. Thus, by default, hours and sometimes days may pass before an unnecessary catheter is recognized and removed. Because every additional day of urinary catheter use increases the patient's risk of infectious and non-infectious catheter-related complications, interventions that facilitate prompt removal of unnecessary catheters can have a strong impact. We describe below the evidence regarding strategies that may accelerate or bypass some of these four steps to prompt catheter removal.

Perhaps the most important CAUTI prevention strategy after placement of the catheter is to maintain awareness of the catheter's existence (in lifecycle stage 2 of Figure 1), as health care providers commonly forget the catheter is in place.4 Thus, a key step in prompting removal of unnecessary catheters is frequently (by day or by shift) reminding nurses and physicians that the catheter remains in place. Catheter reminder interventions include a daily checklist23,32,33,36,37 or verbal/written reminder31,38-42 to assess continued catheter need, a sticker reminder on the patient's chart35,43,44 or catheter bag,45 or an electronic23 reminder that a catheter is still in place. Reminder interventions can be generated by nurses, physicians or electronic order sets, and can be targeted to remind either nurses or physicians about the catheter. Some reminder interventions have employed nurses dedicated to detecting unnecessary catheters.23,35 Reminder interventions can also serve to remind clinicians of appropriate catheter indications.

Unfortunately, reminder interventions can also be easy to ignore43 and catheters may remain in place without action. The next type of intervention to prompt removal of unnecessary catheters, which goes a step further, is a “stop order” that requires action. Stop orders prompt the clinician (either nurse or physician) to remove the catheter by default after a certain time period has elapsed or condition has occurred, unless the catheter remains clinically appropriate. For example, catheter stop orders can be configured to “expire” in the same fashion as restraint or antibiotic orders, unless action is taken by a clinician. Stop orders directed at physicians23,25,28,30,42 require an order to be renewed or discontinued on the basis of review at specific intervals, such as every 24 to 48 hours after admission or post-procedure. Stop orders directed at nurses either require the nurse to obtain a catheter removal order from physicians,27,32,46 or can empower nurses to remove the catheter without requesting a physician order20,28,30,34,47-49 on the basis of an appropriate indication list. Admittedly, implementing a nurse-empowered catheter removal protocol may be less effective than anticipated, as early qualitative research of nurse-empowered interventions indicate some nurses are uncomfortable with this autonomy49 and might not remove catheters as expected.

## What Is the Impact of Strategies To Avoid Unnecessary Urinary Catheter Use?

### Impact of Interventions To Avoid Unnecessary Catheter Placement

Multiple before-and-after studies of interventions to decrease inappropriate catheter placement (such as catheter placement restrictions and urinary retention protocols) have resulted in a decrease in the use of urinary catheters,21-23,28,29,31,33 a lower proportion of catheters in place without a physician order21,23,25,26 and a reduction in the proportion of catheters in place without an appropriate indication.21,23,26,28

### Impact of Reminder and Stop Order Interventions on Catheter Use and CAUTIs

A systematic review and meta-analysis of 14 studies19 published prior to August 2008 (including nine reminder interventions and five stop order interventions) demonstrated that the rate of CAUTI (episodes per 1,000 catheter-days) was reduced by 52 percent (p<0.001) with the use of either a reminder or stop order. Based on this meta-analysis, reminders and stop orders could result in large numbers of avoided CAUTI episodes per 1,000 catheter-days, particularly when baseline rates of CAUTI are high (Table 3, adapted from a previous meta-analysis19).

Table 3, Chapter 9 Number of avoided CAUTI episodes per 1,000 catheter-days

Baseline rate of CAUTI episodes per 1,000 catheter-days | Number of avoided CAUTI episodes per 1,000 catheter-days anticipated by the type of intervention to prompt catheter removal
Baseline rate of CAUTI episodes per 1,000 catheter-days | Reminder | Stop order | Overall
5 | 2.8 | 2.0 | 2.6 (95%CI, 1.6–3.6)
10 | 5.6 | 4.1 | 5.2 (95%CI, 3.2-7.2)
20 | 11.2 | 8.2 | 10.4 (95%CI, 6.4-14.4)

This meta-analysis19 also suggested that the mean duration of urinary catheterization decreased by 37 percent, with 2.61 fewer days of catheterization per patient in the intervention vs. control groups. The pooled standardized mean difference (SMD) in the duration of catheterization was -1.11 overall (p=0.070); a statistically significant decrease in duration was observed in studies that used a stop order (SMD -0.30; p=0.001) but not in those that used only a reminder intervention (SMD -1.54; p=0.071).19 An update of the literature review since this meta-analysis yielded 12 additional studies with reminder and/or stop order interventions. Figure 2 illustrates the major findings of the 14 studies for catheter use and CAUTI events as reported in the prior meta-analysis;19 Figure 3 illustrates the major findings for the 12 subsequent studies, including eight that reported measures of catheter use, and eight that reported CAUTI events.

Figure 2, Chapter 9 Summary of CAUTI and urinary catheter outcomes from 14 studies

Note: Summary comes from the 14 studies20,25,28-30,33,36-41,43,45 included in the 2010 meta-analysis.19

* Difference of p<0.05 reported between intervention and comparison group.

Figure 2 is a table that summarizes the major findings of 14 studies of catheter use and CAUTI events as reported in the 2010 meta-analysis by Meddings and colleagues published in Clinical Infectious Diseases. The table consists of 5 columns. The left-most column lists the first author and year of the studies included in the review. The 2nd and 3rd columns from the left list CAUTI outcomes: column 2 lists “episodes per 1000 catheter days,” and the adjacent column lists “the percentage of patients who developed CAUTI.” The 4th and 5th columns describe Urinary Catheter Use Outcomes: the 4th column lists “mean days of urinary catheter use per patient” and the 5th column lists the “percent of patient days with a catheter in place.”

Figure 3, Chapter 9 Summary of CAUTI and urinary catheter outcomes from 12 additional studies

Note: Summary comes from 12 additional studies23,27,31,32,34,35,42,44,46-49 since the prior meta-analysis.19

* Difference of p<0.05 reported between intervention and comparison group.

Figure 3 depicts a 5-column table that shows the major findings for 12 studies that appeared subsequent to the 2010 meta-analysis or were excluded from the 2010 meta-analysis because they did not meet the inclusion criteria for that review. The 12 studies included eight that reported measures of catheter use, and eight that reported CAUTI events. The left-most column lists the first author and year of publication of each study. The second and third columns list “CAUTI Outcomes:” the second column captures the data for the articles that reported “CAUTI episodes per 1000 catheter days” and the third column shows the “Percentage Patients who developed CAUTI.” The fourth, fifth, and sixth columns list “Urinary Catheter Use Outcomes:” “Mean Days of Urinary Catheter Use per Patient,” “Percentage Patient Days with Catheter in Place,” and/or “Daily Catheter Prevalence Percentage,” respectively.

### Potential for Unintended Harm by Catheter Removal Interventions

Interventions that facilitate removal of urinary catheters do pose the risk of premature urinary catheter removal, with patients then requiring unnecessary recatheterization; any catheterization event is associated with procedure-related discomfort and other potential complications. Thus, monitoring the need for re-catheterization is important to avoid unintended patient harm. In the meta-analysis of reminder and stop order studies, only four of the 14 studies reported rates of re-catheterization20,25,39,43 with low re-catheterization rates noted in both intervention and control groups. None of the 12 more recent studies involving reminders or stop orders to prompt catheter removal reported data on potential patient harm, such as premature removal.

### Summary of Other Strategies To Prevent CAUTI

Several recent evidence-based guidelines11-14 have focused on preventing CAUTI and have assessed the evidence and provided recommendations for implementing prevention strategies. Key recommendations in the CDC guideline,11 in addition to appropriate catheter use (Table 2), include (1) aseptic insertion of urinary catheters by properly trained personnel, using aseptic technique and sterile equipment (with an exception being that clean technique is appropriate for chronic intermittent catheterization), and (2) proper urinary catheter maintenance with a sterile, closed drainage system permitting unobstructed urine flow. Aseptic insertion is primarily recommended as a standard of care for which limited evidence exists. Stronger evidence (epidemiological and clinical) supports the importance of a sterile, closed, unobstructed urinary drainage system.

A more controversial topic is the use of antimicrobial catheters. Based on the current evidence, the CDC guideline recommends11 that antimicrobial catheters should not be used routinely to prevent CAUTI. It also suggests that further research is needed both on the effect of silver-alloy coated catheters in reducing the risk of clinically significant CAUTI outcomes and on the benefit of silver-alloy coated catheters in selected patients at high risk of infection.

Bundles of interventions are also an important strategy, as part of a multi-modal approach that focuses efforts on high-yield interventions. For example, one strategy that includes several of the components from the “Bladder Bundle” implemented by the Michigan Health and Hospital Association (MHA) Keystone Center for Patient Safety & Quality is the “ABCDE” approach:16

- Adherence to general infection control principles is important (e.g., hand hygiene, surveillance and feedback, aseptic insertion, proper maintenance, education).
- Bladder ultrasound may avoid indwelling catheterization.
- Condom catheters or other alternatives to an indwelling catheter such as intermittent catheterization should be considered in appropriate patients.
- Do not use the indwelling catheter unless you must!
- Early removal of the catheter using a reminder or nurse-initiated removal protocol appears warranted.

## What Is the Cost of Implementing a CAUTI Prevention Program?

The cost of implementing a CAUTI prevention program will vary based on the level of technology used (e.g., computerized vs. pre-printed catheter orders, and whether portable bladder ultrasounds are purchased) and the time invested in implementing and evaluating the interventions. Saint and colleagues, in their study of a written urinary catheter reminder generated by a research nurse to remind physicians which of their inpatients had urinary catheters,43 found that the intervention was either cost-neutral or modestly cost-saving depending on the assumptions made. More recently, a study35 of five hospitals in the Netherlands employed a multi-modal intervention including reminders in four hospitals, and a stop order in the fifth hospital. The program was found to be cost-saving, with the mean amount saved being € 537 (or ∼$700) per 100 hospitalized patients.

## What Methods Have Been Used To Improve the Implementation of Interventions To Prevent Catheter-Associated Urinary Tract Infections?

Because reducing unnecessary catheter use often requires changing well-established habits and beliefs of nurses and physicians, the challenge of implementation should not be under-estimated. To facilitate implementation of practices to prevent CAUTI, the Michigan Keystone Bladder Bundle Initiative16 used the Johns Hopkins University collaborative model for transformational change. This model is based in part on the “four E's”: Engage, Educate, Execute, and Evaluate.50 During the “Engage” and “Educate” steps, hospitals were provided information in multiple formats and a toolkit describing the intervention steps and outcomes measures. In the “Execute” step, the hospital was strongly encouraged to choose one nurse champion51 (for example, a case manager, nurse coordinator, or clinical nurse specialist) to lead the initiative and organize a bladder bundle team, including at least one physician, and to participate in workshops and conference calls with other participating hospitals to provide additional expert content and practical coaching. Also during the “Execute” step, daily patient rounds (which in some hospitals were called a “catheter patrol”) were recommended to assess catheter presence and necessity, and provide feedback to specific units and re-evaluate strategies in progress. Hospitals were also encouraged to implement more active strategies for prevention, such as a catheter reminder system or promoting the use of catheter alternatives by developing protocols or making sure the necessary supplies were readily available. In the “Evaluate” phase, hospitals were asked to conduct a baseline assessment of catheter use (point prevalence) and appropriate use according to specified indications and to conduct periodic reassessments to assess progress and sustainability.

Implementation challenges within CAUTI prevention should be expected52 and managed accordingly. Qualitative assessment focusing on HAI prevention has identified two important potential barriers to healthcare-associated infection preventive efforts: “active resisters” and “organizational constipators.”53 Active resisters are hospital personnel who vigorously and openly oppose changes in practice, as a matter of habit or culture (e.g., “just not how they were trained”). Management of active resisters often requires those in authority to mandate compliance, collect data, and provide feedback.53 A “champion” who is influential or a peer of the resisting staff may also help to overcome active resistance.51,52 “Organizational constipators” are usually mid- or high-level executives who act as barriers to change by preventing or delaying certain actions needed to implement new practices.53 Strategies to address an organizational constipator are to include this person in early discussions to improve buy-in and motivation, working around the person, or replacing the constipator.

A unique challenge to expect when implementing urinary catheter removal strategies is reluctance by some nurses to remove the catheter,52 even when the nurse is “empowered” to do so. In some cases, nurses may be active resisters due to disagreement with the catheter policy and/or a desire to avoid the inconveniences and increased frequency of patient contact required for the care of incontinence and catheter alternatives. Other nurses report they simply do not feel comfortable49 removing the catheter without explicit orders from the physician, which is ironic considering that many nurses place catheters without orders. Nursing comfort with catheter removal can be increased49 with peer support and education, and may be facilitated by directly addressing the workload concerns associated with the removal of indwelling catheters. Indeed, a survey of nurses27 during implementation of a nurse-empowered catheter removal protocol indicated increased nursing and patient satisfaction, despite the expected increase in workload.

Even though CAUTI is a very common healthcare-associated infection, Krein and colleagues reported that CAUTI preventive practice use is lagging behind efforts to prevent central line-associated bloodstream infection and ventilator-associated pneumonia,54 with room for improvement in adopting catheter removal and CAUTI preventive strategies demonstrated again in two recent large surveys of hospitals55 and ICUs.56 Fortunately, many resources exist (www.Catheterout.org) to help hospitals develop and implement programs to decrease catheter use and prevent CAUTI, including a range of tools and educational materials to address implementation challenges. Hospital and unit-level leadership also play a key role in preventing infection.57

## Monitoring and Providing Feedback on Catheter Use and CAUTI Rates

Inappropriate urinary catheter use is an easy habit to start and a difficult one to break.18 Consequently, many studies17,30 have emphasized the importance of on-going surveillance and feedback as an intervention to reduce healthcare-associated infections such as CAUTI and sustain prevention efforts. New national efforts to reduce CAUTI (www.onthecuspstophai.org/stop-cauti/) incorporate periodic feedback to participating units on urinary catheter use and CAUTI rates. The CAUTI rates evaluated include the National Healthcare Safety Network (NHSN) and the newly described population-based rates.58 The population-based CAUTI rate incorporates both the NHSN rate and the device utilization ratio, to account for interventions focused on reduction in catheter use and improvements in placement and maintenance.

Important next steps to address CAUTI involve developing strategies to decrease the effort and resources required to monitor catheter use and CAUTI rates. Advanced informatics tools have recently been shown to increase the impact of this feedback loop to the extent that rates of CAUTI were lower in facilities that deployed these tools compared with those that did not.59 Careful selection or development of datasets used for implementing hospital payment changes and public reporting for CAUTI events is also recommended. Unfortunately, the current administrative data used to implement non-payment7 for hospital-acquired CAUTIs and to publicly report hospital performance likely captures few CAUTI events, given documentation and coding challenges60 to translate a urinary tract infection event from a medical record into hospital-acquired CAUTI in the administrative datasets.

## Conclusions and Comment

In summary, hospitals should strongly consider employing interventions to avoid unnecessary catheter placement and to prompt removal of unnecessary catheters. These interventions appear to be low cost, low risk and effective strategies to address a common hospital-acquired infection in the United States, with some unique but not impossible challenges for implementation. Furthermore, reducing indwelling catheter use addresses the noninfectious complications of urinary catheter use such as catheter-related patient discomfort and immobility (Table 4).

Table 4, Chapter 9 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Moderate | Moderate-to-high | Low | Low | Moderate/Moderate

## References

1 Gokula RR, Hickner JA, Smith MA. Inappropriate use of urinary catheters in elderly patients at a midwestern community teaching hospital. Am J Infect Control. 2004;32(4):196-9. [pmid: 15175612].
2 Fakih MG, Shemes SP, Pena ME, et al. Urinary catheters in the emergency department: very elderly women are at high risk for unnecessary utilization. Am J Infect Control. 2010;38(9):683-8. [pmid: 21034978].
3 Jain P, Parada JP, David A, et al. Overuse of the indwelling urinary tract catheter in hospitalized medical patients. Arch Intern Med. 1995;155(13):1425-9. [pmid: 7794092].
4 Saint S, Wiese J, Amory JK, et al. Are physicians aware of which of their patients have indwelling urinary catheters?. Am J Med. 2000;109(6):476-80. [pmid: 11042237].
5 Foxman B. Epidemiology of urinary tract infections: incidence, morbidity, and economic costs. Am J Med. Suppl 1A. 2002;113:5S-13S. [pmid: 12113866].
6 Saint S. Clinical and economic consequences of nosocomial catheter-related bacteriuria. Am J Infect Control. 2000;28(1):68-75. [pmid: 10679141].
7 Medicare program; changes to the hospital inpatient prospective payment systems and fiscal year 2009 rates. Fed Regist. 2008;73(161):48473-91. [pmid: 18956499].
8 Cardo D, Dennehy PH, Halverson P, et al. Moving toward elimination of healthcare-associated infections: a call to action. Am J Infect Control. 2010;38(9):671-5. [pmid: 21058460].
9 Department of Health and Human Services. Action Plan to Prevent Healthcare-Associated Infections, Appendix G. 2009. www.hhs.gov/ash/initiatives/hai/actionplan/hhs_hai_action_plan_final_06222009.pdf. February 28, 2012.
10 Department of Health and Human Services. National Targets and Metrics: Monitoring Progress Toward Action Plan Goals: A Mid-Term Assessment. 2011. www.hhs.gov/ash/initiatives/hai/nationaltargets/index.html.
11 Gould CV, Umscheid CA, Agarwal RK, et al. Guideline for prevention of catheter-associated urinary tract infections 2009. Infect Control Hosp Epidemiol. 2010;31(4):319-26. [pmid: 20156062].
12 Hooton TM, Bradley SF, Cardenas DD, et al. Diagnosis, prevention, and treatment of catheter-associated urinary tract infection in adults: 2009 International Clinical Practice Guidelines from the Infectious Diseases Society of America. Clin Infect Dis. 2010;50(5):625-63. [pmid: 20175247].
13 Lo E, Nicolle L, Classen D, et al. Strategies to prevent catheter-associated urinary tract infections in acute care hospitals. Infect Control Hosp Epidemiol. Suppl 1. 2008;29:S41-50. [pmid: 18840088].
14 Greene L, Marx J, Oriola S. An APIC guide to the elimination of catheter-associated urinary tract infections (CAUTIs): developing and applying facility-based prevention interventions in acute and long-term care settings. 2008.
15 Saint S. Chapter 15. Prevention of Nosocomial Urinary Tract Infections. Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Evidence Report/Technology Assessment, No. 43. AHRQ Publication No. 01-E058. Agency for Healthcare Research and Quality. Rockville, MD. 2001. www.ahrq.gov/clinic/ptsafety/pdf/chap15.pdf. February 28, 2012.
16 Saint S, Olmsted RN, Fakih MG, et al. Translating health care-associated urinary tract infection prevention research into practice via the bladder bundle. Jt Comm J Qual Patient Saf. 2009;35(9):449-55. [pmid: 19769204].
17 Fakih MG, Watson SR, Greene MT, et al. Reducing inappropriate urinary catheter use: a statewide effort. Arch Intern Med. 2012;172(3):255-60. [pmid: 22231611].
18 Meddings J, Saint S. Disrupting the life cycle of the urinary catheter. Clin Infect Dis. 2011;52(11):1291-3. [pmid: 21596672].
19 Meddings J, Rogers MA, Macy M, et al. Systematic review and meta-analysis: reminder systems to reduce catheter-associated urinary tract infections and urinary catheter use in hospitalized patients. Clin Infect Dis. 2010;51(5):550-60. [pmid: 20673003].
20 Loeb M, Hunt D, O'Halloran K, et al. Stop orders to reduce inappropriate urinary catheterization in hospitalized patients: a randomized controlled trial. J Gen Intern Med. 2008;23(6):816-20. [pmid: 18421507].
21 Fakih MG, Pena ME, Shemes S, et al. Effect of establishing guidelines on appropriate urinary catheter placement. Acad Emerg Med. 2010;17(3):337-40. [pmid: 20370769].
22 Patrizzi K, Fasnacht A, Manno M. A collaborative, nurse-driven initiative to reduce hospital-acquired urinary tract infections. J Emerg Nurs. 2009;35(6):536-9. [pmid: 19914479].
23 Knoll BM, Wright D, Ellingson L, et al. Reduction of inappropriate urinary catheter use at a Veterans Affairs hospital through a multifaceted quality improvement project. Clin Infect Dis. 2011;52(11):1283-90. [pmid: 21596671].
24 Gardam MA, Amihod B, Orenstein P, et al. Overutilization of indwelling urinary catheters and the development of nosocomial urinary tract infections. Clin Perform Qual Health Care. 1998;6(3):99-102. [pmid: 10182561].
25 Cornia PB, Amory JK, Fraser S, et al. Computer-based order entry decreases duration of indwelling urinary catheterization in hospitalized patients. Am J Med. 2003;114(5):404-7. [pmid: 12714131].
26 Gokula RM, Smith MA, Hickner J. Emergency room staff education and use of a urinary catheter indication sheet improves appropriate use of foley catheters. Am J Infect Control. 2007;35(9):589-93. [pmid: 17980237].
27 Rothfeld AF, Stickley A. A program to limit urinary catheter use at an acute care hospital. Am J Infect Control. 2010;38(7):568-71. [pmid: 20381918].
28 Topal J, Conklin S, Camp K, et al. Prevention of nosocomial catheter-associated urinary tract infections through computerized feedback to physicians and a nurse-directed protocol. Am J Med Qual. 2005;20(3):121-6. [pmid: 15951517].
29 Stephan F, Sax H, Wachsmuth M, et al. Reduction of urinary tract infection and antibiotic use after surgery: a controlled, prospective, before-after intervention study. Clin Infect Dis. 2006;42(11):1544-51. [pmid: 16652311].
30 Dumigan DG, Kohan CA, Reed CR, et al. Utilizing national nosocomial infection surveillance system data to improve urinary tract infection rates in three intensive-care units. Clin Perform Qual Health Care. 1998;6(4):172-8. [pmid: 10351284].
31 Elpern EH, Killeen K, Ketchem A, et al. Reducing use of indwelling urinary catheters and associated urinary tract infections. Am J Crit Care. 2009;18(6):535-41. quiz 42. [pmid: 19880955].
32 Fuchs MA, Sexton DJ, Thornlow DK, et al. Evaluation of an evidence-based, nurse-driven checklist to prevent hospital-acquired catheter-associated urinary tract infections in intensive care units. J Nurs Care Qual. 2011;26(2):101-9. [pmid: 21037484].
33 Reilly L, Sullivan P, Ninni S, et al. Reducing foley catheter device days in an intensive care unit: using the evidence to change practice. AACN Adv Crit Care. 2006;17(3):272-83. [pmid: 16931923].
34 Schultz P, Aljawawdeh A, Hopp T. EB105: Reducing use of indwelling urinary catheters with a nurse-driven protocol. Crit Care Nurse. 2011;31(2):e42.
35 van den Broek PJ, Wille JC, van Benthem BHB, et al. Urethral catheters: can we reduce use?. BMC Urol. 2011;11:10. [pmid: 21605403].
36 Jain M, Miller L, Belt D, et al. Decline in ICU adverse events, nosocomial infections and cost through a quality improvement initiative focusing on teamwork and culture change. Qual Saf Health Care. 2006;15(4):235-9. [pmid: 16885246].
37 Weitzel T. To cath or not to cath?. Nurs. 2008;38(2):20-1. [pmid: 18223406].
38 Apisarnthanarak A, Thongphubeth K, Sirinvaravong S, et al. Effectiveness of multifaceted hospitalwide quality improvement programs featuring an intervention to remove unnecessary urinary catheters at a tertiary care center in Thailand. Infect Control Hosp Epidemiol. 2007;28(7):791-8. [pmid: 17564980].
39 Crouzet J, Bertrand X, Venier AG, et al. Control of the duration of urinary catheterization: impact on catheter-associated urinary tract infection. J Hosp Infect. 2007;67(3):253-7. [pmid: 17949851].
40 Huang WC, Wann SR, Lin SL, et al. Catheter-associated urinary tract infections in intensive care units can be reduced by prompting physicians to remove unnecessary catheters. Infect Control Hosp Epidemiol. 2004;25(11):974-8. [pmid: 15566033].
41 Fakih MG, Dueweke C, Meisner S, et al. Effect of nurse-led multidisciplinary rounds on reducing the unnecessary use of urinary catheterization in hospitalized patients. Infect Control Hosp Epidemiol. 2008;29(9):815-9. [pmid: 18700831].
42 Seguin P, Laviolle B, Isslame S, et al. Effectiveness of simple daily sensitization of physicians to the duration of central venous and urinary tract catheterization. Intensive Care Med. 2010;36(7):1202-6. [pmid: 20237761].
43 Saint S, Kaufman SR, Thompson M, et al. A reminder reduces urinary catheterization in hospitalized patients. Jt Comm J Qual Patient Saf. 2005;31(8):455-62. [pmid: 16156193].
44 Bruminhent J, Keegan M, Lakhani A, et al. Effectiveness of a simple intervention for prevention of catheter-associated urinary tract infections in a community teaching hospital. Am J Infect Control. 2010;38(9):689-93. [pmid: 21034979].
45 Murphy D, Francis K, Litzenberger M, et al. Reducing urinary tract infection: a nurse-initiated program. Pa Nurse. 2007;62(4):20. [pmid: 18286841].
46 Robinson S, Allen L, Barnes MR, et al. Development of an evidence-based protocol for reduction of indwelling urinary catheter usage. Medsurg Nurs. 2007;16(3):157-61. [pmid: 17849921].
47 Gotelli JM, Merryman P, Carr C, et al. A quality improvement project to reduce the complications associated with indwelling urinary catheters. Urol Nurs. 2008;28(6):465-7. 73. [pmid: 19241786].
48 Voss AB. Incidence and duration of urinary catheters in hospitalized older adults: before and after implementing a geriatric protocol. J Gerontol Nurs. 2009;35(6):35-41. [pmid: 19537293].
49 Wenger JE. Cultivating quality: reducing rates of catheter-associated urinary tract infection. Am J Nurs. 2010;110(8):40-5. [pmid: 20671495].
50 Pronovost PJ, Berenholtz SM, Needham DM. Translating evidence into practice: a model for large scale knowledge translation. BMJ. 2008;337:a1714. [pmid: 18838424].
51 Damschroder LJ, Banaszak-Holl J, Kowalski CP, et al. The role of the champion in infection prevention: results from a multisite qualitative study. Qual Saf Health Care. 2009;18(6):434-40. [pmid: 19955453].
52 Saint S, Kowalski CP, Forman J, et al. A multicenter qualitative study on preventing hospital-acquired urinary tract infection in US hospitals. Infect Control Hosp Epidemiol. 2008;29(4):333-41. [pmid: 18462146].
53 Saint S, Kowalski CP, Banaszak-Holl J, et al. How active resisters and organizational constipators affect health care-acquired infection prevention efforts. Jt Comm J Qual Patient Saf. 2009;35(5):239-46. [pmid: 19480375].
54 Krein SL, Kowalski CP, Hofer TP, et al. Preventing hospital-acquired infections: a national survey of practices reported by U.S. hospitals in 2005 and 2009. J Gen Intern Med. 2011. Dec. 6. (online). [pmid: 22143455].
55 Fink R, Gilmartin H, Richard A, et al. Indwelling urinary catheter management and catheter-associated urinary tract infection prevention practices in Nurses Improving Care for Healthsystem Elders hospitals. Am J Infect Control. 2012. Jan. 30. (online). [pmid: 22297241].
56 Conway LJ, Pogorzelska M, Larson E, et al. Adoption of policies to prevent catheter-associated urinary tract infections in United States intensive care units. Am J Infect Control. 2012. Feb. 6. (online). [pmid: 22317857].
57 Saint S, Kowalski CP, Banaszak-Holl J, et al. The importance of leadership in preventing healthcare-associated infection: results of a multisite qualitative study. Infect Control Hosp Epidemiol. 2010;31(9):901-7. [pmid: 20658939].
58 Fakih MG, Todd Greene M, Kennedy EH, et al. Introducing a population-based outcome measure to evaluate the effect of interventions to reduce catheter-associated urinary tract infection. Am J Infect Control. 2011. Aug. 24. (online). [pmid: 21868133].
59 Palumbo AJ, Loveless PA, Moll ME, et al. Evaluation of healthcare-associated infection surveillance in Pennsylvania hospitals. Infect Control Hosp Epidemiol. 2012;33(2):105-11. [pmid: 22227977].
60 Meddings J, Saint S, McMahon LF Jr. Hospital-acquired catheter-associated urinary tract infection: documentation and coding issues may reduce financial impact of Medicare's new payment policy. Infect Control Hosp Epidemiol. 2010;31(6):627-33. [pmid: 20426577].