# Discussion

## Introduction

### Progress Since the 2001 Report

Over 2000 years ago, Hippocrates reminded physicians to, “first, do no harm.” In 1863, Florence Nightingale wrote, “It may seem a strange principle to enunciate as the very first requirement in a hospital that it should do the sick no harm.” Notwithstanding these commonsensical admonitions, it was not until the turn of this century that a systematic effort to improve patient safety began, catalyzed by the publication of the IOM report, “To Err is Human.”1

The year following the publication of the IOM report, AHRQ commissioned a group of investigators, led by the UCSF-Stanford EPC, to synthesize the world's literature on PSPs, an effort that culminated in the 2001 report, “Making Health Care Safer.”2 This report was widely used by clinicians, safety workers, researchers, and policymakers, and it informed a variety of other initiatives including the National Quality Forum's Safe Practices list.

Since 2001, research in the patient safety field has exploded, with literally thousands of published studies. In fact, some of today's popular safety practices—rapid response teams, disclosure of errors to patients, or any of the “checklist”—based interventions—had barely been invented at the time of the 2001 report.

In light of this maturation of the field, AHRQ asked a group of investigators, many of whom were involved in producing the earlier report, to synthesize the vast amount of new information on PSPs that has emerged since the release of “Making Health Care Safer.” Using a similar method, which combined explicit criteria, detailed evidence reviews, and an international panel of expert advisors, this report reviewed the evidence on 41 PSPs. In Table 1, below, we provide a summary of this evidence, followed by a discussion of the evidence in the context of prior work on patient safety, and then present priorities for adoption of PSPs

Table 1, Chapter 44 Summary table^*^

Patient Safety Practice | Scope of the Problem Targeted by the PSP(Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Practices Designed for a Specific Patient Safety Target
Adverse Drug Events
High-alert drugs: patient safety practices for intravenous anticoagulants;in-depth review | Common/Moderate | Low | Low-to-moderate | Low | Little/Moderate
Use of clinical pharmacists to prevent adverse drug events;brief review | Common/Low | Moderate-to-high | Low | High | Little/Moderate
The Joint Commission's “Do Not Use” list; brief review | Common/Low | Low | Negligible | Low | Little/Probably not difficult
Smart infusion pumps; brief review | Common/Low | Low | Low | Moderate | Moderate/Moderate
Infection Control
Barrier precautions, patient isolation, and routine surveillance for the prevention of healthcare-associated infections; brief review | Common/Moderate | Moderate | Moderate (isolation of patients) | Moderate-to-high | Moderate/Moderate
Interventions to improve hand hygiene compliance; brief review | Common/Moderate | Low | Low | Low | Moderate/Moderate
Reducing unnecessary urinary catheter use and other strategies to prevent catheter-associated urinary tract infections; brief review | Common/Moderate | Moderate-to-high | Low | Low | Moderate/Moderate
Prevention of central line-associated bloodstream infections; brief review | Common/Moderate | Moderate-to-high | Low | Low-to-moderate | Moderate-to-difficult/Not difficult (implementation of a “bundle”)-to-moderate (understanding organization culture and context)
Ventilator-associated pneumonia; brief review | Common/High | Moderate-to-high | Low | Low-to-moderate | Moderate/Moderate
Interventions to allow the reuse of single use devices; brief review | Common/Low | Low | Low | Low | A lot/Not difficult
Surgery, Anesthesia, and Perioperative Medicine
Preoperative checklists and anesthesia checklists to prevent a number of operative safety events, such as surgical site infections and wrong site surgeries; in-depth review | Common/Moderate | High | Negligible | Low | A lot/Moderate
The use of ACS-NSQIP report cards and outcome measurements to decrease perioperative morbidity and mortality; in-depth review | Common/High | Moderate-to-high | Low | Moderate | Moderate/Moderate
New interventions to prevent surgical items from being left inside a patient; brief review | Rare/Low | Low | Negligible | Low if it simply involves more frequent manual counting; high if RFID is used | Little
Operating room integration and display systems, such as a centralized display of consolidated data; brief review | Common/Low-to-high | Low | Negligible | Moderate | Moderate/Moderate
Use of beta blockers to prevent perioperative cardiac events; brief review | Common/High | High evidence harms may equal or exceed benefits | High (death, stroke, hypotension, and bradycardia) | Low | NA
Use of real-time ultrasound guidance during central line insertion to increase the proportion correctly placed on the first attempt; brief review | Common/Low-to-moderate | High | Negligible | Low-to-moderate | A lot/Moderate
Safety Practices for Hospitalized Elders
Multicomponent interventions to prevent in-facility falls; in-depth review | Common/Low | High | Moderate (increased use of restraints and/or sedation) | Moderate | Moderate/Moderate
Multicomponent interventions to prevent in-facility delirium; in-depth review | Common/Low | Moderate | Low | Moderate | Moderate/Moderate
General Clinical Topics
Multicomponent initiatives to prevent pressure ulcers; in-depth review | Common/Moderate | Moderate | Negligible | Moderate | Moderate/Moderate
Inpatient, intensive, glucose control strategies to reduce death and infection; in-depth review | Common/Moderate | Moderate-to-high evidence it doesn't help | High (hypoglycemia) | Low-to-moderate | NA
Interventions to prevent contrast-induced acute kidney injury; in-depth review | Common/Low | Low | Negligible | Low | Little/Not difficult
Rapid-response systems to prevent failure-to-rescue; in-depth review | Common/High | Moderate | Low | Moderate | Moderate/Moderate
Medication reconciliation supported by clinical pharmacists; in-depth review | Common/Low | Moderate | Low | Moderate | Moderate/Moderate
Identifying patients at risk for suicide; brief review | Rare/High | Low | Low | Moderate | Little/Moderate
Strategies to prevent stress-related gastrointestinal bleeding (stress ulcer prophylaxis); brief review | Rare/Moderate | Moderate | Moderate (pneumonia) | Moderate | Little/Not difficult
Strategies to increase appropriate prophylaxis for venous thromboembolism; brief review | Common/Moderate | High | Moderate(bleeding) | Low | Little/Moderate
Preventing patient death or serious injury associated with radiation exposure from fluoroscopy and computed tomography through technical interventions, appropriate utilization, and use of algorithms and protocols; brief review | Rare/High | Moderate | Negligible | Low | Moderate/Not difficult
Ensuring documentation of patient preferences for life-sustaining treatment, such as advanced directives; brief review | Common/Moderate | Moderate | Low | Low | Moderate/Moderate
Increasing nurse-to-patient staffing ratios to prevent death; in-depth review | Common/High | Moderate | Low | High | A lot/Not difficult
Practices Designed To Improve Overall System/Multiple Targets
Increasing nurse-to-patient staff ratios to prevent falls, pressure ulcers, and other nursing sensitive outcomes (other than mortality); in-depth review | Common/High | Low | Low | High | A lot/Not difficult
Incorporation of human factors and ergonomics in the design of health care practices by hiring an expert or training clinicians in human factors; in-depth review | Potentially applicable to all patient safety problems | Not assessed systematically, but moderate-to-high evidence for some specific applications | Negligible | Moderate | A lot/Moderate
Promoting engagement by patients and families to reduce adverse events (such as patients encouraging providers to wash their hands); in-depth review | Common | Emerging practice (few studies available) | Uncertain | Low | Little/Moderate
Interventions to promote a culture of safety; in-depth review | Common/Low-to-high | Low | Uncertain | Low–to-moderate (varies) | Moderate/Not difficult-to-moderate (varies with intervention)
Patient safety practices targeted at diagnostic errors; in-depth review | Common/High | Emerging practice (few studies available) | Uncertain | Varies | Varies
Monitoring patient safety problems; in-depth review | Common/Low-to-high | Low | Negligible | High | Moderate/Difficult
Interventions to improve care transitions at hospital discharge; in-depth review | Common/Moderate | Low | Negligible | Moderate-to-high | Little/Difficult
Use of simulation-based training and exercises; in-depth review | Common/Moderate-to-high | Moderate-to-high for specific topics | Uncertain | Moderate | Moderate
Obtaining informed consent from patients to improve patient understanding of potential risks of medical procedures; brief review | Common/Moderate | Moderate | Negligible | Low | Moderate/Not difficult
Team-training in health care; brief review | Common/High | Moderate | Low | Moderate | Moderate/Moderate-to-difficult
Computerized provider order entry (CPOE) with clinical decision support systems (CDSS); brief review | Common/Moderate | Low-to-moderate | Low-to-moderate | High | Moderate/Difficult
Interventions to prevent tubing misconnections; brief review | Common/Moderate | Low | Low | Low | Moderate/Not difficult
Limiting trainee work hours; brief review | Common/Moderate | Low | Moderate (at least); includes lack of training time | High | Moderate/Difficult

Abbreviations: ACS NSQIP=American College of Surgeons National Surgical Quality Improvement Program; NA = not available; PSP: Patient Safety Practice; RFID = radio-frequency identification.

* In some cases, the text in the “PSP” column differs slightly from the chapter heading for that PSP. This difference is attributable to our Technical Expert Panel's desire to include the target safety problem (if the practice is in fact targeted at a specific safety problem), more specification, or an example of the PSP (e.g., adding “such as a centralized display of consolidated data” to the PSP designated as “operating room integration and display systems”).

Rating Scales:

- Scope of the problem targeted by the PSP (frequency/severity): frequency = rare or common; severity = low, moderate, or high.
- Strength of evidence for effectiveness of the PSPs: low, moderate, or high.
- Evidence or potential for harmful unintended consequences: negligible, low, moderate, or high.
- Estimate of cost: low, moderate, or high.
- Implementation issues: How much do we know? = little, moderate, or a lot; How hard is it? = not difficult, moderate, or difficult.

One of the great challenges in measuring patient safety is determining whether to assess primary outcomes (“harms”), intermediate outcomes (“errors”) or processes (such as adherence to evidence-based safety practices). Each of these methods has advantages and disadvantages. Over the past few years, the safety field has increasingly emphasized primary outcomes (namely, harm measures), and the IHI Global Trigger Tool (GTT) has emerged as an increasingly popular method for such assessment. In fact, several studies using the GTT3-5 have come to the same disappointing conclusion: that rates of harm remain high and, at least in a group of North Carolina hospitals, did not improve during the first several years of the patient safety movement. Although the Global Trigger Tool has demonstrated better test characteristics than other outcomes-oriented methods of measuring safety, such as voluntary incident reports and the AHRQ Patient Safety Indicators,3 one of the main insights to have emerged from recent patient safety research is that multiple lenses are needed to get a broad, and true, view of progress in safety. Shojania has called this issue the “elephant of patient safety,” in that one gets a different view depending on what part one is looking at.6

Because of the limitations of outcome measures in patient safety, it is important that we continue to assess the degree to which we now understand and have implemented effective PSPs. The present report, conducted by many of the same investigators, as 2001's “Making Health Care Safer” illustrates both the progress and the challenges in this area of safety research.

Over the past decade, we have achieved greater agreement on what constitutes evidence of effectiveness and the importance of implementation and context (this new understanding was codified in a prior AHRQ report, “Assessing the Evidence for Context-Sensitive Effectiveness and Safety of Patient Safety Practices: Developing Criteria”7 and in the peer-reviewed articles that drew on this report).8-12 In the current review, 20, or about half of the PSPs reviewed, had the strength of evidence for their effectiveness rated as at least “moderate,” which represents significant progress since 2001. The evidence base supporting implementation strategies is also improving. For 26 of the PSPs reviewed in the present report, we judged that there was at least moderate evidence about how to implement the practice; the area of implementation was so underdeveloped a decade ago that “Making Health Care Safer” did not even consider it. However, for almost no PSPs do we understand with confidence the potential role that context plays in effectiveness. This area remains a major gap in our knowledge base about how to select and implement PSPs; and it is a particularly crucial gap as institutions and individuals try to implement “best practices,” and policymakers, accreditors, and payers seek to create incentives for implementation via transparency- or payment-related initiatives.

### Priorities for Adoption of Patient Safety Practices

We identified sufficient evidence about effectiveness and implementation for our technical experts to judge that some PSPs are ready to be “strongly encouraged” for adoption by health care providers. Table 2 shows the “strongly encouraged” PSPs. For particular targets for which we discussed multiple PSPs, (such as catheter-associated urinary tract infection), the table describes a particular PSP or category of PSPs.

Table 2, Chapter 44 Strongly encouraged patient safety practices

- Preoperative checklists and anesthesia checklists to prevent operative and post-operative events; - Bundles that include checklists to prevent central line-associated bloodstream infections; - Interventions to reduce urinary catheter use, including catheter reminders, stop orders, or nurse-initiated removal protocols; - Bundles that include head-of-bed elevation, sedation vacations, oral care with chlorhexidine, and subglottic-suctioning endotracheal tubes to prevent ventilator-associated pneumonia; - Hand hygiene; - “Do Not Use” list for hazardous abbreviations; - Multicomponent interventions to reduce pressure ulcers; - Barrier precautions to prevent healthcare-associated infections; - Use of real-time ultrasound for central line placement; - Interventions to improve prophylaxis for venous thromboembolisms

The conclusions in this report explicitly represent a combination of the available evidence with the judgment of our technical expert panelists interpreting that evidence.

Additional PSPs were judged by our technical experts as having sufficient evidence about effectiveness and implementation that they should be “encouraged” for adoption. Table 3 presents the “encouraged” PSPs.

Table 3, Chapter 44 Encouraged patient safety practices

- Multicomponent interventions to reduce falls; - Use of clinical pharmacists to reduce adverse drug events; - Documentation of patient preferences for life-sustaining treatment; - Obtaining informed consent to improve patients' understanding of the potential risks of procedures; - Team training; - Medication reconciliation; - Practices to reduce radiation exposure from fluoroscopy and computed tomography scans; - Use of surgical outcome measurements and report cards, like the American College of Surgeons National Surgical Quality Improvement Program; - Rapid response systems; - Utilization of complementary methods for detecting adverse events/medical errors to monitor for patient safety problems; - Computerized provider order entry; - Use of simulation exercises in patient safety efforts

The 22 PSPs in Tables 2 and 3 represent practices that health care providers can consider for adoption now. This recommendation particularly applies to the 10 “strongly encouraged” practices in Table 2, which, at least in the judgment of our technical experts, providers have sufficient knowledge to implement and doing so will likely result in safer care. And while future evaluations will probably strengthen our knowledge base regarding how best to implement these practices to make them most effective, our technical experts believe that providers should not delay consideration of adopting these practices while waiting for more research: enough is known now to permit health care systems to move ahead.

## Limitations

Because of limited resources and time, the current report does not cover the entire patient safety field, which has grown exponentially since the last report, both in the number of potential PSPs and in the amount of data about individual PSPs). We used an explicit and transparent process to select the PSPs we did evaluate, and our final list should include most PSPs of highest priority to policymakers and providers.

Secondly, we did not do in-depth reviews of all the PSPs. Again, in order to make the best use of the available time and resources, we tailored our methods to the needs of our stakeholders, targeting those PSPs of greatest interest (or for which there was perceived to be the most new information) for in-depth reviews; others received briefer reviews. It was crucial that the decisions about which PSPs would receive in-depth review and which would receive brief review were made by a broadly representative stakeholder committee. The in-depth reviews, while thorough, did not conform to all of the criteria in the 2011 IOM report, “Finding What Works in Health Care: Standards for Systematic Reviews,”13 nor all the criteria in the EPC Methods Guide (for example, we did not publicly post a protocol for each individual review). We used our collective experience as EPCs to adapt existing EPC methods that we judged best preserved the essence of a systematic review while allowing us to complete 18 in-depth reviews within 9 months and the available budget.

Additionally, over time, we will likely improve our methods for assessing evidence regarding how patient safety interventions affect health care processes and outcomes. The methods we used for this report incorporate new perspectives regarding the importance of implementation and context, which was the focus of the “Context Sensitivity” report; likewise, in the future, we can expect to increase our understanding of the interactions between multiple intervention, implementation, and organizational variables and how these influence safety outcomes. If future research reveals that these variables interact in ways that our current understanding of theory and logic models cannot explain, we will need to modify the methods of evaluating PSPs again.

Lastly, we relied on the judgment of our technical experts at every important step of the project: Therefore our results are as much a product of these judgments as of our systematic review methods. Hence, our results might be sensitive to the selection of particular experts on our technical expert panel. However, we mitigated this potential bias by including more than double the number of experts on our technical expert panel as we typically would for an EPC review, which allowed us to include a diverse set of stakeholders from the U.S., Canada, and the United Kingdom; from PSP developers and evaluators to patient safety policymakers to experts in design and evaluation methods. Rather than regarding the tight linkage between the needs of the stakeholders and the work of the EPCs as a limitation, we view it as a strength that increases the likelihood that the results of the review will be meaningful to providers, payors, and patients, and that the report's results will lead to meaningful change.

## Conclusions

In 2001, when we published “Making Health Care Safer,” the literature on PSPs was limited, for several reasons.

First, the dominant cognitive model for patient safety was that errors represented human lapses; thus, there seemed little to study. The key PSP, one might say with only slight hyperbole, was to admonish caregivers to be more careful next time.

Moreover, no business case existed for institutions or individuals to focus on patient safety, no public pressure was exerted to improve safety, and no research funding was available for safety studies. The fact that the literature on safety was relatively primitive was anything but surprising.

This picture changed completely over the ensuing decade. AHRQ's Patient Safety Network, the organization's main portal for safety literature, now lists more than 3000 research studies, with 400 of these deemed by the editors as “Classics.” Safety research receives substantial support from AHRQ and others, the business case for safety improvement has grown, and policymakers are intensely interested in safety research as they consider what they can do to promote safety.

We found evidence of this progress in our current review of the literature on patient safety. There are now over a dozen practices for which the evidence of effectiveness is strong or very strong, and data are emerging on the contextual factors that so often determine the outcome of implementation. With the Federal investment in safety (under the “Partnership for Patients”) of about $1 billion, and an investment of more than 20 times that amount in information technology implementation, we are on the cusp of an exploding database of research on safety practices.

Yet recent studies of rates of harm have demonstrated how difficult improving safety really is and have caused policymakers and researchers to redouble their efforts to identify and implement safe practices in hospitals, nursing homes, and clinics. Individuals and institutions seeking to improve safety would do well to scrutinize the practices described in this report—widespread implementation is likely to save hundreds, if not thousands, of lives. It will also help us continue to refine our efforts to identify the factors associated with successful implementation of PSPs, and to pinpoint, and hopefully prevent, any unintended consequences.

## Future Research Needs

Our technical expert panel judged the following topics to be high priority for future research:

General issues:

- Sufficient data about the costs of PSPs to support cost-effectiveness analyses or return-on-investment analyses
- More patient safety measures for ambulatory care
- Better measures of the major causes of harm

Specific PSPs that are the highest priority for future research:

- Interventions to improve care transitions at hospital discharge
- Medication reconciliation
- Multicomponent interventions to reduce falls
- Simulation methods
- Team training
- Use of human factors engineering and ergonomics in the design of health care practices
- Surgical outcome report cards
- Systems and decision aids to reduce diagnostic errors
- Measures to encourage a culture of patient engagement in patient safety

Some PSPs were not included in this review because they were not deemed sufficiently developed, and new PSPs will subsequently be developed. Thus a strategy of surveillance should be adopted regarding evidence on PSPs. Future research also requires advancing the “basic science” of safety measurement such as standardized methods for rare events and for evaluating studies that assess only process-related outcomes relative to those that assess patient outcomes.

### Future Research Needs Specific to Context Sensitivity

As part of our project on developing criteria to assess context sensitive PSPs, we worked with this same panel of technical experts to determine future research needs with respect to context. They bear repeating here.

1. Developing and validating measures of patient safety culture. Discussion at the panel meetings indicated that several technical experts considered patient safety culture to be the overarching important construct. This view may explain why patient safety culture received majority support as a high priority for future research, whereas research on leadership and teamwork measures did not. Specific suggestions for future research included:
  a. Developing validated measures of cultural adaptability to change.
  b. Assessing the potential distinction between a culture of safety, a culture of excellence, and organizational culture.
  c. Establishing connections between aspects of patient safety culture and patient outcomes or processes of care.
  d. Assessing correlations between measures.
  Additionally several TEP members commented that teamwork and leadership are important concepts for which several measures are currently available. Several TEP members felt researchers should use these measures working to mature and build the evidence about this construct.
2. Developing criteria and recommendations for what constitutes “reporting the intervention in sufficient detail that it can be replicated.” More precise criteria for how PSP interventions should be described warrant additional research. In particular, the guidance described here, along with that provided by Standards for Quality Improvement Reporting Excellence (SQUIRE) and the National Quality Forum (NQF), need to be evaluated. Doing so will help determine which PSP elements need to be described and in what detail in order to evaluate whether the PSP is truly effective. This also will help maximize the possibility of successful PSP replication with similar outcomes. Further research could also evaluate the effect of applying these draft criteria regarding PSP descriptions on the quality of PSP projects and published articles. Thoroughly describing PSPs also can help readers determine the relevance of an evaluation study to other PSPs or other contexts. For example, if a PSP requires an individual behavior change such as hand-washing, then knowing intervention details may help readers of the study assess whether the given results are relevant only to hand-washing interventions or if they could be applied to other types of PSPs requiring individual behavior change. Knowing the details of the intervention also could help readers of the study determine how much the success of the PSP implementation depended on contextual issues (e.g., organization or teamwork).
3. Understanding the important items to measure and report on for implementation. Experts consider having comprehensive information about implementation key to being able to replicate a PSP. However, little empirical evidence exists about what makes a description of the PSP adequate for reporting. Assessing what implementers need to know, if they are to be able to implement or adapt an intervention in their own settings, is critical. Most experts considered “understanding the important items to measure and report on for implementation” to be related to or even the same as “reporting the intervention in sufficient detail that it can be replicated.” This view suggests that the distinction between “the intervention” and “the implementation” may be an arbitrary line, and that ideal evaluations of PSP interventions need to consider the implementation as part of the intervention.
4. Developing a theory-based taxonomy or framework with which to describe and evaluate key elements of interventions, contexts, and targeted behaviors. Although the current project made a promising start on meeting this need, progress in this area will require additional development to produce a taxonomy that would be both sufficiently broad based and flexible enough to be widely useful. Issues to be considered include whether a taxonomy is the preferable way to proceed, or whether a more useful strategy might be to create an explicit methodology that researchers could apply to specific problems and contexts. Yet another approach might be to devise an “assessment framework.” Some experts sounded cautionary notes on this topic. They reported that outpatient PSP research may be too new to apply a taxonomy at this stage. They also reported that a single “unified” taxonomy may not be sufficiently flexible for diverse PSPs, and multiple taxonomies may be needed in any case. The countervailing view to these cautionary notes was that the field would not be well-served by having a proliferation of taxonomies. Instead, they reported, what is needed is a coherent, sufficiently comprehensive taxonomy that can accommodate the challenges of the subject.
5. Refining a framework for assessing the strength of a body of evidence. The research team did developmental work on an adaptation of the GRADE and Evidence-based Practice Center (EPC) systems for assessing the strength of evidence across studies of a PSP. This work warrants further development.
6. Generating empirical evidence that the contextual factors identified in this project influence the success of the PSP. The research team acknowledges that most of the recommendations in the report have a thin empirical evidence base, which simply reflects the relatively immature state of research in this still relatively young field. Building a stronger evidence base will help future efforts at refining the recommendations presented here.

### Future Methodological Needs

Despite over a decade of effort, there is little evidence that patient outcomes (broadly measured) have significantly improved. Yet there have been patches of success, generally focused on efforts to reduce one type of harm, usually using one method of improvement. For example, efforts have focused on reducing blood stream infections, improving teamwork, or enhancing patient engagement.

If health care is to make significant improvements in patient safety, research should inform and guide these efforts, just as it has done in every other field. We have learned much about how to improve safety, yet we need to learn much more. Acquiring this knowledge will require investments in patient safety research, including “basic” methodological research. To date, investments in patient safety research have fallen far short of the magnitude of the problem.

To achieve progress in improving patient safety, research is needed in a number of areas:

- “basic” patient safety research to develop new tools and measures and ensure that the tool matches the problem;
- a larger number of valid measures of patient safety;
- better methods to measure context and how an intervention was implemented;
- methods to identify and provide the necessary skills, resources, and accountability (i.e., a safety management infrastructure) at each level of the health care system; and
- more effective and less burdensome methods of improvement so that clinicians, researchers, and administrators work on reducing all types of harms patients are at risk of suffering rather than a select few. Below we briefly discuss each of these.

Basic patient safety research. Largely driven by an appropriate desire to reduce patient harm from medical errors immediately, the field has often invested in quick fixes that may have lacked sufficient theory or validated evaluation tools. For example, although the need to evaluate context when implementing patient safety interventions is widely recognized, few validated instruments have been developed to accomplish this task. Just as the hundreds of thousands of deaths from heart disease or cancer each year inspire rather than obfuscate the need for basic research, so too should the large number of deaths from preventable harm. To improve patient safety, the Federal Government will need to invest in “basic” patient research, to diagnose different types of safety problems, to match the theories and methods to the type of problem, to better evaluate implementation efforts and their surrounding context, and to evaluate whether patient safety is indeed improving

The future research needed to advance the science of basic patient safety research was covered in “Context Sensitivity,”7 where this technical expert panel rated as highest priority topics such as “development of a theory-based taxonomy with which to describe and evaluate key elements of interventions, contexts, and targeted behaviors” and “understanding the important items to measure and report in implementation.”

Larger number and more valid tools to measure safety. Despite more than a decade of effort, the health care system remains unable to quantify the magnitude of preventable harm or to use valid tools to evaluate progress in improving patient safety over time or among provider organizations. Moreover, for most of the patient safety harms discussed in this report, the field lacks valid, broadly accepted definitions for—and the mechanisms to monitor—progress in reducing patient harm. Thus, despite significant efforts to improve patient safety over the last decade, no one—including patients, providers, researchers, payors, and policymakers—knows whether care is safer. The need for evaluation tools is urgent.

Better methods to measure context and to describe an intervention. In contrast to most clinical research interventions, patient safety interventions are iterative, evolve over time, are context dependent, and are strongly influenced by the organizations in which they are implemented and the personnel involved. Both this report and “Context Sensitivity” have demonstrated that too often, the intervention is insufficiently described and the context is barely mentioned; the result is stalled learning and reduced generalizability. Research is needed to better understand how an intervention was implemented over time, the most salient iterations the intervention has undergone, and the critical contextual domains that may have supported or mitigated the improvement effort. For example, while leadership and teamwork are widely regarded as important in implementing patient safety interventions, the field lacks consensus both on how best to measure these domains and on a theory that explains how various domains of context support or hinder the success of an intervention.

The topics “more patient safety measures for ambulatory care” and “better measures of the major causes of harm,” which were judged as high priority by our technical expert panel, fall into this domain.

Methods to build a safety management infrastructure. Health care is largely organized around the care of individual patients, yet patient safety requires the management of populations of patients and accountability for complications. While physicians have profound individual accountability for their patients, especially for complications that are directly related to their care, their accountability often diminishes for complications less directly related to the care they provide, or complications that are influenced by the care of a care team or how care is organized; infections are an example of such complications.

If patient safety requires the management of a population of patients, an infrastructure should be in place to help monitor risks and prioritize interventions, to implement interventions, and to monitor progress. At multiple levels of a provider organization (clinic or unit; department or region; hospital or group practice), an infrastructure is needed to ensure that safety leaders have sufficient resources, skills, and accountabilities to improve safety. Little is known regarding the specifics of the infrastructure that is needed. Nevertheless, the existing infrastructure is largely underdeveloped.

Specifically, researchers and managers must determine how much physician, nurse, and other staff support are needed at each unit/clinic, department/groups of clinics, hospital/health system levels to ensure patient safety; what skills they need, and how they should be held accountable for the safety of the care provided. For example, if an employee's job is to evaluate progress in patient safety, does he require training in clinical epidemiology? If an employee's job is to implement interventions, does she require training in human factors engineering and implementation science? Finally, how will managers and researchers create a cascading accountability system in which unit and clinical leaders hold individual clinicians accountable, department or regional leaders hold unit/clinical leaders accountable, and hospital or health systems leaders hold department and regional leaders accountable. Although this type of infrastructure exists in other industries, little is known about its benefits and costs. Investments are needed to understand, implement, and evaluate a safety management infrastructure in health care.

The topic, “more data about the costs of patient safety practices,” which was judged high priority by our technical expert panel, falls into this domain.

More effective and efficient system interventions to reduce multiple, rather than single types of harm. Our technical expert panel strongly advocated for a systematic approach to preventing harm and exploring the concept of mutually reinforcing practices that reduce many kinds of harm.

The Center for Medicare and Medicaid Services (CMS) is now embarking on an ambitious national effort to reduce 10 types of preventable harm. However, because of the burden of implementing the interventions, hospitals are generally selecting interventions to reduce only a subset of the harms. Yet most patients are at risk for all 10 harms and many others as well.14

In health care, too many improvement efforts rely on the heroism of clinicians rather than safely designed systems. In other industries, as the amount of information has increased, technological improvements are implemented, with the result that productivity and safety increase. Health care productivity remains flat and clinicians use technologies that generally do not talk to each other. For example, the infusion pump does not talk to a respiratory monitor. If such intercommunication occurred, a respiratory monitor would automatically shut off an infusion pump if a patient developed a dangerously low respiratory rate from an infusion of narcotics, a common cause of respiratory arrest. Preciously few examples exist of safe design in health care. Such an approach will require close collaboration with systems engineers.

Patient harms do not occur in isolation, and they are not independent. Rather, they are interdependent; thus, the solutions must be as well. Hospitalized patients are at risk for multiple complications. For example, a patient on a breathing machine after surgery is at risk for 9 of the 10 complications targeted for reduction by CMS (the tenth, which is an obstetric complication, would not apply in this case).

Complex patients suffer the same fate. Because these patients have a variety of chronic diseases, they are at risk for a variety of harms, yet few efforts have been undertaken to systematically reduce the risk for all types of harm.

Yet there is an alternative. Health care could more fully embrace systems engineering. The need to develop and demonstrate a system framework that addresses the universal and fundamental challenges in contemporary health care delivery remains a critical challenge. In the 2005 report, “Building a Better Delivery System–A New Engineering/Health Care Partnership,” the National Academy of Engineering (NAE) and the IOM noted:

a systems approach to healthcare delivery could transform the U.S. health care sector from an underperforming conglomerate of independent entities into a high-performance system in which every participating unit recognizes its interdependence and influence on every other unit…

Ideally, the new and improved health care delivery system should include: 1) an integrated, ubiquitous, distributed, responsive, expansive, flexible, affordable and resilient system; 2) personalized delivery facilitated by secure information flow and optimized information that runs smoothly, efficiently, and safely.

The IOM/NAE report highlighted the observation that health care is significantly under-engineered and called for greater input from systems engineers to make health care safer. Future research in patient safety needs to take a systems approach, focusing on all the harms a patient suffers, clarifying the therapies that may reduce harm, and ensuring that patients always receive them. This research could include three key areas: a focus on engaging patients and their families, ensuring patients receive therapies to reduce harm, and creating a learning and accountability system. Few examples of successful collaboration between engineering and medicine currently exist. One example of such a collaboration is the Systems Engineering Initiative for Patient Safety (SEIPS) program at the University of Wisconsin-Madison, which brings human factors and systems engineers together with clinicians to work on solving complex patient safety problems.15 This model, developed by Carayon, views the work system as an interaction among people, tasks, tools and technologies, organization, and environment. Another example, occurring at Johns Hopkins University, involves a collaboration with the Johns Hopkins University Whiting School of Engineering, Applied Physics Laboratory, the School of Medicine, the Bloomberg School of Public Health, the Carey Business School, the School of Nursing, and the private sector. The purpose of this collaboration is to develop a model to eliminate preventable harm.

As a part of these collaborations, clinicians and researchers are exploring ways to apply systems engineering to patient safety. For example, providers might consider all potential harms of being hooked up to a breathing machine. The resulting list includes 9 of the 10 harms enumerated by CMS and several more, including patient-centered harms from loss of dignity, autonomy, and respect. The clinicians and engineers would then consider the tasks or treatments to prevent those harms and the barriers to performing those tasks and ultimately design a system that ensures patients receive the recommend therapies and monitors and improve performance.

For example, clinicians could be provided visual displays indicating when a treatment is due and when it has been completed. As discussed above, at present, few of the technologies responsible for care processes are integrated: these technologies, which include the medical devices including the bed, the ventilator, the infusion pump, the monitors, and the electronic health record, do not communicate. Research into how to better integrate systems engineering into health care could help improve safety and allow clinicians and managers to work on preventing all types of patient harm.

A part of adopting a systems approach dictates including patients and their families. Patients and their families are an integral part of the health care system, yet often, are not adequately engaged or provided with sufficient information. Future research needs to explore how best to engage and activate patients to help improve safety and how best to view patients as an integral part of the health care system.

Efforts to improve patient safety are often fragmented into specific clinical or academic disciplines. While each approach and method is necessary, it is unlikely any one, by itself, will be sufficient to address the entire patient safety problem and reduce all types of harms. These “systems” approaches that link clinicians, human factors and systems engineers, social scientists, health services researchers, informatics specialists, economists, and biostatisticians, offer hope for realizing broad improvements in patient safety. Although such diverse groups pose management challenges, they have enormous potential to rebuild the health care chasse, which remains largely broken. If we are to make progress, science must guide us, an endeavor that will require investments in patient safety research. The research agenda outlined above may point health care in the right direction.

## References

1 Kohn L, Corrigan J, Donaldson M, et al. To Err is Human: Building a Safer Health System Committee on Quality of Health Care in America, Institute of Medicine. Washington, DC. Press NA. 2000.
2 Shojania KG, Duncan BW, McDonald KM, et al. Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ). 2001;(43):i-x. 1. 668. [pmid: 11510252].
3 Classen DC, Resar R, Griffin F, et al. ‘Global trigger tool’ shows that adverse events in hospitals may be ten times greater than previously measured. Health Aff (Millwood). Apr. 2011;30(4):581-9. [pmid: 21471476].
4 Landrigan CP, Parry GJ, Bones CB, et al. Temporal trends in rates of patient harm resulting from medical care. N Engl J Med. Nov. 25. 2010;363(22):2124-34. [pmid: 21105794].
5 Levinson DR. Office of Inspector General. Adverse Events in Hospitals: National Incidence Among Medicare Beneficiaries. Department of Health and Human Services. November. 2010.
6 Shojania KG. The elephant of patient safety: what you see depends on how you look. Jt Comm J Qual Patient Saf. Sep. 2010;36(9):399-401. [pmid: 20873672].
7 Shekelle PG, Pronovost PJ, Wachter RM, et al. Assessing the Evidence for Context-Sensitive Effectiveness and Safety of Patient Safety Practices: Developing Criteria. Contract Final Report. AHRQ Publication No. 11-0006-EF. December. 2010. Prepared under Contract No. HHSA-290-2009-10001C. Agency for Healthcare Research and Quality. Rockville, MD. www.ahrq.gov/qual/contextsensitive/.
8 Foy R, Ovretveit J, Shekelle PG, et al. The role of theory in research to develop and evaluate the implementation of patient safety practices. BMJ Qual Saf. May. 2011;20(5):453-9. [pmid: 21317181].
9 Ovretveit JC, Shekelle PG, Dy SM, et al. How does context affect interventions to improve patient safety? An assessment of evidence from studies of five patient safety practices and proposals for research. BMJ Qual Saf. Jul. 2011;20(7):604-10. [pmid: 21493589].
10 Shekelle PG, Pronovost PJ, Wachter RM, et al. Advancing the science of patient safety. Ann Intern Med. May. 17. 2011;154(10):693-6. [pmid: 21576538].
11 Dy SM, Taylor SL, Carr LH, et al. A framework for classifying patient safety practices: results from an expert consensus process. BMJ Qual Saf. Jul. 2011;20(7):618-24. [pmid: 21610267].
12 Taylor SL, Dy S, Foy R, et al. What context features might be important determinants of the effectiveness of patient safety practice interventions?. BMJ Qual Saf. Jul. 2011;20(7):611-7. [pmid: 21617166].
13 Committee on Standards for Systematic Reviews of Comparative Effectiveness Research, Institute of Medicine. Finding What Works in Health Care: Standards for Systematic Reviews. The National Academies Press. 2011.
14 Pronovost PJ, Bo-Linn GW. Preventing patient harms through systems of care. JAMA. Aug. 22. 2012;308(8):769-70. [pmid: 22910751].
15 Carayon P, Schoofs Hundt A, Karsh BT, et al. Work system design for patient safety: the SEIPS model. Qual Saf Health Care. Dec. Suppl 1. 2006;15:i50-8. [pmid: 17142610].