# Limiting Individual Providers' Hours of Service: Brief Update Review

## Introduction

Long and unpredictable work hours have been a staple of medical training for centuries, but the effects of fatigue among residents on patient safety garnered little attention until March 1984, when a young woman died at a teaching hospital in New York. Her death was attributed in part to a medication prescribing error made by residents in the midst of a 36-hour shift. This seminal event led to the passage of regulations in the State of New York limiting residents' shift duration to 24 consecutive hours and overall work week to 80 hours. However, at the time of the original Making Health Care Safer1 report in 2001, widespread violations of the New York regulations were common, and it was not unusual for residents still to work 36 hour shifts and over 100 hours per week in other states as well).

A considerable body of evidence from health care and other industries2 links acute and chronic sleep deprivation to impaired cognitive performance. Some studies have also shown that sleep deprivation can affect psychomotor skills.3 Working extended duration shifts can be harmful for both clinicians and patients. Studies have shown that residents who work more than 16 consecutive hours have an increased risk of motor vehicle accidents after their shift4 and of suffering a needlestick injury during their shift.5 Working over 16 consecutive hours in the intensive care unit has been shown to result in interns committing more diagnostic and therapeutic errors.6 Among nurses, shift duration of greater than 12 hours is also associated with a significantly increased risk of committing errors.7 In response to these and other data, the Accreditation Council for Graduate Medical Education (ACGME) implemented formal work hour restrictions for resident physicians in 2003, and made these regulations even more stringent in 2011.^8^

Despite these known risks, the extent to which patients are harmed by clinician fatigue is difficult to determine. Fatigue on the part of an individual provider may only be one of several latent causes of a preventable adverse event, especially in the complex hospital environment. Few studies have attempted to directly address the connection between clinician fatigue and adverse clinical outcomes. Two recent studies9,10 examined whether attending surgeon's fatigue was linked to an increased risk of complications, and reached conflicting results; one study10 found an increased risk of complications when the surgeon had the opportunity to sleep for less than 6 hours the night prior to the procedure, but the other9 did not find the same association.

Despite the lack of hard data linking fatigue and complications, the traditional residency work hours that existed prior to 2003 could not be justified from an educational, humanistic, or patient safety standpoint. The implementation of regulations to reduce residents' work hours have resulted in fundamental changes to residency education over the past decade, and the regulations' effect on patient safety has been extensively studied.

The 2001 report reviewed the evidence linking sleep deprivation and fatigue to medical errors, and reached four conclusions:

- “Sleep deprivation and disturbances of circadian rhythm lead to fatigue, decreased alertness, and poor performance on standardized testing.”
- “Although data from non-medical fields suggest that sleep deprivation leads to poor job performance, this link has not yet been established in medicine.”
- “Forward rather than backward shift rotation [i.e., progressing from day to evening to night shifts, rather than the reverse], education about good sleep hygiene, and strategic napping before or during shifts may reduce fatigue and improve performance. High face validity, low likelihood of harm, and ease of implementation make these promising strategies, although more evidence of their effectiveness in medicine is warranted.”
- “Given that medical personnel, like all human beings, probably function suboptimally when fatigued, efforts to reduce fatigue and sleepiness should be undertaken, and the burden of proof should be in the hands of the advocates of the current system to demonstrate that it is safe.”

In this review, we assess the evidence that has accumulated since 2001 for the effect of limiting individual providers' hours of service on patient safety outcomes. Although other countries have significantly more stringent regulations (for example, trainees in the European Union are limited to 48 hours per week), the focus of this review will be on studies conducted in the United States.

## What Efforts Have Been Made To Reduce Clinician Work Hours?

Specific attempts have been made to reduce clinician work hours in order to improve safety by minimizing fatigue. The vast majority of the research in this area pertains to resident physicians in the United States. In 2003, the ACGME passed regulations intended to significantly reduce work hours for trainees. These regulations included four principal components:

- A maximal limit of 80 hours worked per week
- No more than 24 consecutive hours on duty (an additional 6 hours were allowed to ensure safe transitions of care, meaning that residents could work a maximum of 30 consecutive hours)
- “On-call” frequency of no more than once every 3rd night
- At least 4 days off per month

These regulations became effective on July 1, 2003 (some specialties received partial exemption from the regulations). Since that date, the effect of the regulations has been intensively studied, and forms the largest body of evidence specifically addressing the patient safety effects of reducing individual providers' hours of service.

## What is the Context for Current Efforts To Reduce Work Hours?

The Institute of Medicine issued a report11 in 2008 that took into account the initial data on the effect of the 2003 ACGME regulations, as well as the evolving evidence base in the area of fatigue and performance. The IOM's recommendations included the following:

- Continued maximal limit of 80 hours per week
- No more than 16 consecutive hours on duty, after which residents must be off duty completely or provided 5 hours of protected sleep time
- No more than 4 consecutive night shifts
- 1 full day off per week, and 1 full weekend off per month

The revised resident duty hour regulations published by the ACGME in 2010, and implemented July 1, 2011, did not incorporate all of the IOM's recommendations. The 2011 regulations have four key components:

- Continued 80-hour work week limit
- No more than 16 consecutive hours on duty for first-year residents only. Second-year and more senior residents can work 24 hours on duty, with an additional 4 hours allowed for transitions of care
- No more than 6 consecutive night shifts
- Continued minimum of 4 days off per month and on-call frequency of no more than once every 3rd night

Although excessive work hours are linked to errors among nurses, regulation of nurses' work hours is less uniform. Currently, 16 states do restrict mandatory overtime for nurses, but many nurses still routinely work more than 12 hours per shift.7 There are also no regulations on working hours for practicing physicians, despite some data indicating that many practicing physicians work schedules that would be prohibited were they still residents.12

## What Have We Learned About Limiting Physician Work Hours?

### Recent Reviews and Systematic Evaluations

Multiple systematic reviews have addressed the patient safety effects of reducing shift length for residents. One systematic review that included only studies of the effect of the 2003 ACGME regulations13 identified 20 studies that assessed mortality and 24 studies that assessed other patient safety outcomes before and after implementation of the regulations. Meta-analysis of the mortality studies did show a statistically significant decline in mortality after 2003 (OR 0.9, 95% CI 0.84 – 0.95), which was consistent in studies examining either medical or surgical patient populations. However, considerable unexplained heterogeneity was present (I^2^=83%), and the subset of studies that used a contemporaneous control group of non-teaching hospitals generally did not find a difference in mortality. The authors acknowledged that as they were unable to control for secular trends or changes in patient characteristics, the mortality improvement could be due to overall improvement in the quality of care during the time period studied. The studies examining patient safety outcomes yielded mixed results, with no clear pattern of improvement or worsening across studies.

Another review14 identified 36 studies that examined the association between reduced trainees' working hours and patient outcomes. This study also included studies performed outside the U.S.. The conclusions were largely similar to that of the previous review: Mortality and patient safety outcomes appeared unchanged after implementation of duty hour limits. Both reviews found that limiting work hours appeared to improve residents' quality of life.

The question of why patient safety outcomes have not improved after reducing resident work hours is a subject of intense debate. Reduced shift length almost certainly led to greater discontinuity among providers, and the resultant handoffs of care may have had deleterious effects on patient safety. Adherence to work hour limitations was (and is) likely suboptimal.15,16 In addition, studies have shown that changing residents' work schedules to meet the regulations did not actually result in residents sleeping more.17 Finally, although resident quality of life improved, in some studies objective measurements of burnout and depression among residents did not change.18 Burnout and depression are themselves linked to impaired job performance, independent of acute or chronic fatigue.19

The 2003 duty hour regulations still allowed all residents to work a maximum of 30 consecutive hours. These extended duration shifts are still longer than those allowed in virtually any other industry, and studies have found an association between working more than 16 consecutive hours and an increased risk of self-reported errors and attentional failures.20 A 2010 systematic review21 that identified 13 studies in which shift length for clinicians was purposefully reduced found consistent evidence among the higher-quality studies that both objectively-measured and self-reported errors decreased after shift length reduction. One particularly high quality study6 found a significant reduction in serious medical errors for medical interns assigned to work a 16-hour shift in the intensive care unit, compared with interns working a traditional 30-plus hour shift. However, the reviewers were unable to reach a firm conclusion regarding the optimal shift length, due to heterogeneity between shift lengths used in the primary literature.

Thus, the totality of the evidence on the 2003 ACGME duty hour regulations indicates that reducing resident duty hours does not improve—or worsens—patient safety or mortality. The association between extended duration (>16 hour) shifts and adverse events ultimately was a factor in the ACGME's decision to enact a 16-hour shift length limit for first-year residents as part of the 2011 regulations.

### New Studies for Effectiveness of the Patient Safety Practices

As the ACGME's latest regulations were implemented earlier this year, no further data are available in addition to those summarized above.

#### Potential for Harm

The greatest potential harm of work hour regulations is an increase in adverse events due to increased handoffs of care between providers. Although this association is certainly plausible, and handoffs have unquestionably increased after both the 2003 and 2011 regulations, studies have not specifically examined whether errors attributable to handoffs have increased after the regulations were implemented.

The other oft-cited adverse consequence of duty hour reduction is decreased clinical experience for trainees, limiting their ability to practice independently once training is completed. Studies of the 2003 duty hour regulations generally did not find that objective clinical experience worsened, when measured by criteria such as surgical case volume. However, both faculty22,23 and residents24 have voiced concerns that duty hour regulations have actually compromised their educational experience, and most residents25 appear unconvinced that further duty hour reductions will improve either patient safety or their educational experience.

#### Costs and Implementation

Implementing the 2011 ACGME regulations is likely to be extremely costly for teaching hospitals. A 2011 cost-effectiveness analysis26 estimated that implementing the new ACGME regulations would cost teaching hospitals $1.6 billion if the decreased workload of interns was replaced entirely by attending physicians, and $1.34 billion if interns were replaced by physician extenders (nurse practitioners or physician assistants). A 7.2% decrease in preventable adverse events would be required in order to make the regulations cost-neutral to society, but teaching hospitals would still encounter considerable costs. The expenses associated with the need to replace the housestaff workforce with alternative providers and the need to provide greater supervision for residents by senior physicians is likely to be considerable.

## Conclusions and Comment

Sleep deprivation and fatigue have clear deleterious consequences for patients and providers. However, the most prominent effort to improve patient safety by reducing fatigue—limiting the work hours of resident physicians—has not yielded the expected benefits. It is conceivable that the 2003 ACGME duty hour regulations were simply not stringent enough, given that extended duration shifts were still permitted and those shifts are associated with preventable adverse events. Alternatively, it may be that advocates underestimated the complexity of the relationship between duty hours and safety, or the detrimental impact of handoffs. The 2011 regulations further restrict hours, particularly for first-year residents. The effects of these new regulations are as yet unknown, and unfortunately, the existing evidence does not offer us great clarity regarding the optimal work hour structure that would improve safety by decreasing clinician fatigue with minimal potential for unintended consequences. A summary table is located below (Table 1).

Table 1, Chapter 43 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Moderate | Low | Moderate (at least) Includes lack of training time | High | Moderate/Difficult

## References

1 Shojania KG, Duncan BW, McDonald KM, Wachter RM, Markowitz AJ. Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ). 2001:i-x. 1. 668.
2 Philibert I. Sleep loss and performance in residents and nonphysicians: a meta-analytic examination. Sleep. 2005;28:1392-402. [pmid: 16335329].
3 Weinger MB, Ancoli-Israel S. Sleep deprivation and clinical performance. JAMA. United States. 2002:955-7. [pmid: 11866625].
4 Barger LK, Cade BE, Ayas NT, et al. Extended work shifts and the risk of motor vehicle crashes among interns. N Engl J Med. United States: 2005 Massachusetts Medical Society. 2005:125-34. [pmid: 15647575].
5 Ayas NT, Barger LK, Cade BE, et al. Extended work duration and the risk of self-reported percutaneous injuries in interns. JAMA. United States. 2006:1055-62. [pmid: 16954484].
6 Landrigan CP, Rothschild JM, Cronin JW, et al. Effect of reducing interns' work hours on serious medical errors in intensive care units. N Engl J Med. United States: 2004 Massachusetts Medical Society. 2004:1838-48. [pmid: 15509817].
7 Rogers AE, Hwang WT, Scott LD, Aiken LH, Dinges DF. The working hours of hospital staff nurses and patient safety. Health Aff (Millwood). 2004;23:202-12. [pmid: 15318582].
8 Nasca TJ, Day SH, Amis ES Jr. The new recommendations on duty hours from the ACGME Task Force. N Engl J Med. United States. 2010:e3. [pmid: 20573917].
9 Chu MW, Stitt LW, Fox SA, et al. Prospective evaluation of consultant surgeon sleep deprivation and outcomes in more than 4000 consecutive cardiac surgical procedures. Arch Surg. United States. 2011:1080-5. [pmid: 21576596].
10 Rothschild JM, Keohane CA, Rogers S, et al. Risks of complications by attending physicians after performing nighttime procedures. JAMA. United States. 2009:1565-72. [pmid: 19826026].
11 Medicine. Io. Resident Duty Hours: Enhancing Sleep, Supervision, and Safety. Washington, DC. The National Academies Press. 2009.
12 Anim M, Markert RJ, Wood VC, Schuster BL. Physician practice patterns resemble ACGME duty hours. Am J Med. United States. 2009:587-93. [pmid: 19486724].
13 Fletcher KE, Reed DA, Arora VM. Patient safety, resident education and resident well-being following implementation of the 2003 ACGME duty hour rules. J Gen Intern Med. 2011;26:907-19. [pmid: 21369772].
14 Moonesinghe SR, Lowery J, Shahi N, Millen A, Beard JD. Impact of reduction in working hours for doctors in training on postgraduate medical education and patients' outcomes: systematic review. BMJ. 2011;342:d1580. [pmid: 21427046].
15 Tabrizian P, Rajhbeharrysingh U, Khaitov S, Divino CM. Persistent noncompliance with the work-hour regulation. Arch Surg. United States. 2011:175-8. [pmid: 21339428].
16 Landrigan CP, Barger LK, Cade BE, Ayas NT, Czeisler CA. Interns' compliance with accreditation council for graduate medical education work-hour limits. JAMA. United States. 2006:1063-70. [pmid: 16954485].
17 Landrigan CP, Fahrenkopf AM, Lewin D, et al. Effects of the accreditation council for graduate medical education duty hour limits on sleep, work hours, and safety. Pediatrics. United States. 2008:250-8. [pmid: 18676540].
18 Fahrenkopf AM, Sectish TC, Barger LK, et al. Rates of medication errors among depressed and burnt out residents: prospective cohort study. BMJ. England. 2008:488-91. [pmid: 18258931].
19 West CP, Tan AD, Habermann TM, Sloan JA, Shanafelt TD. Association of resident fatigue and distress with perceived medical errors. JAMA. 2009;302:1294-300. [pmid: 19773564].
20 Barger LK, Ayas NT, Cade BE, et al. Impact of extended-duration shifts on medical errors, adverse events, and attentional failures. PLoS Med. United States. 2006:e487. [pmid: 17194188].
21 Reed DA, Fletcher KE, Arora VM. Systematic review: association of shift length, protected sleep time, and night float with patient care, residents' health, and education. Ann Intern Med. United States. 2010:829-42. [pmid: 21173417].
22 Reed DA, Levine RB, Miller RG, et al. Effect of residency duty-hour limits: views of key clinical faculty. Arch Intern Med. United States. 2007:1487-92. [pmid: 17646602].
23 Cohen-Gadol AA, Piepgras DG, Krishnamurthy S, Fessler RD. Resident duty hours reform: results of a national survey of the program directors and residents in neurosurgery training programs. Neurosurgery. 2005;56:398-403. discussion 398-403. [pmid: 15670388].
24 Vidyarthi AR, Katz PP, Wall SD, Wachter RM, Auerbach AD. Impact of reduced duty hours on residents' educational satisfaction at the University of California, San Francisco. Acad Med. United States. 2006:76-81. [pmid: 16377825].
25 Drolet BC, Spalluto LB, Fischer SA. Residents' perspectives on ACGME regulation of supervision and duty hours--a national survey. N Engl J Med. 2010;363:e34. [pmid: 21121827].
26 Nuckols TK, Escarce JJ. Cost Implications of ACGME's 2011 Changes to Resident Duty Hours and the Training Environment. J Gen Intern Med. 2011.