# Tubing Misconnections: Brief Review (NEW)

## How Important Is the Problem?

Tubing lines connect patients to devices and allow for the delivery of medication or nutrition therapy. Liquid-to-liquid misconnections can introduce fluids, medications, or nutritional formulas into the wrong body part.1 Gas-to-liquid misconnections can deliver gas into the vasculature or liquid into the respiratory tract.2 The consequences of tubing misconnections include severe patient harm and death.

Although misconnections have been recognized as a serious problem for years, incidents are still common.3 One of the first publications of a tubing misconnection (enteral) was in 1972 reporting the inadvertent intravenous (IV) administration of breast milk.2 From January 1, 2000 to December 31, 2006 the United States Pharmacopeia (USP) collected a total of 24 reports of tubing misconnections of an enteral feeding formula, other solutions, or medications intended for the feeding tube but administered via the wrong route.2 Eight (33%) of the reports resulted in permanent injury, life threatening situation, and/or death.2 Between January 2008 and September 2009, the Pennsylvania Patient Safety Authority received 36 reports of tubing misconnections, with the incidents ranging from near misses to serious events; 35 were liquid-to-liquid events and one was liquid-to-gas.3

Factors that contribute to misconnections include lines that have been disconnected and need to be reconnected, the use of adapters to permit connections that are meant to be impossible, luer fittings (male and female components) allowing a variety of lines to be connected with no indication that the connection might be inappropriate, and line connectors with similar features.1 Luer fittings have been listed by ECRI Institute as one of the top 10 technology hazards for 2011^1^

Human error is one factor resulting in tubing misconnections. Clinicians are often under time pressure, experience rotating shift work and fatigue, and attempt to use short-term recall for large amounts of information.2 Inadequate training and lighting, moving patients from one setting or service to another, and using tubes or catheters for unintended purposes (e.g., IV extension tubing for epidurals, irrigation, etc.) can also result in tubing misconnections.2

## What Is the Patient Safety Practice?

Engineering (i.e., design) controls and the implementation of administrative controls (hospital policies and work practices) are the two basic means that can minimize misconnections. Human error is inevitable and may cause fatalities when tubing lines are misconnected. Therefore, the Joint Commission has urged product manufacturers to implement appropriate “designed incompatibility” to prevent dangerous misconnections of tubes and catheters.2

According to ECRI Institute, engineering controls to reduce misconnections fall into three categories: connectors with physical incompatibilities (leaving users with little or no choice but to make the correct connection), connectors with locking mechanisms (to prevent accidental disconnection), and connectors with a distinct physical appearance (size, shape, or color).4 In 2000, The European Standards Organization created a standard using a graduated catheter tip on the distal end of enteral tubing and standardized the proximal end of the tubing by replacing the spike with a screw-type connection.5 In 2007, a catheter-adapter tip (i.e., “Christmas-tree” connector) was standardized in the United States for the distal end of enteral feeding tubing to prevent staff from plugging it into IV equipment.5

Until appropriately designed tubing is developed and consistently supplied, it is recommended that hospitals incorporate both design solutions and work practices to decrease and eliminate any tubing misconnections.1,6 Organizations such as The Joint Commission, The International Organization for Standardization, and ECRI Institute have published tubing misconnection risk reduction strategies for clinical and non-clinical staff (e.g., Clinical/biomedical engineering, risk management, purchasing, etc.), and specific to general tubing and enteral tubing. We have listed the general tubing misconnection risk reduction strategies below and organized the list by the target audience.

### Clinical Staff1,7

- Trace all lines back to their point of origin to verify that correct connections are made
- Recheck connections and trace all lines to their point of origin after the patient's arrival to a new care area or as part of a handoff process
- Do not force connections
- Only use adapters in accordance with hospital policy for a specific indication
- Label certain high-risk catheters as to the type of catheter (e.g., epidural, intrathecal)
- Route lines with different purposes in unique and standardized directions (e.g., IV line towards patient's head, enteral feeding line towards patient's feet)
- Identify and manage conditions that may contribute to worker fatigue, which could result in inattentiveness when making connections

### Non-Clinical Staff1,7

- Provide regular misconnection prevention education to all personnel working in the patient care environments (e.g., explain the need to request help rather than attempting to disconnect or reconnect lines).
- Assess the need for adapters throughout the facility, and establish policies to limit or restrict their routine use
- Revise and/or establish purchasing policies that include, when possible, purchasing equipment with misconnection safeguards (e.g., avoid purchasing nonintravenous equipment)

The risk reduction strategies suggested for enteral feeding misconnections for clinical and non-clinical staff include the following.

### Clinical Staff1,7

- Do not use standard luer syringes for oral medications or enteral feedings
- Do not modify or adapt IV or enteral feeding devices
- Route lines with different purposes in unique and standardized directions (e.g., route IV lines towards patient's head, route enteral feeding lines towards patient's feet)
- Identify and manage conditions that may contribute to worker fatigue
- Review identification labels before administering solutions to ensure that the intended delivery route is correct
- Placing labels with warnings - “WARNING” for Enteral Use Only – Not for IV Use

### Non-Clinical Staff1,7

- Ensure that an adequate number of distinctly labeled enteral pumps are purchased to reduce or eliminate the use of infusion pumps for enteral administration to adult patients
- Reinforce existing purchasing policies that mandate purchasing only enteral feeding sets that are incompatible with female luer connectors
- When possible purchase only non-IV compatible enteral feeding containers
- Secure enteral administration sets with enteral feeding containers (e.g., with rubber band) or pre-attached sets from the manufacturer before sending them to the patient care unit
- Perform pre-purchase evaluations of enteral feeding systems under the guidance of a multidisciplinary task force before purchasing decisions are made

According to ECRI Institute, the single most important work practice solution for clinicians is to trace all lines back to their origin before connecting or disconnecting any devices and infusions.8 Additional strategies that may be useful include ensuring proper lighting when making connections, contacting manufacturers to determine if luer fittings can be replaced with different connector types, storing medications for different delivery routes in different locations, and using a color-code system.1

## Why Should the Patient Safety Practice Work?

Theoretically, the combination of engineering controls and a change in work practices will prevent any tubing misconnections. The engineering controls have varying levels of effectiveness.4 The forcing function is the most reliable approach since it leaves the user with little or no choice but to make the correct connection.4 Other solutions will prompt users to make the correct connection by identifying the appropriate connector size, etc.

Work practice solutions such as tracing lines back to the point of origin verifies that the correct lines will be connected and ultimately avoids errors. Trainings provided by manufacturers will help users understand the equipment and its safeguards. While trainings provided by the facility will increase the awareness of clinical and non-clinical staff of appropriate tubing misconnection policies and procedures (e.g., potential consequences), only trained staff should reconnect disconnected lines.

## What Are the Benefits of the Patient Safety Practice?

The hospital environment is filled with lines and cables connecting medical devices with patients and can cause confusion when patients are being connected or reconnected to the lines.1 The most important benefit of implementing equipment design solutions and changes in work practices is the reduction and elimination of severe patient harm or death as a result of tubing misconnections.

Searches performed for this report identify three studies that implemented work practice and engineering controls. Each facility's needs varied and the PSP implemented was based on the specific needs. The multidisciplinary staff at Beaumont Commercialization Center in Royal Oak, Michigan identified and examined potential connector hazards, produced educational materials, provided hands-on training, and revised equipment purchasing procedures and staff guidelines.9 Woods and Schultz (2006)10 reported the standardization of labeling procedures and nomenclature used by materials management and clinical staff at Columbus Children's Hospital.10 In-house equipment was also assessed for potential to contribute to misconnections and revisions were made for future purchasing policies. Both studies report the elimination of tubing misconnections. A third study by Lawton (2010)11 assessed the use of a new non-luer device and a color-coding system.11 Clinicians involved in the study report that the device would benefit patient safety and would be willing to adopt the non-luer device with resolutions to design concerns.

Although the solutions implemented in these studies varied, each facility used a combination of equipment and work practice solutions to address the tubing misconnection problem.

## What Are the Harms of the Patient Safety Practice?

Labeling and color-coding tubing lines have been suggested as ways to reduce misconnections. The Joint Commission and U.S. Pharmacopeia Medication Safety Forum have acknowledged the potential in these methods. However, in the tubing misconnection Sentinel Event Alert, The Joint Commission noted that users may rely on color-coding rather than assuring a clear understanding of correct connections between tubes or catheters and body inlets.7 Ongoing education and training about the color-coding system would be necessary for staff on-site, as well as temporary or traveling staff. One study identified in our search results mentioned a concern regarding the use of a color-coding system. Clinicians involved in a study by Lawton (2010)11 were concerned with this system since visual discrimination is not possible in poor lightning conditions.11 Another variable of consideration is the potential for various facilities within the same geographic area to use different color-coding systems which could lead to confusion, particularly for temporary or travel staff.7

## How Has the Patient Safety Practice Been Implemented, and in What Contexts?

One of the first steps to implementing a risk reduction strategy is to formally assess the current state of the work practices, equipment, and identify areas of improvement. One facility is likely to have specific misconnection risks that require special attention compared with the needs of another facility.4 A multidisciplinary task force should perform a formal risk assessment to gauge the overall risks and the strategies that will reduce these risks.4

In 2004, the Beaumont Commercialization Center in Royal Oak, Michigan undertook a program to address the problem of tubing misconnections.9 The task force collected all equipment from the pediatric intensive care unit, developed human factors testing protocols, and examined the connectors to identify potential misconnections and their severity.9 Along with educational materials, employees had the opportunity to receive hands on training by performing correct and incorrect connections via a “training bear”. This allowed staff to identify the right and wrong way to connect tubing lines. As a result of this process, a corporate Misconnection Prevention Policy was created and covered equipment purchases, technical and safety testing, risk assessment, guidelines for clinical staff, and orientation and education.9 Also, Beaumont reports that its misconnection rate dropped to zero.9

Lawton (2010) investigated the potential for and implementation of non-luer compatible equipment for use in spinal procedures.11 The findings indicated that clinicians were enthusiastic about the use of new well-designed devices for intrathecal chemotherapy, but not spinal (i.e., epidural) anesthesia as they were not convinced the devices will help tackle the problem of spinal drug errors.11 The clinicians were also concerned with color-coding since visual discrimination is not possible in poor lightning conditions, non-translucent devices preventing the ability to see what a needle is doing and if it has reached the right place during injections, and drug leakage.11 Overall, if the identified design issues are resolved, clinicians would be willing to adopt the non-luer devices because they believe patient safety will benefit from implementation.11

In 2004, the Columbus Children's Hospital conducted a Health Failure Mode and Effects Analysis (HFMEA) to identify the inherent risks of use and labeling of various enteral, parenteral, and other tubing types in patient care and the potential for harm.10 Woods and Shultz (2006) found three common themes causing all failure modes: non-standardized labeling of tubing, lack of knowledge of nomenclature or alias, and inconsistent inventory.10 Labeling of tubing with infused mechanisms happened 85% of the time in the pediatric intensive care unit, 53% of the time during surgery, and 93% of the time during interventional radiology. The risk reduction methods subsequently implemented involved the standardization of the labeling process throughout the organization (e.g., color of labels, content on label, size and placement of tubing), and the development of an online pictorial catalog listing all available supplies by category and the nomenclature used by materials management and “common names” used by clinical staff.10 The third risk reduction method conducted an inventory with the help from clinical staff and materials management to identify currently used tubing, connectors that fit properly and those that needed to be removed from practice, and devices that needed to be purchased. According to the authors, several recommendations have been implemented and no tubing misconnections have been reported.10

Another point of consideration when implementing the PSP for tubing misconnections is cost. In 2008, Peter Angood, the chief patient safety officer and vice president of The Joint Commission stated that “the cost of acquiring new devices, identifying risky connections and practices, and implementing training and testing will no doubt impact hospitals.”12 However, “the cost of not making such changes could, of course, be much greater in terms of lives lost – erroneous connections between tubes and catheters can create catastrophic outcomes, even death” says Angood.12

## Conclusions and Comments

Ideally, the combination of engineering controls and a change in work practices should eliminate all tubing misconnections. Organizations such as The Joint Commission, The International Organization for Standardization, and ECRI Institute have been consistent with suggestions for solutions to reduce the risks of tubing misconnections. In general, suggestions for work practice solutions include tracing lines back to the point of origin, rechecking connections and tracing lines when moving a patient or when work shifts change, not forcing connections, using appropriate adapters, labeling high-risk catheters, routing lines in different directions, and addressing and managing conditions contributing to worker fatigue. Equipment design solutions involve assessing the need for adapters, revising purchasing procedures, and educating clinical staff on correct equipment use. Angood states, “this area of healthcare is difficult to get under control because the issues cut across several sectors within the industry. It will take time before a coordinated approach occurs to address these issues. In the interim, organizations and all practitioners must be highly vigilant about preventing misconnections.”12 Chapter 31 reviews the evidence for Human Factors and Ergonomics (HFE). The goal of HFE is to address physical, cognitive, and organizational issues of devices. The importance of designing devices that help reduce human error is discussed further in this chapter.

As seen in the previously mentioned studies, each facility will have specific needs and inherent risks that require the implementation of different risk reduction strategies. Again, one of the most important work practice solutions involves the tracing of lines back to the point of origin. Regardless of the differences between facilities, it is recommended that facilities perform a risk assessment to determine their ultimate needs in equipment changes and work practice policy updates. A summary table is located below (Table 1).

Table 1, Chapter 42 Summary table

Scope of the Problem Targeted by the PSP (Frequency/Severity) | Strength of Evidence for Effectiveness of the PSPs | Evidence or Potential for Harmful Unintended Consequences | Estimate of Cost | Implementation Issues: How Much do We Know?/How Hard Is it?
Common/Moderate | Low | Low | Low | Moderate/Not Difficult

## References

1 ECRI Institute. Health devices. Health Devices. Mar. 2006;35(3):79-107.
2 Guenter P, Hicks RW, Simmons D, et al. Enteral feeding misconnections: a consortium position statement. Jt Comm J Qual Patient Saf. May. 2008;34(5):285-92. 245. [pmid: 18491692].
3 ECRI Institute. Fixing bad links. Preventing misconnections in your hospital. Health Devices. Jul. 2009;38(7):220-7. [pmid: 20848951].
4 ECRI Institute. Healthcare risk control: risk analysis. Supplement A, Special Clinical Services 14. Plymouth Meeting (PA). ECRI Institute. 2007. Jul. Preventing misconnections of lines and cables.
5 Pratt N. Tubing misconnections: a perilous design flaw. Mater Manag Health Care. Nov. 2006;15(11):36-9. [pmid: 17191554].
6 Simmons D, Phillips MS, Grissinger M, et al. Error-avoidance recommendations for tubing misconnections when using Luer-tip connectors: a statement by the USP Safe Medication Use Expert Committee. Jt Comm J Qual Patient Saf. May. 2008;34(5):293-6. 245. [pmid: 18491693].
7 Tubing misconnections: making the connection to patient safety. PA Patient Saf Advis. Jun. 2010;7(2):41-5.
8 Joint Commission on Accreditation of Healthcare Organizations, USA. Tubing misconnections--a persistent and potentially deadly occurrence. Sentinel Event Alert. Apr. 3. 2006;(36):1-3. [pmid: 16594109].
9 ECRI Institute. Fixing bad links. Preventing misconnections in your hospital. Health Devices. Jul. 2009;38(7):220-7. [pmid: 20848951].
10 Kimehi-Woods J, Shultz JP. Using HFMEA to assess potential for patient harm from tubing misconnections. Jt Comm J Qual Patient Saf. Jul. 2006;32(7):373-81. [pmid: 16884124].
11 Lawton R. Testing new devices to help prevent ‘misconnection’ errors in health care. J Health Serv Res Policy. Jan. Suppl 1. 2010;15:79-82. [pmid: 20075137].
12 Cruise C. Education, evaluation are key… sentinel event alert compels hospitals to address tubing and catheter misconnections. Biomed Instrum Technol. Nov-Dec. 2008;42(6):469-70. [pmid: 19012462].